# Bibliography

Albertini JJ, Lyman GH, Cox C, et al. Lymphatic mapping and sentinel node biopsy in the patient with breast cancer. JAMA. 1996;276:1818-22. [pmid: 8946902].
Armstrong K, Eisen A, Weber B. Assessing the risk of breast cancer. N Engl J Med. 2000;342:564-71. [pmid: 10684916].
Askins DG Jr. Common breast problems: detection and management. JSC Med Assoc. 1999 Nov;95:415-9.
Barnwell, JM, Arredondo, MA, Kollmorgen, D, et al. Sentinel node biopsy in breast cancer. Ann Surg Oncol. 1998;5:126-30. [pmid: 9527265].
Barton MB, Elmore JG, Fletcher SW. Breast symptoms among women enrolled in a health maintenance organization: Frequency, evaluation, and outcome. Ann Intern Med. 1999;130:651-7. [pmid: 10215561].
Bass SS, Dauway E, Mahatme A, et al. Lymphatic mapping with sentinel lymph node biopsy in patients with breast cancers < 1 centimeter (T1A-T1B). Am Surg. 1999;65:857-61. [pmid: 10484089].
Bassett LW, Hendrick RE, Bassford TL, et al. High-quality mammography: information for referring providers. Quick reference guide for clinicians No. 13. AHCPR Publication No 95-0633. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. October 1994.
Bassett L, Winchester DP, Caplan RB, et al. Stereotactic core needle biopsy of the breast - a report of the Joint Task Force of the American College of Radiology, American College of Surgeons, and College of American Pathologists. CA Cancer J Clin. 1997;47:171-90. [pmid: 9152175].
Bianchi S, Palli D, Ciatto S, et al. Accuracy and reliability of frozen section diagnosis in a series of 672 nonpalpable breast lesions. Am J Clin Pathol. 1995;103:199-205. [pmid: 7856563].
Bobin JY, Zinzindohoue C, Isaac S, et al. Tagging sentinel lymph nodes: A study of 100 patients with breast cancer. Eur J Cancer. 1999;35:569-73. [pmid: 10492629].
Bodian CA, Perzin KH, Lattes R. Lobular neoplasia. Long term risk of breast cancer and relation to other factors. Cancer. 1996;78:1024-34. [pmid: 8780540].
Bone B, Pentek Z, Perbeck L, et al. Diagnostic accuracy of mammography and contrast-enhanced MR imaging in 238 histologically verified breast lesions. Acta Radiol. 1997;38:489-96. [pmid: 9240665].
Borgstein PJ, Pijpers R, Comans EF, et al. Sentinel lymph node biopsy in breast cancer: Guidelines and pitfalls of lymphoscintigraphy and gamma probe detection. J Am Coll Surg. 1998;186:275-83. [pmid: 9510258].
Brendlinger DL, Robinson R, Sylves V, et al. Stereotactic core breast biopsy. An alternative. Va Med Q. 1994;121:179-84. [pmid: 8061069].
Brown ML, Houn F, Sickles EA, et al. Screening mammography in community practice - Positive predictive value of abnormal findings and yield of follow-up diagnostic procedures. Am J Roentgenol. 1995;165:1373-7. [pmid: 7484568].
Brown TA, Wall JW, Christensen ED, et al. Atypical hyperplasia in the era of stereotactic core needle biopsy. J Surg Oncol. 1998;67:168-73. [pmid: 9530887].
Bruzzi P, Green SB, Byar DP, et al. Estimating the population attributable risk for multiple risk factors using case-control data. Am J Epidemiol. 1985;122:904-14. [pmid: 4050778].
Buadu LD, Murakami J, Murayama S, et al. Patterns of peripheral enhancement in breast masses: Correlation of findings on contrast medium enhanced MRI with histologic features and tumor angiogenesis. J Comput Assist Tomogr. 1997;21:421-30. [pmid: 9135652].
Burak Jr WE, Walker MJ, Yee LD, et al. Routine preoperative lymphoscintigraphy is not necessary prior to sentinel node biopsy for breast cancer. Am J Surg. 1999;177:445-9. [pmid: 10414690].
Burak Z, Argon M, Memis A, et al. Evaluation of palpable breast masses with 99Tcm-MIBI: A comparative study with mammography and ultrasonography. Nucl Med Commun. 1994;15:604-12. [pmid: 7970442].
Burbank F. Stereotactic breast biopsy of atypical ductal hyperplasia and ductal carcinoma in situ lesions: improved accuracy with directional, vacuum-assisted biopsy. Radiology. 1997;202:843-7. [pmid: 9051043].
Byrne C, Schairer C, Wolfe J, et al. Mammographic features and breast cancer risk -- effects with time, age, and menopause status. J Nat Cancer Inst. 1995;87:1622-9. [pmid: 7563205].
Cabanas RM. An approach for the treatment of penile carcinoma. Cancer. 1977;39:456-66. [pmid: 837331].
Canavese G, Gipponi M, Catturich A, et al. Sentinel lymph node mapping opens a new perspective in the surgical management of early-stage breast cancer: A combined approach with vital blue dye lymphatic mapping and radioguided surgery. Semin Surg Oncol. 1998;15:272-7. [pmid: 9829386].
Carson W, Sanchez-Forgach E, Stomper P. Lobular carcinoma in situ: observation without surgery as an appropriate therapy. Ann Surg Onc. 1994:141-6.
Charnvises S. The accuracy of mammography: A comparison with fine needle aspiration cytology. J Med Assoc Thai. 1996;79:27-30. [pmid: 8867398].
Ciatto S, Del Turco MR, Bonardi R, et al. Non-palpable lesions of the breast detected by mammography. Review of 1182 consecutive histologically confirmed cases. Eur J Cancer. 1994;30A:40-4. [pmid: 8142162].
Ciatto S, Rosselli DT, Catarzi S, et al. The contribution of ultrasonography to the differential diagnosis of breast cancer. Neoplasma. 1994;41:341-5. [pmid: 7870218].
Cimitan M, Volpe R, Candiani E, et al. The use of thallium-201 in the preoperative detection of breast cancer: An adjunct to mammography and ultrasonography. Eur J Nucl Med. 1995;22:1110-7. [pmid: 8542893].
Claus EB, Risch N, Thompson WD. Autosomal dominant inheritance of early-onset breast cancer: implications for risk prediction. Cancer. 1994;73:643-51. [pmid: 8299086].
Cody H. Sentinel lymph node mapping in breast cancer. Oncology. 1999;13:25-34. [pmid: 10027197].
Colditz GA, Hankinson SE, Hunter DJ, et al. The use of estrogens and progestins and the risk of breast cancer in postmenopausal women. N Engl J Med. 1995;332:1589-93. [pmid: 7753136].
Colditz GA, Willett WC, Hunter DJ, et al. Family history, age, and risk of breast cancer: prospective data from the Nurses' Health Study. JAMA. 1993;270:338-43. [pmid: 8123079].
Costantino JP, Gail MH, Pee D, et al. Validation studies for models projecting the risk of invasive and total breast cancer incidence. J Natl Cancer Inst. 1999;91:1541-8. [pmid: 10491430].
Cox CE, Pendas S, Cox JM, et al. Guidelines for sentinel node biopsy and lymphatic mapping of patients with breast cancer. Ann Surg. 1998;227:645-51. [pmid: 9605656]. [pmcid: 1191339].
Crossin JA, Johnson AC, Stewart PB, et al. Gamma-probe-guided resection of the sentinel lymph node in breast cancer. Am Surg. 1998;64:666-8. [pmid: 9655279].
Cserni G. Estimating the overlap between sentinel lymph nodes and axillary node samples in breast cancer. Pathol Oncol Res. 1999;5:129-33. [pmid: 10393365].
Daly MB, Lerman CL, Ross E, et al. Gail model breast cancer risk components are poor predictors of risk perception and screening behavior. Breast Cancer Res Treat. 1996;41:59-70. [pmid: 8932877].
Dawson JS, Wilson AR. Short-term recall for 'probably benign' mammographic lesions detected in a three yearly screening programme. Clin Radiol. 1994;49:391-5. [pmid: 8045062].
De Cicco C, Chinol M, Paganelli G. Intraoperative localization of the sentinel node in breast cancer: Technical aspects of lymphoscintigraphic methods. Semin Surg Oncol. 1998;15:268-71. [pmid: 9829385].
De Cicco C, Cremonesi M, Luini A, et al. Lymphoscintigraphy and radioguided biopsy of the sentinel axillary node in breast cancer. J Nucl Med. 1998;39:2080-4. [pmid: 9867145].
Dowlatshahi K, Fan M, Bloom KJ, et al. Occult metastases in the sentinel lymph nodes of patients with early stage breast carcinoma: A preliminary study. Cancer. 1999;86:990-6. [pmid: 10491525].
Dupont WD, Page DL, Parl FF, et al. Estrogen replacement therapy in women with a history of proliferative breast disease. Cancer. 1999;85:1277-83. [pmid: 10189132].
Edge SB and Hurd TA. Sentinel node update: Breast cancer. Oncology NCCN Proceedings. 1999:213-7.
Ernster VL, Barclay J, Kerlikowske K. Mortality among women with ductal carcinoma in situ of the breast in the population-based surveillance, epidemiology and end results program. Arch Intern Med. 2000;160:953-8. [pmid: 10761960].
Falkeborn M, Persson I, Adami HO, et al. The risk of acute myocardial infarction after oestrogen and oestrogen-progestogen replacement. Br J Obst Gyn. 1992;99:821-8.
Faulk RM, Sickles EA, Sollitto RA, et al. Clinical efficacy of mammographic screening in the elderly. Radiology. 1995;194:193-7. [pmid: 7997552].
Feldman SM, Krag DN, McNally RK, et al. Limitation in gamma probe localization of the sentinel node in breast cancer patients with large excisional biopsy. J Am Coll Surg. 1999;188:248-54. [pmid: 10065813].
Felson DT, Zhang Y, Hannan MT, et al. The effect of postmenopausal estrogen therapy on bone density in elderly women. N Engl J Med. 1993;329:1141-6. [pmid: 8377776].
Finucane FF, Madans JH, Bush TL, et al. Decreased risk of stroke among postmenopausal hormone users. Arch Intern Med. 1993;153:73-9. [pmid: 8422201].
Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 1998;90:1371-88. [pmid: 9747868].
Fisher ER, Costantino J, Fisher B, et al. Pathologic findings from The National Surgical Adjuvant Breast Project (NSABP) Protocol B-17. Five-year observations concerning lobular carcinoma in situ. Cancer. 1996;78:1403-16. [pmid: 8839545].
Fleming ID, Cooper JS, Henson DE, et al, editors. AJCC Cancer Staging Manual. 5^th^ ed. Philadelphia: Lippincott-Raven; 1997.
Flynn MB, Amin EA, Martin RC. Mobile mammography screening: The James Graham Brown Cancer Center three year experience. Implications for public and professional education. J Ky Med Assoc. 1998;96:17-20. [pmid: 9470312].
Foote FW, Stewart FE. Lobular carcinoma in situ, a rare form of mammary cancer. Am J Pathol. 1941;17:491-505. [pmid: 19970575].
Ford K, Marcus E, Lum B. Breast cancer screening, diagnosis, and treatment. Dis Mon. 1999;45:333-405. [pmid: 10513286].
Fowble B, Hanlon AL, Patchefsky A, et al. The presence of proliferative breast disease with atypia does not significantly influence outcome in early-stage invasive breast cancer treated with conservative surgery and radiation. Int J Radiation Oncol Biol Phys. 1998;42:105-15.
Gabriel H. The dilemma of lobular carcinoma in situ at precutaneous biopsy: to excise or to monitor. AJR. 1999;173:200-2.
Gail MH, Brinton LA, Byar DP, et al. Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst. 1989;81:1879-86. [pmid: 2593165].
Galimberti V, Zurrida S, Zucali P, et al. Can sentinel node biopsy avoid axillary dissection in clinically node-negative breast cancer patients?. Breast. 1998;7:8-10.
Gapstur SM, Morrow M, Sellers TA. Hormone replacement therapy and risk of breast cancer with a favorable histology: Results of the Iowa Women's Health Study. JAMA. 1999;281:2091-7. [pmid: 10367819].
Giuliano AE, Haigh PI, Brennan MB, et al. Prospective observational study of sentinel lymphadenectomy without further axillary dissection in patients with sentinel node-negative breast cancer. J Clin Oncol. 2000;18:2553-9. [pmid: 10893286].
Giuliano AE, Jones RC, Brennan M, et al. Sentinel lymphadenectomy in breast cancer. J Clin Oncol. 1997;15:2345-50. [pmid: 9196149].
Grady D, Rubin SM, Petitti DB, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Int Med. 1992;117:1016-41. [pmid: 1443971].
Guenther JM, Krishnamoorthy M, Tan LR. Sentinel lymphadenectomy for breast cancer in a community managed care setting. Cancer J Sci Am. 1997;3:336-40. [pmid: 9403045].
Gulec SA, Moffat FL, Carroll RG, et al. Sentinel node localization in early breast cancer. J Nucl Med. 1998;39:1388-93. [pmid: 9708514].
Gump F, Dinne D, Schwartz GF. Current treatment for lobular carcinoma in situ. Ann Surg Onc. 1998;5:33-6.
Hammond CB. Menopause and hormone replacement therapy: an overview. Obstet Gynecol (Suppl). 1996;87:2S-15S.
Harkins K, Tartter PI, Hermann G, et al. Multivariate analysis of roentgenologic characteristics and risk factors for nonpalpable carcinoma of the breast. J Am Coll Surg. 1994;178:149-54. [pmid: 8173725].
Harvey JA. Use and cost of breast imaging for postmenopausal women undergoing hormone replacement therapy. Am J Roentgenol. 1999;172:1615-9. [pmid: 10350301].
Herrington D. Study could show whether estrogen treatment stops advancing heart disease in women. ACC 49th Annual Scientific Session Late-Breaking Clinical Trials in Interventional Cardiology; 2000; Anaheim, CA. Available from: <http://www.acc.org/session/conf2000/media/late/estrogen.html>.
Hill AD, Tran KN, Akhurst T, et al. Lessons learned from 500 cases of lymphatic mapping for breast cancer. Ann Surg. 1999;229:528-35. [pmid: 10203086]. [pmcid: 1191739].
Hindle WH, Chen EC. Accuracy of mammographic appearances after breast fine-needle aspiration. Am J Obstet Gynecol. 1997;176:1286-90. [pmid: 9215186].
Hindle WH, Davis L, Wright D. Clinical value of mammography for symptomatic women 35 years of age and younger. Am J Obstet Gynecol. 1999;180:1484-90. [pmid: 10368495].
Hong MK, Romm PA, Reagan K, et al. Effects of estrogen replacement therapy on serum lipid values and angiographically defined coronary artery disease in postmenopausal women. Am J Cardiol. 1992;69:176-8. [pmid: 1731455].
Huang CS, Wu CY, Chu JS, et al. Microcalcifications of non-palpable breast lesions detected by ultrasonography: Correlation with mammography and histopathology. Ultrasound Obstet Gynecol. 1999;13:431-6. [pmid: 10423808].
Hulley S, Grady D, Bush T, et al. Ramdomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. JAMA. 1998;280:605-13. [pmid: 9718051].
Hunter TB, Roberts CC, Hunt KR, et al. Occurrence of fibroadenomas in postmenopausal women referred for breast biopsy. J Am Geriatr Soc. 1996;44:61-4. [pmid: 8537592].
Anaheim, CA. Available from: <http://www.acc.org/session/conf2000/media/late/estrogen.html>.
Irwig L, Tosteson PNA, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994;120:667-76. [pmid: 8135452].
Jackman RJ, Burbank F, Parker SH, et al. Atypical ductal hyperplasia diagnosed at stereotactic breast biopsy: Improved reliability with 14-gauge, directional, vacuum-assisted biopsy. Radiology. 1997;204:485-8. [pmid: 9240540].
Jaderborg JM, Harrison PB, Kiser JL, et al. The feasibility and accuracy of the sentinel lymph node biopsy for breast carcinoma. Am Surg. 1999;65:699-703. [pmid: 10432076].
Janes RH, Bouton MS. Initial 300 consecutive stereotactic core-needle breast biopsies by a surgical group. Am J Surg. 1994;168:533-7. [pmid: 7977991].
Kaelin CM, Smith TJ, Homer MJ, et al. Safety, accuracy, and diagnostic yield of needle localization biopsy of the breast performed using local anesthesia. J Am Coll Surg. 1994;179:267-72. [pmid: 8069420].
Kao CH, Wang SJ, Liu TJ. The use of technetium-99m methoxyisobutylisonitrile breast scintigraphy to evaluate palpable breast masses. Eur J Nucl Med. 1994;21:432-5. [pmid: 8062849].
Kapteijn BA, Nieweg OE, Petersen JL, et al. Identification and biopsy of the sentinel lymph node in breast cancer. Eur J Surg Oncol. 1998;24:427-30. [pmid: 9800974].
Kerin MJ, O'Hanlon DM, Khalid AA, et al. Mammographic assessment of the symptomatic nonsuspicious breast. Am J Surg. 1997;173:181-4. [pmid: 9124622].
Klimberg VS, Rubio IT, Henry R, et al. Subareolar versus peritumoral injection for location of the sentinel lymph node. Ann Surg. 1999;229:860-4. [pmid: 10363900]. [pmcid: 1420833].
Krag D, Weaver D, Ashikaga T, et al. The sentinel node in breast cancer -- A multicenter validation study. N Engl J Med. 1998;339:941-6. [pmid: 9753708].
Lambe M, Hsieh CC, Trichopoulos D, et al. Transient increase in the risk of breast cancer after giving birth. N Engl J Med. 1994;331:5-9. [pmid: 8202106].
Lee MM, Petrakis NL, Wrensch MR, et al. Association of abnormal nipple aspirate cytology and mammographic pattern and density. Cancer Epidemiol Biomarkers Prev. 1994;3:33-6. [pmid: 8118383].
Lein BC, Alex WR, Zebley DM, et al. Results of needle localized breast biopsy in women under age 50. Am J Surg. 1996;171:356-9. [pmid: 8615472].
Liberman L, Abramson AF, Squires FB, et al. The breast imaging reporting and data system: positive predictive value of mammographic features and final assessment categories. Am J Roentgenol. 1998;171:35-40. [pmid: 9648759].
Liberman L, Cody HS, Hill AD, et al. Sentinel lymph node biopsy after percutaneous diagnosis of nonpalpable breast cancer. Radiology. 1999;211:835-44. [pmid: 10352613].
Liberman L, Cohen MA, Dershaw DD, et al. Atypical ductal hyperplasia diagnosed at stereotaxic core biopsy of breast lesions: an indication for surgical biopsy. Am J Roentgenol. 1995;164:1111-3. [pmid: 7717215].
Liberman L, Sama M, Susnik B, et al. Lobular carcinoma in situ at percutaneous breast biopsy: surgical biopsy findings. AJR. 1999;173:291-9. [pmid: 10430122].
Lidbrink E, Elfving J, Frisell J, et al. Neglected aspects of false positive findings of mammography in breast cancer screening: Analysis of false positive cases from the Stockholm trial. Br Med J. 1996;312:273-6. [pmid: 8611781].
Linehan DC, Hill AD, Akhurst T, et al. Intradermal radiocolloid and intraparenchymal blue dye injection optimize sentinel node identification in breast cancer patients. Ann Surg Oncol. 1999;6:450-4. [pmid: 10458682].
Linehan DC, Hill AD, Tran KN, et al. Sentinel lymph node biopsy in breast cancer: Unfiltered radioisotope is superior to filtered. J Am Coll Surg. 1999;188:377-81. [pmid: 10195721].
Lishman SC and Lakhani SR. Atypical lobular hyperplasia and lobular carcinoma in situ: surgical and molecular pathology. Histopathology. 1999;35:199-200.
Lumachi F, Marzola MC, Zucchetta P, et al. Breast cancer detection with 99m-Tc-sestamibi scintigraphy, mammography, and fine needle aspiration cytology: comparative study in 64 surgically treated patients. Ann Surg Oncol. 1999;6:568-71. [pmid: 10493625].
Madigan MP, Ziegler RG, Benichous J, et al. Proportion of breast cancer cases in the United States explained by well-established risk factors. J Natl Cancer Inst. 1995;87:1681-5. [pmid: 7473816].
Maffioli L, Agresti R, Chiti A, et al. Prone scintimammography in patients with non-palpable breast lesions. Anticancer Res. 1996;16:1269-73. [pmid: 8702249].
Margolese RG, Cantin J, Bouchard F The palpable breast lump: information and recommendations to assist decision-making when a breast lump is detected. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer CMAJ 1998 158(Suppl 3):S3 8 9484272
Markopoulos C, Kakisis J, Kouskos S, et al. Management of nonpalpable, mammographically detectable breast lesions. World J Surg. 1999;23:434-8. [pmid: 10085389].
Marshall LM, Hunter DJ, Connolly JL, et al. Risk of breast cancer associated with atypical hyperplasia of lobular and ductal types. Cancer Epidemiol Biomarkers Prev. 1997;6:297-301. [pmid: 9149887].
McMasters KM, Tuttle TM, Carlson DJ, et al. Sentinel lymph node biopsy for breast cancer: a suitable alternative to routine axillary dissection in multi-institutional practice when optimal technique is used. J Clin Oncol. 2000;18:2560-6. [pmid: 10893287].
Meyer JE, Christian RL, Lester SC, et al. Evaluation of nonpalpable solid breast masses with stereotaxic large-needle core biopsy using a dedicated unit. Am J Roentgenol. 1996;167:179-82. [pmid: 8659367].
Meyer JE, Smith DN, Lester SC, et al. Large-core needle biopsy of nonpalpable breast lesions. JAMA. 1999;281:1638-41. [pmid: 10235159].
Miner TJ, Shriver CD, Jaques DP, et al. Sentinel lymph node biopsy for breast cancer: The role of previous biopsy on patient eligibility. Am Surg. 1999;65:493-8. [pmid: 10366201].
Miner TJ, Shriver CD, Jaques DP, et al. Ultrasonographically guided injection improves localization of the radiolabeled sentinel lymph node in breast cancer. Ann Surg Oncol. 1998;5:315-21. [pmid: 9641452].
Moore MM, Hargett CW, Hanks JB, et al. Association of breast cancer with the finding of atypical ductal hyperplasia at core breast biopsy. Ann Surg. 1997;225:726-33. [pmid: 9230813]. [pmcid: 1190878].
Morgan A, Howisey RL, Aldape HC, et al. Initial experience in a community hospital with sentinel lymph node mapping and biopsy for evaluation of axillary lymph node status in palpable invasive breast cancer. J Surg Oncol. 1999;72:24-30. [pmid: 10477872].
Morrow M. Clinical assessment of breast cancer risk. American Society of Clinical Oncology Educational Book, 36th Annual Meeting. Alexandria, VA: American Society of Clinical Oncology; 2000. p. 621-3.
Mulrow C, Cook DJ, Davidoff F. Systematic reviews: critical links in the great chain of evidence. Ann Intern Med. 1997;156:376-80.
Murray ME, Given-Wilson RM. The clinical importance of axillary lymphadenopathy detected on screening mammography. Clin Radiol. 1997;52:458-61. [pmid: 9202590].
Nwariaku FE, Euhus DM, Beitsch PD, et al. Sentinel lymph node biopsy, an alternative to elective axillary dissection for breast cancer. Am J Surg. 1998;176:529-31. [pmid: 9926784].
O'Hea BJ, Hill AD, El-Shirbiny AM, et al. Sentinel lymph node biopsy in breast cancer: Initial experience at Memorial Sloan-Kettering Cancer Center. J Am Coll Surg. 1998;186:423-7. [pmid: 9544956].
Overmoyer B. Breast cancer screening. Med Clin North Am. 1999;83:1443-66. [pmid: 10584602].
Ozdemir A, Oznur II, Vural G, et al. TL-201 scintigraphy, mammography and ultrasonography in the evaluation of palpable and nonpalpable breast lesions: a correlative study. Eur J Radiol. 1997;24:145-54. [pmid: 9097057].
Paganelli G, De Cicco C, Cremonesi M, et al. Optimized sentinel node scintigraphy in breast cancer. Q J Nucl Med. 1998;42:49-53. [pmid: 9646645].
Pendas S, Dauway E, Cox CE, et al. Sentinel node biopsy and cytokeratin staining for the accurate staging of 478 breast cancer patients. Am Surg. 1999;65:500-5. [pmid: 10366202].
Perdue PW, Galbo C, Ghosh BC. Stratification of palpable and nonpalpable breast cancer by method of detection and age. Ann Surg Oncol. 1995;2:512-5. [pmid: 8591081].
Pijpers R, Meijer S, Hoekstra OS, et al. Impact of lymphoscintigraphy on sentinel node identification with technetium-99m-colloidal albumin in breast cancer. J Nucl Med. 1997;38:366-8. [pmid: 9074519].
Psaty BM, Heckbert SR, Atkins D, et al. The risk of myocardial infarction associated with the combined use of estrogens and progestins in postmenopausal women. Arch Intern Med. 1994;154:1333-9. [pmid: 8002685].
Raju U, Vertes D. Breast papillomas with atypical ductal hyperplasia: A clinicopathologic study. Hum Pathol. 1996;27:1231-8. [pmid: 8912836].
Ratanawichitrasin A, Levy L, Myles J, et al. Experience with lymphatic mapping in breast cancer using isosulfan blue dye. J Womens Health. 1998;7:873-7. [pmid: 9785313].
Rehman S, Sardi A, Spiegler E, et al. Sentinel lymph node mapping for staging breast cancer: Preliminary results of a prospective study. Md Med J. 1999;48:105-10. [pmid: 10394225].
Rothman LP, Harvald TB, Overgaard H. Impalpable breast lesions diagnosed by mammography: Incidence of histologically confirmed malignancy. Eur J Surg. 1996;162:691-4. [pmid: 8908449].
Roumen RMH, Valkenburg JGM, Geuskens LM. Lymphoscintigraphy and feasibility of sentinel node biopsy in 83 patients with primary breast cancer. Eur J Surg Oncol. 1997;23:495-502. [pmid: 9484918].
Rubio IT, Korourian S, Cowan C, et al. Sentinel lymph node biopsy for staging breast cancer. Am J Surg. 1998;176:532-7. [pmid: 9926785].
Rubio IT, Korourian S, Cowan C, et al. Use of touch preps for intraoperative diagnosis of sentinel lymph node metastases in breast cancer. Ann Surg Oncol. 1998;5:689-94. [pmid: 9869514].
Sacks HS, Berrier J, Reitman D, et al. Meta-analyses of randomized controlled trials. N Engl J Med. 1987;316:450-5. [pmid: 3807986].
Sailors DM, Crabtree JD, Land RL, et al. Needle localization for nonpalpable breast lesions. Am Surg. 1994;60:186-9. [pmid: 8116978].
Sandrucci S, Mussa A. Sentinel lymph node biopsy and axillary staging of T1-T2 N0 breast cancer: A multicenter study. Semin Surg Oncol. 1998;15:278-83. [pmid: 9829387].
Sardanelli F, Calabrese M, Zandrino F, et al. Dynamic helical CT of breast tumors. J Comput Assist Tomogr. 1998;22:398-407. [pmid: 9606380].
Sardanelli F, Melani E, Ottonello C, et al. Magnetic resonance imaging of the breast in characterizing positive or uncertain mammographic findings. Cancer Det Prevent. 1998;22:39-42.
Schairer C, Lubin J, Troisi R, et al. Menopausal estrogen and estrogen-progestin replacement therapy and breast cancer risk. JAMA. 2000;283:485-91. [pmid: 10659874].
Schootman M. Factors associated with adequacy of diagnostic workup after abnormal breast cancer screening results. J Am Board Fam Pract. 2000;13:94-100. [pmid: 10764189].
Secker-Walker RH, Vacek PM, et al. Screening for breast cancer: Time, travel, and out-of-pocket expenses. J Natl Cancer Inst. 1999;91:702-8. [pmid: 10218508].
Sellers TA, Mink PJ, Cerhan JR, et al. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer. Ann Intern Med. 1997;127:973-80. [pmid: 9412302].
Seymour HR, Cooke J, Given-Wilson RM. The significance of spontaneous resolution of breast calcification. Br J Radiol. 1999;72:3-8. [pmid: 10341682].
Shaw AD, Gazet JC, Ford HT. The importance of the non-palpable lesion in women under 50, detected by mammography on self-referral for screening, symptoms or follow up. Eur J Surg Oncol. 1995;21:284-6. [pmid: 7781798].
Shields MW, Smith RS, Bardwil MF, et al. Is needle-directed breast biopsy overused?. West J Med. 1994;160:229-31. [pmid: 8191754]. [pmcid: 1022385].
Sickles EA. Breast imaging: From 1965 to the present. Radiology. 2000;215:1-16. [pmid: 10751459].
Sickles EA. Nonpalpable, circumscribed, noncalcified solid breast masses: Likelihood of malignancy based on lesion size and age of patient. Radiology. 1994;192:439-42. [pmid: 8029411].
Sillar R, Howarth D, Clark D. The initial Australian experience of technetium-99m sestamibi scintimammography - A complementary test in the management of breast cancer. Aust NZ J Surg. 1997;67:433-7.
Simonetti G, Cossu E, Montanaro M, et al What's new in mammography European J of Radiol 1998 27(Suppl 2):S234 S241 9652528
Snider H, Dowlatshahi K, Fan M, et al. Sentinel node biopsy in the staging of breast cancer. Am J Surg. 1998;176:305-10. [pmid: 9817244].
Sparano J, Mocharnuk R. Management of premalignant breast lesions and carcinoma in situ. Daily Summaries from the 22nd Annual San Antonio Breast Cancer Symposium. New York: Medscape; 1999. p. 16-7.
Speroff L. Postmenopausal hormone therapy and breast cancer. Obstet Gynecol (Suppl). 1996;87:44S-54S.
Stanford JL, Weiss NS, Voigt LF, et al. Combined estrogen and progestin hormone replacement therapy in relation to risk of breast cancer in middle-aged women. JAMA. 1995;274:137-42. [pmid: 7596001].
Stark A, Hulka BS, Joens S, et al. HER-2/neu amplification in benign breast disease and the risk of subsequent breast cancer. J Clin Oncol. 2000;18:267-74. [pmid: 10637239].
Symmans WF, Weg N, Gross J, et al. A prospective comparison of stereotaxic fine-needle aspiration versus stereotaxic core needle biopsy for the diagnosis of mammographic abnormalities. Cancer. 1999;85:1119-32. [pmid: 10091797].
Taves DH, McCurdy LI, Sparrow RK. The relative diagnostic impact of screening mammography and physical examination. Can Assoc Radiol J. 1996;47:257-9. [pmid: 8696991].
Tran DQ, Wilkerson DK, Namm J, et al. Needle-localized breast biopsy for mammographic abnormalities: A community hospital experience. Am Surg. 1999;65:283-8. [pmid: 10075310].
van der Ent FW, Kengen RA, van der Pol HA, et al. Sentinel node biopsy in 70 unselected patients with breast cancer: Increased feasibility by using 10 mCi radiocolloid in combination with a blue dye tracer. Eur J Surg Oncol. 1999;25:24-9. [pmid: 10188850].
Velentgas P, Daling JR. Risk factors for breast cancer in younger women. J Natl Cancer Inst Monogr. 1994;16:15-22. [pmid: 7999458].
Veronesi U, Paganelli G, Galimberti V, et al. Sentinel-node biopsy to avoid axillary dissection in breast cancer with clinically negative lymph-nodes. Lancet. 1997;349:1864-7. [pmid: 9217757].
Veronesi U, Paganelli G, Viale G, et al. Sentinel lymph node biopsy and axillary dissection in breast cancer: Results in a large series. J Natl Cancer Inst. 1999;91:368-73. [pmid: 10050871].
Vetto JT, Pommier RF, Schmidt WA, et al. Diagnosis of palpable breast lesions in younger women by the modified triple test is accurate and cost-effective. Arch Surg. 1996;131:967-74. [pmid: 8790167].
Vieira MR, Weinholtz JH. Technetium-99m tetrofosmin scintigraphy in the diagnosis of breast cancer. Eur J Surg Oncol. 1996;22:331-4. [pmid: 8783646].
Villanueva-Meyer J, Leonard MHJ, Briscoe E, et al. Mammoscintigraphy with technetium-99m-sestamibi in suspected breast cancer. J Nucl Med. 1996;37:926-30. [pmid: 8683313].
Vural G, Atasever T, Ozdemir A, et al. TL-201 scintigraphy in the evaluation of palpable and nonpalpable breast lesions: Correlation with mammography and ultrasonography. Nuklearmedizin. 1997;36:282-8. [pmid: 17068879].
Vural G, Unlu M, Atasever T, et al. Comparison of indium-111 octreotide and thallium-201 scintigraphy in patients mammographically suspected of having breast cancer: Preliminary results. Eur J Nucl Med. 1997;24:312-5. [pmid: 9143470].
Wakefield SE, Powis SJA. Benign breast surgery: Is there a need for outpatient follow-up?. Ann R Coll Surg Engl. 1995;7:457-9.
Wallace JE, Sayler C, McDowell NG, et al. The role of stereotactic biopsy in assessment of nonpalpable breast lesions. Am J Surg. 1996;171:471-3. [pmid: 8651387].
White J, Levine A, Gustafson G, et al. Outcome and prognostic factors for local recurrence in mammographically detected ductal carcinoma in situ of the breast treated with conservative surgery and radiation therapy. Int J Radiation Oncology Biol Phys. 1995;31:791-7.
Writing Group for the PEPI Trial. Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women: the Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. JAMA. 1995;273:199-208. [pmid: 7807658].
Zurrida S, Bartoli C, Galimberti V, et al. Interpretation of the risk associated with the unexpected finding of lobular carcinoma in situ. Ann Surg Onc. 1996;3:57-61.