# Acknowledgments

We are grateful to the following individuals for their diverse contributions throughout the course of developing this report: Elenie Chadbourne, Rebecca Cintron, Janet Connelly, Matthew Guldin, Veronica Ludensky, Luba Nalysnyk, Christopher Schmid, Sandy Schwartz, Marya Zilberberg, members of the TEP, peer reviewers, representatives from Kaiser, and representatives from AHRQ.