# Recommendations for Future Research

The following recommendations would enable researchers to generate useful data to support answers for the questions posed in this report:

Questions 1 and 3 (risk factors, abnormal clinical or mammographic findings):

- Perform prospective studies that report patients' risk factors, symptoms, cancer incidence, time of cancer diagnosis, and duration of followup. The current literature reports some, but not all, of these elements. Complete information is essential to build an accurate assessment of the relationship between breast cancer risk factors, breast symptoms, and cancer incidence. If this information were available, risk-factor assessment could be used to accurately assess pre-test probability of malignancy and could possibly affect management of patients with breast symptoms.
- Standardize reporting of risk factors.
  - For family history, the number of first degree and more remote relatives with cancer, as well as the age at which cancer was diagnosed are important. Simply reporting the presence or absence of family history is inadequate to support meaningful analysis.
  - Regarding parity, the number of pregnancies and the age at first delivery should be reported. Additionally, age at menarche and age at menopause are needed to estimate duration of estrogen exposure.
  - With reference to HRT, the type of hormone (unopposed estrogen vs. combination therapy), dosages, and duration of therapy are important elements to report.
  - Genetic alterations, including HER-2/neu gene expression in benign breast disease, should be further evaluated with regard to subsequent risk of breast cancer.
- Standardize reporting of mammographic results. The BI-RADS classification is useful and, if generally adopted, could enable researchers to perform valid inter-study comparisons.
- Evaluate role of digital mammography.
- Summary Receiver Operating Characteristics (ROC) curves could be prepared to summarize the sensitivities and specificities of mammography and ultrasound. The sensitivities and specificities from each study could be weighted for its sample size (Irwig, Tosteson, Gatsonis, et al., 1994). The validity of such comparisons may be questioned, however, due to possible variations in mammographic equipment, technique, and operator skill.
- Important new developments in genetic susceptibility for breast cancer and promising new imaging techniques are likely to have a major impact on the diagnosis and management of breast disease. Information on these topics should be collected and included in an update of this systematic review.
- Consider expanding the literature search to include other, less well established risk factors, such as diet, exercise, and alcohol use. Given the limited data on established risk factors, however, it is likely that the information on additional risk factors would be even more sparse.
- Consider expanding the search to include foreign language articles.

Question 2 (management of LCIS and AH):

- Evidence supports tamoxifen therapy as cancer prophylaxis for patients with either LCIS or AH. Further studies need to evaluate the risks and benefits of tamoxifen compared with other SERMs.
- The appropriate duration of SERM therapy needs to be established.
- Further studies should address whether SERMs should be recommended for all patients with AH or LCIS diagnoses or only for patients with additional risk factors.
- Further studies should make an attempt to distinguish the different types of AH to determine whether the subsequent cancer incidence differs between ADH and ALH.

Question 4 (sentinel node biopsy):

- The existing short-term data support performing sentinel node biopsy on most patients with newly diagnosed breast cancer. Long-term data are required, however, before this procedure can be recommended in place of full axillary dissection.
- Further studies should attempt to clarify optimal use of sentinel node biopsy by determining differences in sensitivities based on tumor size, location, and history of breast surgeries. Most studies in this database give baseline information on these characteristics but do not follow up by linking the characteristics with the outcome of sentinel node detection.
- Evaluate use of sentinel node biopsy for DCIS.
- Compare incidence and severity of lymphedema after SLN biopsy vs. ALND.
- Correlate surgeon's amount of experience with success rate for SLN biopsy.
- Determine appropriate degree of pathological dissection of SLN biopsy to maximize identification of malignancy.

## Updating the Database

Given the large volume of information continuing to be published regarding breast cancer, semiannual updates are recommended to keep this evidence base current.

## Harnessing the Available Evidence

This systematic review has led to an evidence base that contains a wealth of data regarding diagnosis and management of breast disease. The relational database could be provided with a navigational software interface that permits easy filtering and exporting for analysis. The evidence base provides a valuable opportunity to test recommendations from clinical practice guidelines against the weight of the best available evidence.