# Conclusions

This systematic review of diagnosis and management of breast disease identified 109 studies published between 1994 and 1999 that met the prospectively determined inclusion criteria. The literature suffers from a lack of standardization of the terms used in reporting information regarding breast disease. The most glaring example of this is the number of studies that referred to numbers of lesions rather than numbers of patients. If all studies reported numbers of patients, comparison of results from different studies would be greatly facilitated.

The following conclusions may be drawn from this systematic review.

Questions 1 and 3 (risk factors, abnormal clinical or mammographic findings):

- The best available evidence suggests that breast symptoms are evaluated by clinical breast exam and mammogram, with supplemental studies when the diagnosis is unclear.
- There is no evidence to support modifying the work-up based on risk factors other than age.
- It was hoped that a risk model, similar to the Gail model, could be created from the data amassed during this project, based not only on risk factors, but also on breast symptoms. This is not possible, however, because individual patient data, rather than aggregate data, are required. If a model could be constructed using aggregate data, age is the only risk factor that could be included, as sufficient information regarding other risk factors is lacking.

Question 2 (management of LCIS and AH):

- Excisional biopsy is essential following SCBX diagnosis of ADH.
- Although data are limited, selective estrogen receptor modulator therapy with tamoxifen appears to markedly decrease the incidence of cancer following a diagnosis of LCIS or AH.
- There is no evidence to support ipsilateral mastectomy after a diagnosis of LCIS.

Question 4 (sentinel node biopsy):

- Sentinel node biopsy is successful in most breast cancer patients and could save millions of women from the more invasive procedure of axillary node dissection. However, the risk of false-negative results must be recognized, in addition to the potential variability of results depending on surgical experience and extent of pathological investigation.