# Results

In the following results, "k" refers to the number of studies, and "n" refers to the number of patients.

## Searches

The numbers of abstracts obtained from searches in Medline and Current Contents^®^ are displayed in Figure 2. The primary search in Medline (search window: 1994-1999) yielded 7,575 abstracts, and the primary search in Current Contents^®^ (search window: 1994-1999) yielded 1,762. When these two groups of citations were merged, 1,147 duplicates were removed resulting in 8,190 unique citations for Level I screening. Bibliographies of all accepted studies were searched for potentially relevant articles. Citations of interest were referenced against a database containing abstracts downloaded from electronic searches of Medline and Current Contents^®^. All citations identified in the database had already undergone Level I screening at an earlier stage in the project. Citations that were not present in the database were retrieved for Level II and Level III screening.

Figure 2: Study Attrition

Over the duration of this project, 8,190 abstracts were screened against protocol-defined exclusion criteria. Of these 8,190 citations, 7,179 were rejected during Level I screening of abstracts. During Level II screening of full-text papers, 413 were rejected (Figure 2). Seventy of the 1,015 potentially eligible papers were not available in any of the three major Boston medical libraries and were not retrieved by the retrieval cut-off date.

During Level III screening of full-text papers, 319 were rejected, and 89 additional studies were rejected during data extraction. The final set of studies is composed of 109 primary and 11 linked or "child" studies.

Evidence Table 1 summarizes the number of studies rejected during Level II screening or data extraction, organized by rejection reason. The most common reasons for rejection included: risk factors not reported (k=253), cancer population (k=131); animal or in vitro studies (k=128), no outcome of interest (k=101), reviews, meta-analyses, letters, case reports, editorials or commentaries (k=55), screening population (k=55), suspicious findings not reported (k=39), and outcomes not extractable (k=11). Less frequently cited reasons for rejection (k < 10) included: < 10 patients total sample size, languages other than English, risk factor outcomes not extractable, indication for sentinel node biopsy not reported, unpublished study reports or abstracts, LCIS/AH management options not reported, DCIS, results of biopsy not reported, and male sex.

The screening strategies were reviewed a priori with the TEP, TOO, and Kaiser Permanente. After the draft report was submitted to the TEP and peer reviewers, three of the reviewers expressed concern regarding the decision to exclude studies consisting entirely of screening populations. They pointed out that most mammographic abnormalities are found in asymptomatic women, i.e., screening populations. However, papers in which the cohort of patients with abnormal mammograms could be identified and followed were accepted for this project.

## Studies

### Study characteristics

Evidence Table 2 describes the most distinguishing characteristics of the 109 studies (n=39,560) accepted for data extraction. Sixty-nine studies (n=28,698) were conducted in North America, compared with 33 studies (n=10,438) conducted in Europe and 7 studies (n=424) conducted in countries in other regions of the world, including Australia, China, Japan, Taiwan, Thailand, and Turkey.

With the exception of one study (Fisher, Constantino, Wickerham, et al., 1998), which was graded as Level I evidence, all studies were classified as reporting Level III (scale of I - V) evidence. Quality score can be calculated only for randomized controlled trials (RCTs), therefore only one study (Fisher, Constantino, Wickerham, et al., 1998) was rated for this parameter; its quality score was three out of five possible points.

Two studies reported industry sponsorship, and two authors mentioned relationships with industry but did not indicate if the studies were sponsored by industry.

Questions 1 & 3 Results: What are the recommendations for evaluation of breast symptoms, mammographic findings and other suspicious findings based on menstrual status, hormone replacement therapy (HRT), pregnancy, age, and family history?

Lack of standardization of risk factor reporting prevents definitive answers. Many studies reported presence of risk factors and breast symptoms. Relatively few studies associated the presence of risk factors (other than age) and symptoms with the eventual diagnosis of breast cancer. Furthermore, studies of breast disease suffer from lack of standardized reporting formats. Specifically, studies reported results in terms of numbers of patients or numbers of lesions. Results could not be combined. The evidence shows that most patients who presented with a breast symptom underwent clinical breast examination and imaging study, regardless of their risk factors. Further imaging modalities, type of biopsy, and performance of biopsy by surgeon vs. radiologist were not impacted by risk factor analysis. While risk factors may be recorded during patient encounters, the presence of a breast symptom or mammographic abnormality overrides the existence of any risk factors in the work-up of each individual patient.

Therefore, the evidence does not support modifying the evaluation of breast symptoms based on risk factors other than age. The only age modification that is mentioned is the use of ultrasound, instead of mammography, for younger women.

The database contains a total of 51 studies plus four kin studies that address Questions 1 and/or 3 (n=30,178). These studies include 25 from North America (n=21,360), 19 from Europe (n=8,394), and seven from other locations (n=424). Twenty-three studies were uncontrolled case series (UCSs) (n=8,149), one study was a noncontrolled randomized trial (nRCT) (n=41), and 27 were observational studies, consisting of 23 retrospective (n=14,070), three prospective (n=4,662), and one cross-sectional (n=3,256). These results are summarized in Evidence Table 2.

Fifty of the 51 studies contained only women. One study of 70 patients (Ozdemir, Oznur, Vural, et al., 1997) included two males and did not discriminate between the outcomes of men and women. Thus, the database is composed of 30,176 women and two men.

An initial requirement for accepting a study was that the results must be reported in units of patients rather than numbers of breasts or numbers of lesions. However, it rapidly became apparent that numerous informative studies would be excluded; therefore, this requirement was removed. All studies reported the number of patients enrolled, but when the results were given, they were often given in terms of lesions, and it was not possible to accurately convert these to numbers of patients. Data were captured in the units that were reported. Thirty-three studies reported results in terms of numbers of patients [n=20,230, of which 4,261 (21.1 percent) developed cancer], 17 studies used numbers of lesions [n=9,766 lesions, of which 2,004 (20.5 percent) led to a diagnosis of cancer], and one study reported numbers of episodes of patients reporting to a clinic with a new breast symptom [Barton, Elmore, and Fletcher, 1999; n=539 episodes, of which 24 (4.4 percent) led to a diagnosis of cancer].

The initial plan was to capture the number of patients with each risk factor and each clinical or mammographic result, the number who were diagnosed with breast cancer at the time of presentation, and the number who developed cancer at a later date. During data extraction, it became apparent that the timing of the cancer diagnosis was infrequently reported; therefore, this approach was abandoned. In most studies, the duration of follow-up was not reported. Therefore, the results in this report for questions 1 and 3 include all patients in whom cancer was diagnosed as a result of a particular clinical or mammographic finding, whether the diagnosis was made at the time of presentation or subsequently.

Diagnosis was made by various biopsy methods. The most commonly reported biopsy method was excisional, or open biopsy (k=19, n=2,506). Fourteen studies each reported needle localization biopsy results (n=3,669) and fine needle aspiration [(FNA), n=2,594]. Six studies reported use of SCBX (n=2,145). Thirteen studies did not report the biopsy method (n=12,272). The number of studies and patients listed here do not equal the number of studies and patients in the database, because some studies reported more than one biopsy technique, some studies did not report how many of their patients underwent biopsies, and some studies did not report any biopsy technique.

### Risk Factors

Very few studies reported risk factors (other than age) in relation to breast abnormalities and cancer incidence.

#### Risk Factors-Age, Menopausal Status

For any symptom or abnormal finding, patients age 50 or older were much more likely to be diagnosed with cancer than patients younger than 50. When each symptom or mammographic abnormality was considered separately, the numbers of patients stratified by age were too small to make valid generalizations to larger populations.

Risk factors for breast cancer were frequently reported, but few studies reported the number of patients with each risk factor who were diagnosed with cancer. Age was the most commonly reported risk factor. It was stratified in a variety of ways, mainly age > 50 vs. < 50 or by decade. For this synthesis, we demarcated age as > 50 vs. < 50. The following results are summarized in Evidence Table 3.

Menopausal status is not specifically listed in these results. For the purpose of data collection, postmenopausal or perimenopausal women were categorized as age 50 or older, and premenopausal women were categorized as younger than 50. From the papers surveyed, it was usually not possible to distinguish patients with natural vs. surgical menopause.

Forty-three studies reported cancer incidence for patients > 50 vs. < 50. This includes one study (Bianchi, Palli, Ciatto, et al., 1995), in which the age demarcation was > 53 vs. < 53, and one study (Markopoulos, Kakisis, Kouskos, et al., 1999), in which the age demarcation was > 50 vs. < 50. For studies that reported in terms of patients (k=29), 23.6 percent of patients > 50 were diagnosed with cancer, compared with 9.5 percent of those < 50 years of age. For studies that reported in terms of lesions (k=14), 22.6 percent of patients > 50 were diagnosed with cancer, compared with 16.3 percent of those < 50. These totals refer to patients who presented with any clinical finding or mammographic abnormality.

Only two studies stratified the number of patient-detected lesions according to the ages at which the patients presented. In Wakefield and Powis, (1995), eighteen patients > 50 detected a symptom, and none of them were diagnosed with cancer, compared with 82 patients < 50 years of age, three of whom were diagnosed with cancer (3.7 percent). In Barton, Elmore, and Fletcher, (1991), 11 of 172 women in their 40s were diagnosed with cancer (6.4 percent), compared with 6 of 136 women in their 50s (4.4 percent), three of 68 women who presented in their 60s (4.4 percent), and 3 of 36 women who presented in their 70s (8.3 percent). Combining the results from these two studies, 12 of 258 patients > 50 with patient-detected lesions were diagnosed with cancer (4.7 percent), compared with 14 of 254 patients < 50 (5.5 percent).

One study (Sardanelli, Melani, Ottonello, et al., 1998) stratified the number of clinician-detected lesions according to the age of the patients (11 patients > 50 had a clinician-detected lesion, 100 percent were diagnosed with cancer, while 4 patients < 50 had a clinician-detected lesion, 75 percent were diagnosed with cancer).

Eleven studies stratified patients by age when reporting information about palpable masses. Nine of the eleven studies reported cancer incidence; six in relation to numbers of patients and three in relation to numbers of lesions. Of patients with palpable masses, 34.6 percent of those > 50 (n=382) were diagnosed with cancer, compared with 8.7 percent of those < 50 years of age (n=1,338). Of lesions in patients with palpable masses, 54.0 percent in patients > 50 were cancerous (n=137), compared with 26.7 percent of lesions in patients < 50 (n=180).

Nipple discharge was reported by age distinctions in three studies, and only two reported cancer incidence, which was 7.0 percent for patients > 50 and 3.8 percent for patients < 50. One study (Lee, Petrakis, Wrensch, et al., 1994) reported the odds ratios (ORs) of breast cancer risk factors in patients with nipple discharge. For patients > 60 years of age, the OR was 15.6, compared with 2.4 for patients aged 50-54, and 2.2 for patients aged 40-49. No studies characterized patients' ages when reporting cancer diagnoses in women with breast pain.

Very few studies reported mammographic findings by age demarcations. These results are summarized in Evidence Table 4. Three studies reported microcalcifications by age group. In one study (Maffioli, Agresti, Chiti, et al., 1996), eight of twelve patients (66.7 percent) > 50 years of age were diagnosed with cancer, compared with five of nine patients (55.6 percent) < 50. In two studies, 14 of 18 lesions (77.8 percent) were determined to be cancerous in patients > 50, compared with 11 of 14 lesions (78.6 percent) in patients < 50.

Five studies reported masses on mammograms according to age. Two studies reported this by number of patients (13 of 13 patients > 50 had cancer, compared with eight of eight patients < 50). Three studies reported this by number of lesions [370 of 888 lesions in patients > 50 were cancerous (41.7 percent), compared with 125 of 879 lesions in patients < 50 (14.2 percent)].

In the studies that reported BI-RADS classification by age group, three studies reported that 19 of 31 patients > 50 with BI-RADS 4 readings had cancer (61.3 percent), compared with 11 of 23 patients < 50 (47.8 percent). Two studies reported that 45 of 48 patients > 50 with BI-RADS 5 readings had cancer (93.8 percent), compared with 33 of 35 patients < 50 (94.3 percent).

#### Risk Factors-Family History

Family history was reported in eight studies, but most did not distinguish between first- or second-degree relatives. One study (Brendlinger, Robinson, Sylvest, et al., 1994) reported the number of patients with cancer who had a positive family history, but it did not report the number of patients with a positive family history who did not have cancer. Of the remaining seven studies, 584 of 1,476 patients with a positive family history were diagnosed with cancer (39.6 percent), compared with 1,575 of 4,642 percent of patients with a negative family history (33.9 percent). One study (Byrne, Schairer, Wolfe, et al., 1995) reported that women with a family history of breast cancer in a first-degree relative had an OR of 1.79 [95 percent confidence interval (CI) 1.6-2.1], compared with women with no family history.

Clinical findings were rarely reported in relation to family history. No studies reported patient-detected lesions, clinician-detected lesions, palpable mass, or breast pain with respect to family history. Only one study (Lee, Petrakis, Wrensch, et al., 1994) reported nipple discharge with respect to family history. Of 87 patients with a nipple discharge and positive family history, five were diagnosed with cancer (5.7 percent, OR 1.5), compared with 12 of 316 patients with a nipple discharge and negative family history (3.8 percent). No studies reported mammographic findings in relation to family history.

#### Risk Factors - Parity

Only two studies reported parity. Byrne, Schairer, Wolfe, et al., (1995) related risk factors, breast density, and odds ratio adjusted for the percent of breast area with dense appearance on mammogram. Nulliparous women had the highest odds ratio (1.63, CI 1.3-2.1) and the highest proportion of women with high breast density (42 percent). Lee, Petrakis, Wrensch, et al., (1994) reported that seven of 156 nulliparous patients with nipple discharge were diagnosed with breast cancer (4.5 percent), compared with 10 of 252 parous patients with nipple discharge (4.0 percent, OR 0.9).

#### Risk Factors-Hormone Replacement Therapy

HRT was frequently mentioned, but only two studies reported the combination of HRT use, abnormal findings, and cancer diagnosis. Harkins, Tartter, Hermann, et al., (1994) reported the number of patients taking and not taking HRT and how many of each developed cancer. The study did not, however, report clinical or mammographic abnormalities of the patients based on their HRT use.

In Harvey (1999), 699 patients took HRT, compared with 434 patients who never used HRT. This study reported the number of patients in each group who presented with palpable masses or pain, but it did not go on to report the number of patients with symptoms who were diagnosed with cancer. It did report cancer incidence in terms of BI-RADS scores; of the 699 patients on HRT, 13 received a BI-RADS score of 4 or 5, and four of these patients (29 percent) were diagnosed with cancer. Of the 434 non-HRT users, 11 received a BI-RADS score of 4 or 5, and seven of these patients (54 percent) were diagnosed with cancer.

These examples are illustrative of the limitations in the database; it is rich with baseline data, but followup information is lacking. Alternatively, followup information is presented without correlation to baseline symptoms or risk factors. In all cases, the small number of patients limits their applicability to the general population.

### Abnormal Findings

Abnormal findings were divided into clinical and mammographic findings. These results are summarized in Evidence Table 5.

#### Abnormal Clinical Findings

Only four studies reported a "patient-detected" symptom; of these, only two studies reported the number of patients diagnosed with cancer (two of 167 patients, or 22.2 percent). Three studies reported "clinician-detected" signs, and 50 of 236 patients (21.2 percent) were diagnosed with cancer.

Seventeen studies reported the presence of palpable masses. Of these 17 studies, 11 reported results in terms of patients. One study did not report the number of patients diagnosed with cancer. In the remaining 10 studies, 303 of 2,027 patients (14.9 percent) with palpable masses developed cancer. Six studies reported results in terms of lesions, of which 358 of 1,094 lesions (32.7 percent) were cancerous. Barton, Elmore, Fletcher, et al., (1999) reported that the likelihood ratio of a palpable mass leading to a cancer diagnosis was 65.

Six studies reported the presence of nipple discharge. Four were reported in terms of patients (18 of 570, or 3.2 percent were diagnosed with cancer), and although two were reported in terms of lesions, only one study reported cancer incidence, in 1 of 67 (3.0 percent) of episodes, for a likelihood ratio of 16 (Barton, Elmore, Fletcher, et al., 1999).

Five studies reported breast pain, but only two reported cancer incidence; 7 of 216 (3.2 percent) of patients (Kerin, O'Hanlon, Khalid, et al., 1997) and four of 221 (1.8 percent) of episodes (Barton, Elmore, Fletcher, et al., 1999). Barton, Elmore, Fletcher, et al., (1999) also reported that the likelihood ratio for pain leading to a diagnosis of cancer was 10.

Questions 1 and 3 Results (continued): What is the management of nonpalpable lesions and calcifications?

The data indicate that patients who present with palpable masses are much more likely to be diagnosed with cancer than patients who present with nonpalpable masses, nipple discharge or breast pain. Microcalcifications or clustered calcifications on mammography were associated with 26.0 to 44.8 percent incidence of cancer. BI-RADS 1, 2, and 3 readings very rarely lead to cancer diagnoses, while 4 and 5 are associated with a cancer incidence of 38.5 to 94.0 percent.

#### Abnormal Mammographic Findings

Most studies reported mammogram results, although their styles of reporting varied widely (Evidence Table 5). Eleven studies reported microcalcifications. Six were reported in terms of patients, five of which reported the number of patients who had cancer (316 of 819 patients, or 38.6 percent). Five studies reported microcalcifications in terms of lesions (250 of 704, or 35.5 percent were cancerous).

Five studies reported clustered calcifications. Two were reported in terms of patients (13 of 29, or 44.8 percent were diagnosed with cancer), while three were reported in terms of lesions (207 of 796, or 26.0 percent were cancerous).

Fifteen studies reported mammographic findings of masses. It was not clear whether these were palpable masses or masses that were detected only by mammography. Eight were reported in terms of patients, but only six reported which patients were diagnosed with cancer (83 of 260 patients, or 31.9 percent). Seven studies reported masses in terms of lesions (672 of 2,514, or 26.7 percent were cancerous).

Three studies reported mammographic findings of masses plus calcifications. Two were reported in terms of lesions (30 of 96, or 31.3 percent were diagnosed with cancer), and one was reported in terms of patients (zero of three were cancerous).

Seven studies reported mammographic findings of parenchymal distortion. Four were reported in terms of patients (22 of 79, or 27.8 percent were diagnosed with cancer), and three were reported in terms of lesions (9 of 50, or 18.0 percent were cancerous).

For the purposes of this report, all densities are considered together. Focal symmetric, diffuse increased, nodular, irregular, and unspecified densities are all included in this category. Four studies reported numbers of patients with densities, but only three reported the number of patients who received a diagnosis of cancer (five of 39, or 12.8 percent). One study reported that six lesions were densities; two of these were cancerous (33.3 percent).

Mammographic results were infrequently reported in terms of BI-RADS scores. When the specific term "BI-RADS" was not used, but the description of the mammogram reports coincided with the BI-RADS terminology, the results were converted into BI-RADS categories. For example, "negative" became BI-RADS 1. This was an attempt to standardize results from different studies and was rarely necessary. Some studies grouped BI-RADS 4 and 5 together and are noted as such in this report. As BI-RADS readings are for entire mammograms, the numbers of lesions are considered to be equivalent to the numbers of patients.

Three studies reported BI-RADS 1, but only two reported incidence of cancer diagnoses (7 of 163, or 4.3 percent). BI-RADS 2 was reported in two studies, but only one reported incidence of cancer diagnosis (19 of 883, or 2.2 percent).

Four studies reported patients with BI-RADS 3 mammographic readings, of which cancer diagnoses were reported for three studies (22 of 2,034, or 1.1 percent incidence). Five studies reported patients with BI-RADS 4 readings. Three of these studies reported the number of patients diagnosed with cancer (30 of 54, or 55.6 percent).

Four studies reported patients with BI-RADS 5 readings. Two of these studies reported the number of patients diagnosed with cancer (78 of 83, or 94.0 percent). Three studies reported patients with BI-RADS 4 + 5 readings, in which 117 of 304 (38.5 percent) were diagnosed with cancer.

Combining the studies with BI-RADS 4, 5, or 4 + 5, in which cancer diagnoses were reported, there were eight studies (n=441, of which 225 patients (51.0 percent) were diagnosed with cancer).

Nine studies reported the sensitivity of mammography, ranging from 71 to 100 percent, with specificities of 40 to 94.8 percent (Evidence Table 6). Five studies reported the sensitivity of ultrasound (67.6-100 percent), with corresponding specificities of 26 to 97.7 percent. Ranges for PPV and NPV also varied widely.

Question 2 Results: What is the management of lobular carcinoma in situ (LCIS) and atypical hyperplasia (AH)?

Within 5 years after LCIS diagnosis, 4.2-9.3 percent of patients in the database were diagnosed with breast cancer. In studies that followed patients for greater than 5 years, the incidence of cancer was 7.7-26.3 percent. Incidence of cancer in LCIS patients varied widely, depending on treatment. The lowest incidence of cancer was seen in women who underwent bilateral mastectomy (zero), closely followed by women who took tamoxifen (1.9 percent), then observation, ipsilateral mastectomy, and local excision (9.3 percent).

Within 5 years after AH diagnosis, 3.7-19.3 percent of patients were reported to develop breast cancer. In studies that followed patients for greater than 5 years after AH diagnosis, the incidence of cancer was 13.6-33.6 percent.

The evidence indicates that when SCBX yields a diagnosis of atypical ductal hyperplasia, an excisional biopsy of the lesion should be performed. Nearly 50 percent of patients with an original diagnosis of ADH had a change in diagnosis as a result of excisional biopsy. There was not enough information regarding ALH patients in the database to be able to make a similar assessment.

Although data are available from only one study, SERM therapy with tamoxifen appears to have a profound impact in decreasing the incidence of breast cancer following LCIS or AH. Enthusiasm for these results must be tempered, however, by recognition of the risks associated with SERM therapy, such as increased risk of endometrial cancer and thromboembolic disease.

The database originally contained a total of six studies addressing LCIS or ALH. Due to the paucity of data, it was decided to expand the interpretation of atypical hyperplasia to include both ADH and ALH. This resulted in a total of 20 accepted studies (n=3,501), plus 2 kinship studies (Evidence Table 2). Seventeen studies reported no industry sponsorship, one study reported industry sponsorship (Fisher, Costantino, Wickerham, et al., 1998), and two were not specific regarding sponsorship information. One study (Jackman, Burbank, Parker et al., 1997) reported that the authors had a financial interest in Biopsys Medical, but it did not specifically state that the study was industry sponsored. Dupont, Page, Parl, et al., (1999) reported that the author has been a consultant for Wyeth-Ayerst on three occasions in his career, but it did not state that the study was industry sponsored.

Nineteen studies were performed in North America, and one was performed in Europe. Twelve studies were observational, including nine retrospective (n=705) and three prospective (n=420) studies. There were eight interventional studies, consisting of seven UCS (n=357) and one RCT (n=2,019).

The number of studies described below is greater than the total number of studies for Question 2 because three studies included two populations (ALH and ADH, or LCIS and AH); these studies therefore are cited twice, although the patients are counted only once.

One study (Raju and Vertes, 1996) also was included in the database for Question 1. This study involved 20 patients, but the results for one patient were not included in the database, as this patient had a prior history of breast cancer.

Six studies contained 1,482 patients with LCIS. Five of these studies (n=1,014) reported cancer incidence after LCIS diagnosis (112 patients; 11.0 percent). These results are summarized in Evidence Table 7. The duration of followup ranged from 4 to 50 years. Within 5 years after LCIS diagnosis, 4.2-9.3 percent of the patients were diagnosed with breast cancer [k=5, n=1,014 (of which 53 were diagnosed with cancer), overall incidence = 5.2 percent]. In studies that followed patients for greater than 5 years, the incidence of cancer was 7.7-26.3 percent [k=3, n=421 (of which 77 were diagnosed with cancer), overall incidence = 18.3 percent].

Tumor location in reference to LCIS site included 54 ipsilateral tumors, 33 contralateral tumors, nine bilateral tumors, and 26 tumors in which location was not reported (See Evidence Table 8.). Regarding management of LCIS, 794 patients were managed by observation, and 31 were diagnosed with cancer (5.3 percent). Forty-nine patients underwent ipsilateral mastectomy: four were diagnosed with cancer (8.2 percent). Seven patients underwent bilateral mastectomy: none were diagnosed with cancer. Two hundred and fourteen patients underwent local excision: 17 were subsequently diagnosed with cancer (7.9 percent). In one study (Fisher, Costantino, Wickerham, et al., 1998), the only RCT in the database, 415 patients were treated with tamoxifen therapy: eight were diagnosed with cancer (1.9 percent). Four hundred and eleven patients in this study were treated with placebo, and 18 developed cancer (4.4 percent).

Sixteen studies specifically addressed AH (n=2,019). These results are summarized in Evidence Table 9. Ten studies identified patients with ADH (n=403), two identified patients with ALH (n=56), and five did not distinguish between ADH and ALH (n=1,560). One study (Marshall, Hunter, Connoly, et al., 1997) contained both ADH and ALH patients and did distinguish between the two (70 patients had ADH, 49 had ALH).

Burbank (1997) described 18 patients with ADH. Eight of these patients were described also in Jackman, Burbank, Parker, et al., (1997) and therefore were not captured from Burbank's study.

Four studies followed untreated AH patients and reported their subsequent cancer incidence (Evidence Table 7). These studies included 1,039 women with AH, 106 (10.2 percent) of whom developed cancer in the 4 to 20 years during which they were followed. Included in these numbers are 614 patients (Fisher, Costantino, Wickerham, et al., 1998) who were treated with placebo. In studies that reported the timing of cancer diagnosis, the incidence of cancer at 5 years was 6.4 percent (range 3.7-19.3 percent) and at greater than 5 years was 19.5 percent (range 13.6-33.6 percent).

Eight of the ten studies with ADH patients compared initial biopsy results with excisional biopsy results. Excisional biopsy was performed on 314 (77.9 percent) of the 403 patients who were given a diagnosis of ADH. This led to a change in diagnosis in 133 (42.4 percent) of patients, with 26 (19.5 percent) being diagnosed with cancer, and 76 (57.1 percent) receiving a diagnosis of DCIS. The remainder of changes were LCIS (four patients; 3.0 percent) or benign (27 patients; 20.3 percent). The change in diagnosis was even more pronounced when patients were stratified by biopsy type. Those who underwent SCBX (k=7, n=206) had a 56.3 percent incidence of diagnosis change, compared with 27.8 percent diagnosis change for patients who underwent vacuum-assisted biopsy (k=2, n=108).

Only one study of ALH patients (Liberman, Cody, Hill, et al., 1999) compared initial biopsy results with excisional biopsy results. Of the seven patients in the study, four underwent an excisional biopsy, leading to a change in diagnosis in just one patient (ALH was changed to LCIS).

One study (Fisher, Costantino, Wickerham, et al., 1998) examined the effect of tamoxifen therapy on patients with AH. Patients were not separated according to ALH vs. ADH. In this study, 1,193 patients with atypical hyperplasia were followed for up to 5 years. Of the 614 patients who were treated with placebo, 23 developed breast cancer (3.7 percent), compared with three of the 579 patients who were treated with tamoxifen (0.5 percent).

While long-term, confirmatory studies are necessary, the above results suggest that tamoxifen therapy is highly efficacious in decreasing the incidence of breast cancer following a diagnosis of LCIS or AH.

Question 4 Results: What are the indications for sentinel node biopsy?

Regardless of the technique of sentinel node identification (vital blue dye or radiocolloid mapping), sentinel nodes are detected in the vast majority of cases, and are positive in approximately one-third of cases. Both vital blue dye and radiocolloid mapping work well individually, but combining them results in a higher yield of sentinel node detection. False negative sentinel nodes occur in 2 to 3 percent of cases.

The limited data regarding types of tumors most amenable to this procedure suggest that tumor size, location, and history of prior breast surgery do not have major impact on the utility of sentinel node biopsy.

The decrease in morbidity associated with full axillary node dissection is encouraging; however, the risk of false negative sentinel nodes cannot be ignored. The decision regarding sentinel node biopsy vs. full ALND should be made by the patient and the clinician, after full discussion of the benefits and risks. Before SLN biopsy can be recommended as a routine procedure, long-term data are needed, to show that cancer outcome and survival are not impaired. Further attention should be paid to the impact of surgeon experience and extent of pathological investigation of the tissue.

The database contains a total of 39 studies (n=5,900), plus five kin studies, that addressed indications for sentinel node biopsy (Evidence Table 2). These studies include 26 from North America (n=4,013) and 13 from Europe (n=1,887). None of the studies reported industry sponsorship. Thirty-six studies were UCSs (n=5,518), two were retrospective observational (n=167), and one was an RCT (n=215). All studies received a Level of Evidence of III.

To evaluate indications for SLN biopsy, data regarding tumor size and location were captured, in addition to information regarding patients' prior history of breast surgery (Evidence Tables 10 and 11). Baseline data regarding these characteristics were frequently available, but information regarding which patients had sentinel nodes identified was not. The majority of studies did not report the impact of tumor size, location, or prior breast surgery on success rate in identifying SLN. In studies that did report this information, the success rate was over 90 percent for almost all categories. In general, smaller tumors were associated with higher success rate, and tumors in the upper outer quadrant showed a better success rate than those in the upper inner quadrant.

In most studies, there was no significant difference between success rates for patients with prior breast surgery vs. no prior surgery. One study (Feldman, Krag, McNally, et al., 1999) reported that 4 of 21 patients with positive axillary nodes had false-negative sentinel nodes. All four of these patients had prior large excisional biopsies. While the overall sensitivity of sentinel node biopsy was 81 percent in this study, it was only 60 percent for patients with prior excisional biopsies.

Full axillary lymph node dissection (ALND) was done on all patients in 27 studies (n=3,182) and in approximately 30 percent of patients in the remaining 12 studies. In 2 of these 12 studies, the number of patients who received a full ALND was not reported. Both vital blue dye and radiocolloid mapping were used to identify the sentinel lymph nodes (SLN) in the majority of studies (k=20, n=3,866), vital blue dye was used alone in seven studies (n=506), and radiocolloid mapping was used alone in 12 studies (n=1,524). The sum of these numbers does not equal the total number of patients in all of the studies because not all patients in the combination studies ended up receiving both dyes.

Most studies reported the number of patients in whom the sentinel node was detected, the number of sentinel nodes that were positive for cancer, the number of positive axillary nodes, and the number of false negative (FN) sentinel nodes. In the studies in which ALND was not performed on all patients, it was not always possible to distinguish which patients did receive a full ALND. Therefore, the results presented in the following summary are from only the studies in which full ALND was performed on all patients.

From the 27 studies in which all patients underwent ALND, at least one sentinel node was detected in 2,909 of the 3,182 patients studied (91.4 percent). Sentinel nodes were positive for metastatic disease in 1,089 patients (37.4 percent). Axillary nodes were positive for metastatic disease in 1,184 patients. A total of 84 FN sentinel nodes was reported, for a false negative rate of 2.9 percent. Adding the number of FN sentinel nodes to the number of positive sentinel nodes does not yield the number of positive axillary nodes because some of the positive axillary nodes were in patients in whom sentinel nodes were not detected.

Most studies reported results of SLN biopsy in patients with carcinomas only, but two studies included patients with DCIS also. Bass, Duaway, Mahatme, et al., (1999) included 150 patients with DCIS, of which 11 had positive SLNs. Cox, Pendas, Cox, et al., (1998) included 87 patients with DCIS, of which four had positive SLNs. Combining these data elements, 15 of 237 (6.3 percent) patients with DCIS had positive SLN biopsies. This brings into question the accuracy of the DCIS diagnosis.

The percentage of FN procedures varied not only by biopsy method, but also by calculation technique. Roumen, Valkenburg, and Geuskens, (1997) argued that the number of FN biopsies should be compared with the number of true positive ALNDs, rather than comparing the false negatives to the full number of patients studied. This does not take into account the number of true negatives. Another method of calculation would be dividing the false negatives by the total negatives. Both of these methods of calculation would result in higher false negative rates.

Many studies reported statistical evaluation of SLN biopsy (Evidence Table 12). Sensitivity was reported in 17 studies and ranged from 81 to 100 percent. Accuracy was reported in 18 studies and ranged from 94 to 100 percent. NPV was reported in 12 studies and ranged from 93 to 100 percent. As pointed out by Roumen, Valkenburg, and Geuskens, (1997), specificity and PPV must equal 100 percent because there can be no false-positive results. If a sentinel node is positive, even if the rest of the axillary nodes are negative, the axillary node status is still positive due to the sentinel node. Thus, the only cause for false-positive sentinel nodes would be inadequate dissection or erroneous interpretation by the pathologist. The database contains sufficient data to calculate weighted means of sensitivities for different methods of sentinel node identification. Five studies reported sensitivity of radiocolloid mapping; the weighted mean was 89.7 percent, with a range of 81.0 to 93.3 percent. Three studies reported sensitivity of vital blue dye; weighted mean was 91.2 percent, with a range of 83.3 to 95.0 percent. Nine studies reported sensitivity of the combination of radiocolloid mapping plus vital blue dye; weighted mean was 95.2 percent, with a range of 85 to 100 percent. In summary, both radiocolloid mapping and vital blue dye are highly sensitive techniques for identifying sentinel nodes, and the combination of the two methods is slightly more sensitive than either method alone.

Ideally, comparisons of sensitivities of sentinel node biopsy between patients with different tumor characteristics could be calculated; however, the database is lacking sufficient information. Additional useful information would be comparison of success rates in sentinel node biopsy based on amount of experience by the surgeon and yield of biopsy results based on extent of pathological exploration.

Two recent studies which were published after this database was collected provide further evidence in support of sentinel node biopsy (Giuliano, Haigh, Brennan, et al., 2000; McMasters, Tuttle, Carlson, et al., 2000). In the two studies, 939 patients underwent SLN biopsy followed by full ALND. Sentinel nodes were successfully identified in 841 of the 939 patients (89.6 percent). The false-negative rate is consistent with that reported in this database. Long-term, multicenter trials currently are underway to evaluate the impact of SLN biopsy on cancer outcomes and survival (Giuliano, Haigh, Brennan, et al., 2000). If the long-term data are as promising as the short-term data appear to be, SLN biopsy may become the standard of care for nodal staging of women with breast cancer.

Question 5 Results: What are the costs associated with diagnosis and management of breast disease, as outlined above?

Given the wide variation in methods of presenting cost information, it is not possible to answer this question using this database.

Only studies that were accepted for Questions 1 through 4 with cost reported in U.S. dollars were considered for evaluation of Question 5. Studies that dealt with theoretical patients, using modeling exercises, were rejected. Following these criteria, six of the studies accepted for Questions 1 and 3, and none of the studies for Questions 2 or 4, were accepted (See Evidence Table 2). These six studies (n=2,605) were all from North America. None of the studies reported industry sponsorship. Four were observational retrospective studies (n=2,262), and two were UCSs (n=343).

Each of the studies that evaluated cost described it very differently, making comparison difficult. Costs ranged widely across different hospitals and are quoted from different years. Some studies factored in the amount that would be covered by insurance, while others did not. Costs were reported per patient or per episode, some included costs of ancillary services while others reported strictly the cost of the procedures, and others did not differentiate exactly what costs they were describing. It is difficult to summarize this information in a useful manner.

## Strengths and Limitations of the Evidence Base

The strengths of the review presented here include the clear definition of the research question, adherence to an explicit research protocol developed prior to the analysis, the comprehensive nature of the data search (employing both computer databases and manual bibliography searches, resulting in the inclusion of all relevant published materials), consensus between two reviewers of all data elements prior to entry into the database, and a quality control review of every element of this report.

Another primary strength of this evidence base derives from the collaboration of multidisciplinary researchers who participated in its development. It was compiled by investigators who are skilled in employing highly systematic and unbiased methods to collect, review and synthesize data from published clinical literature. Throughout the course of this project, there was frequent input from the coinvestigator and the TEP. In addition, the final draft was evaluated by a panel of peer reviewers.

The major limitations of this review are those related to weaknesses of the available published literature on the management of breast disease specifically linking risk factors, symptoms, and cancer incidence. The database enabled researchers to develop partial answers for Questions 2 and 4 (LCIS, AH, and sentinel node biopsy), however the answers for Questions 1, 3, and 5 (risk factors, breast abnormalities, cost) are limited by the paucity of data.

The major difficulties associated with compiling this evidence report were due to the variations in methods of reporting data. Many studies were rejected because they reported risk factors or breast symptoms but not both. In accepted studies, it was often difficult to ascertain whether authors were referring to numbers of patients or numbers of breast lesions. Studies which did report both risk factors and symptoms often reported cancer incidence only for the entire population. While mammographic results were almost always reported, variations in reporting the results made it impossible to combine the data in a useful way. This was unexpected, given that widespread use of the BI-RADS nomenclature could have prevented this problem. Other areas in which reporting style varied greatly included biopsy methods, timing of subsequent cancer diagnoses, other followup information, types of atypical hyperplasia, and information regarding patients who underwent sentinel node biopsy.