# Methodology

MetaWorks investigators used systematic review methods derived from the evolving science of review research (Mulrow, Cook, and Davidoff, 1997; Sacks, Berrier, Reitman, et al., 1987). These methods were generally applied according to standard operating procedures at MetaWorks and are displayed in Figure 1.

Figure 1: MetaWorks systematic review process

A Task Order, containing the five questions described above, was developed by Kaiser Permanente, submitted to AHRQ, then presented to MetaWorks. From this Task Order, MetaWorks researchers developed a Work Plan, which was then reviewed by AHRQ, Kaiser Permanente, and the Technical Expert Panel (TEP). The work plan outlined the methods to be used for the literature search, study eligibility criteria, data elements for extraction, and methodological strategies to minimize bias and maximize precision during the process of data extraction and synthesis.

After a preliminary literature review, causal pathways relevant to the above five questions were developed. Questions 1 and 3 are facets of the same question; namely, what is the management of patients with risk factors for breast cancer who present with abnormal clinical or mammographic findings? They are therefore included in the same causal pathway. Questions 2 and 4 each have their own causal pathway. Question 5 does not have a pathway; data are derived from questions 1 through 4 that address cost.

These pathways were not designed to be clinical practice guidelines or algorithms for patient care decisions. They were constructed solely for use as guides during the systematic review for this project, and with the expectation that they might change as the project developed.

## Literature Search

The published literature was searched from January 1, 1994 to September 15, 1999, using Medline and Current Contents^®^ databases. A manual search was performed of the bibliographies of all publications accepted for inclusion into the evidence base. In addition, the bibliographies of selected review articles published in 1999 were searched for potentially relevant citations. The search cut-off date was September 15, 1999, and the retrieval cut-off date was March 15, 2000. The Medline search included the following search strategy, back to 1994:

For Question 1 (management of symptomatic breast disease and suspicious findings):

- explode Medical Subject Heading (MeSH) "breast neoplasms"
- AND Topic Subheading (TS) "diagnosis"
- AND NOT foreign language

For Question 2 (management of LCIS and AH):

- explode MeSH "breast neoplasms" AND TS "diagnosis" OR TS "pathology"
- AND explode MeSH "carcinoma in situ" OR
- explode MeSH "carcinoma, infiltrating duct" OR
- explode MeSH "carcinoma, intraductal, noninfiltrating" OR
- explode MeSH "carcinoma, lobular" OR
- explode MeSH "hyperplasia"
- AND NOT foreign language

For Question 3 (management of nonpalpable lesions and calcifications):

- explode MeSH "breast neoplasm" AND (TS "diagnosis" OR TS "pathology" OR TS "radiology") AND explode MeSH "mammography"
- OR Textword (TW) "nonpalpable" OR TW "calcifications" OR TW "microcalcifications"
- AND NOT foreign language

For Question 4 (indications for sentinel node biopsy):

- explode MeSH "lymph nodes" AND TS "pathology"
- AND explode MeSH "breast neoplasm" AND TS "pathology"
- AND NOT foreign language

For Question 5 (costs):

- explode MeSH "breast neoplasms"
- AND explode MeSH "costs and cost analysis"
- OR MeSH "breast neoplasms" AND TS "economic"
- AND NOT foreign language

The search of the Current Contents^®^ CD-ROM database employed the following key word (KW) search terms:

- Keyword (KW) breast cancer
- AND KW diagnosis
- LIMIT to English language
- LIMIT to articles
- LIMIT to Current Contents^®^ clinical medicine

All citations and abstracts resulting from the above searches in Medline and Current Contents^®^ were downloaded and printed at MetaWorks.

To assist with the development of the evidence base, pertinent articles from the following Internet sites were reviewed: The Cochrane Collaboration (http://www.cochrane.org), National Guidelines Clearinghouse (NGC; http://www.guideline.gov), Medscape (http://www.medscape.com), Oncolink (http://www.oncolink.com), CancerNet (http://cancernet.nci.nih.gov), the American College of Obstetricians and Gynecologists (ACOG; http://www.acog.org) and the American Society of Clinical Oncology (ASCO; http://www.asco.org).

### Exclusion Criteria

During Level I screening, all abstracts were downloaded, reviewed and evaluated for the following exclusion criteria:

- Reviews, meta-analyses, letters, case reports, editorials, and commentaries.
- Abstracts.
- Pharmacokinetic and pharmacodynamic studies.
- Animal or in vitro studies.
- Studies written in languages other than English.

### Inclusion Criteria

Full articles were retrieved for all abstracts passing Level I screening. The articles then underwent Level II screening, which consisted of evaluating the articles for the following inclusion criteria:

- Study designs: observational (prospective, retrospective, and cross sectional), or interventional [randomized controlled trials (RCTs), non-randomized controlled trials (non-RCTs), and uncontrolled case series (UCS)].
- Adult female patients undergoing diagnosis or management of breast disease.
- Studies addressing:
- any diagnostic test to establish or support a diagnosis of breast disease in a woman presenting with a breast lump, nipple discharge, thickening, or specific findings on biopsy or mammography OR
- any intervention used in the management of breast disease in women presenting with a breast lump, nipple discharge, thickening, or specific findings on biopsy or mammography OR
- specific management of LCIS, AH, non-palpable lesions and calcifications OR
- sentinel node biopsy OR
- Costs associated with diagnosis and/or management of breast disease.
- At least 10 patients as total sample size.
- Studies where results for one patient population of interest can be separated from results from other populations.

Due to the complexity of the questions and the broad scope of the Level II accepted studies, an additional topic assessment and refinement was prepared in which the causal pathways were used to further refine the inclusion criteria. Level III screening sheets were developed, and studies that had been accepted at Levels I and II underwent Level III screening.

For questions 1 and 3, the inclusion criteria included the reporting of:

- Risk factors (age, menopausal status, pregnancy history, HRT use, or family history) AND
- Description of suspicious findings (palpable lesions, nipple discharge, or mammographic findings) AND
- Diagnosis of cancer made at the time of presentation and/or subsequently.

For question 2, the level III inclusion criteria included the reporting of:

- Diagnosis of LCIS and/or AH AND
- Management options (observation), MRI, SERM therapy, bilateral mastectomy) AND
- Diagnosis of cancer made at the time of presentation and/or subsequently.

For question 4, the level III inclusion criteria included the reporting of:

- Indication for sentinel node biopsy (tumor size, tumor location, absence of palpable axillary nodes, no history of breast surgery) AND
- Method of sentinel node identification (vital blue dye, radiocolloid mapping, both) AND
- Results of biopsy and comparison with gold standard (axillary node dissection).

For question 5, any study that had been accepted for one of the previous questions in which costs were reported in U.S. dollars was accepted.

Studies that consisted entirely of screening populations were rejected, because the questions for this review were focused on patients with clinical or mammographic abnormalities, in addition to risk factors. Populations of interest would not be represented in screening studies, which, by definition, consist of asymptomatic patients. These studies were excluded only when the cohort of patients with abnormal mammograms could not be identified. Studies that included follow-up information regarding asymptomatic patients with abnormalities found on mammography were, therefore, accepted.

For Questions 1 and 3, studies that consisted entirely of cancer populations were rejected, because the questions for this review aimed to determine the incidence of cancer in patients with specific findings, not to determine the prevalence of specific findings in cancer patients.

For Question 2, studies of patients who had cancer concurrently with LCIS or AH were rejected, as it would be impossible to determine whether these patients' outcomes were related to their cancer or their LCIS/AH.

Rejection of studies with cancer populations obviously did not apply to Question 4, as sentinel node biopsy would be done only in patients with a diagnosis of cancer.

## Linked Studies

After the accepted studies were determined, kinship studies were identified. These were studies in which the same patient population was reported in more than one study. "Parent" studies were assigned, which contained primary data. "Child" studies contained supplemental information, such as follow-up data or additional analyses. Data elements were extracted from the parent studies, and supplemented by information presented in kin studies, when appropriate.

## Rating the Evidence

All eligible studies were rated for both quality and level of evidence at the time of data extraction. Two established methods: 1) the Jadad method, and 2) the Level of Evidence method were used.

## Data Extraction

Key data from each eligible study were extracted by a researcher recording data from original reports onto a data extraction form (DEF), and reviewed by a second researcher checking all DEF fields against the original report. Differences were resolved prior to data entry. In all cases, at least one physician reviewed each study. DEFs were designed in advance and pilot tested on a small sample of eligible studies. The pilot test allowed for necessary edits to the DEF to be made prior to implementation on all studies. Dual review of all data served to reduce error and bias in the data extraction process. The data were then entered into MetaWorks' relational database of clinical studies, MetaHub^TM^. Key data elements sought for extraction from each study included:

- Citation
- Publication date
- Accrual year(s)
- Study duration
- Study design
- Industry sponsorship (sponsor name or not reported)
- Level of evidence
- Quality score
- Total number of patients analyzed
- Geographic location
- Questions addressed
- Quality of life
- Primary objective of study
- Mention of cost

Beyond these data elements, the data extraction forms differed for each question. For Questions 1 and 3, the following elements were captured:

- Method of detection (clinical, mammographic, or both)
- Method of biopsy
- Risk factors:
- Age
- Menopausal status
- Family history
- Pregnancy history
- Use of hormone replacement therapy
- Clinical findings:
  - Patient-detected
  - Clinician-detected
  - Palpable mass or thickening
  - Nipple discharge
  - Pain
  - Other
- Mammographic results:
  - Calcifications
  - Masses
  - Parenchymal distortion
  - Densities
  - BI-RADS categories
  - MRI results
  - Ultrasound results
  - Scintigraphy results
  - Biopsy results

For each of these categories, the number of patients who presented with the symptom and the number who were diagnosed with cancer were both captured. Odds ratios, relative risks, sensitivity, specificity, and accuracy were also captured, when reported.

For Question 2, the following elements were captured:

- LCIS or AH (ADH or ALH)
- Method of biopsy
  - Comparison of initial biopsy results with excisional biopsy results
- Management
  - Observation
  - Yearly mammogram
  - MRI
  - SERM therapy
  - Radiation
  - Local excision
  - Bilateral mastectomy
  - Ipsilateral mastectomy
  - Ipsilateral mastectomy with contralateral biopsy
  - Chemotherapy

For each category, captured elements included the number of patients with LCIS or AH and the number who subsequently developed cancer. Risk factors and time of cancer diagnosis after LCIS/AH diagnosis were also captured when reported.

For Question 4 (indications for sentinel node biopsy), the following data elements were captured:

- Method of sentinel node detection
  - Vital blue dye
  - Radiocolloid mapping
  - Both
- Number of patients who had axillary node dissection
- Criteria for sentinel node biopsy
  - Tumor size
  - Metastases
  - History of breast surgery
  - Tumor location
- Number of patients in whom sentinel node detection was attempted
- Number of patients in whom sentinel node was detected
- Number of patients with sentinel node(s) positive for metastatic disease
- Number of patients with axillary node(s) positive for metastatic disease
- Sentinel node biopsy statistics
  - Accuracy
  - Sensitivity
  - Specificity
  - Positive predictive value (PPV)
  - Negative predictive value (NPV)

Lymphoscintigraphy (LSG) has been used to define unanticipated patterns of lymphatic drainage in melanoma patients, but has not been helpful in breast cancer patients (Linehan, Hill, Tran, et al., 1999). Information regarding LSG was, therefore, not extracted from papers that were accepted for this report.

For Question 5, information was infrequently available. It was, therefore, not captured on DEFs. The intention was to summarize data for question 5 in this report.

Only clearly reported aggregate results were extracted from studies. Results that would require extrapolations from graphs or derivations from figures were not captured, due to the potential inaccuracy of reading precise results from graphs or diagrams.

## Database Development

Data were entered from the DEFs into MetaHub, MetaWorks' relational database of clinical trials. At the time each DEF was entered, 100 percent of the data elements were checked back against the originals. In addition, a 20 percent random sample of data in the completed database was checked against the DEFs by the quality control (QC) group. Error rates in excess of 2 percent of QC-checked data would have triggered a 100 percent recheck of all data elements entered into the database. However, the 100 percent recheck was not necessary in this case, due to a low error rate.

## Statistical Methods

No statistical analyses were planned beyond basic descriptive statistics used to summarize data. When studies reported summary statistics, they were captured and reported in this summary. Recommendations for supplemental analyses are provided.

## Role of Consultants

Six people made up the TEP, including two medical oncologists, one surgical oncologist, one internist, one radiologist, and one consumer representative. They all received copies of the work plan and its revisions, causal pathways, topic refinements, study listings, data listings, and draft report. When TEP members provided feedback, MetaWorks investigators reviewed their comments, and applied them as deemed appropriate. Additionally, during the course of the project, monthly conference calls were instituted with the topic nominator (Kaiser Permanente), the AHRQ Task Order Officer (TOO), and the coinvestigator from Leonard Davis Institute (LDI). During these conference calls, project updates were provided and issues of concern were addressed.

## Peer Review

A group of 11 peer reviewers was assembled to review a draft version of this report. The panel was composed of medical, surgical, and radiation oncologists, a family practitioner, a gynecologist, a pathologist, and a breast cancer patient. All reviewers were asked to complete a list of questions about the format and content of the report and were also invited to provide additional comments in writing. Responses were received from 10 of the 11 peer reviewers and 4 of the 6 TEP members. All of these responses were reviewed and, where appropriate, incorporated into the final report.