# Introduction

## Background

Breast cancer is the most common cancer found in women worldwide (Ford, Marcus, and Lum, 1999). Each year, over 170,000 women are diagnosed with breast cancer in the United States alone (Armstrong, Eisen, and Weber, 2000). The average lifetime risk of breast cancer in a female baby born in the United States in the year 2000 is 12 percent, or one in eight. The most common cause of malpractice litigation is the missed or delayed diagnosis of breast cancer (Schootman, Myers-Geadelmann, and Fuortes, 2000). Clearly, breast disease places a major burden on both individual and societal healthcare resources.

When a woman presents to her health care provider with a breast symptom, the initial management will nearly always include, at a minimum, a clinical breast exam (CBE) and mammogram or ultrasound, depending on the age of the patient. Controversies abound concerning the steps after the initial imaging study. It is unclear whether further management should be influenced by patients' risk factors for breast cancer. Further areas of controversy include management of abnormal mammograms, management of certain pathological diagnoses, and whether all women with breast cancer require a full axillary lymph node dissection (ALND).

These are but a few of the numerous unanswered questions regarding the diagnosis and management of breast disease. The purpose of this report is to present the published evidence regarding these issues. In order to harness the highest quality evidence supporting the management of breast disease, MetaWorks has performed a systematic review of the recent literature, consisting of articles published in English from January 1, 1994 to September 15, 1999.

This review of management of breast disease was nominated by Kaiser Permanente, Northern California, and a Task Order was commissioned by the Agency for Healthcare Research and Quality (AHRQ). Evaluation of screening asymptomatic patients, development of clinical practice guidelines or specific clinical recommendations are beyond the scope of this project. This evidence base should, however, be useful to health care providers in developing evidence-based strategies to guide breast disease management. It will be useful also to those planning new clinical trials and making regulatory decisions. Additionally, this evidence base may readily be updated as the literature evolves.

The following questions were posed by AHRQ in this Task Order. An introductory review of the issues underlying each set of questions is provided as a prelude to a presentation of the methods and results of this systematic review.

Questions 1 and 3: What are the recommendations for evaluation of breast symptoms, mammographic findings and other suspicious findings based on menstrual status, hormone replacement therapy (HRT), pregnancy, age, and family history? What is the management of nonpalpable lesions and calcifications?

## Risk Factors

The focus of these questions was to assess the impact of risk factors upon evaluation of women with breast symptoms or abnormal mammograms. It is well established that certain factors increase a woman's risk of developing breast cancer (Velentgas and Daling, 1994). These include age > 50 [relative risk (RR) 6.5], postmenopausal status, use of HRT (RR 1.0-1.5), nulliparity or late age at first pregnancy (age > 30, RR 1.3-2.2), and family history of breast cancer (first degree relative, RR 1.4-13.6; second degree relative, RR 1.5-1.8) (Armstrong, Eisen, and Weber, 2000). Management decisions cannot be based solely on risk factors, as from 50 to 90 percent of women with breast cancer have no identifiable risk factors for the disease (Askins, 1999; Bruzzi, Green, Byar, et al., 1985; Madigan, Ziegler, Benichous, et al., 1995). The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer states that when a woman presents with a breast lump or suspicious change in breast texture, her risk factors should be noted, but presence or absence of risk factors should not influence decisions regarding further workup (Margolese, Cantin, and Bouchard, 1998).

### Age

The frequently quoted figure of "one in eight" or a 12 percent risk of an individual woman developing breast cancer is a lifetime estimate and assumes the woman will live to age 85 (Ford, Marcus, and Lum, 1999). Age is second only to history of breast cancer as the most important risk factor for development of breast cancer in women in the United States (Overmoyer, 1999). While debate continues concerning the optimal age at which to begin screening mammography, the steady increase of breast cancer incidence with age has led most American professional societies to recommend continuing yearly mammographic screening for as long as a woman remains healthy. (Ford, Marcus, and Lum, 1999; Basset, Hendrick, Bassford, et al., 1994).

### Family History

Family history is a known risk factor for breast cancer. The degree of risk, however, varies depending upon the age of the patient, the closeness of the relative(s) with breast cancer, the age(s) at which the relative(s) developed breast cancer, the number of relatives with breast cancer, and the number of relatives with other gynecologic or nongynecologic cancers. In the Nurses' Health Study (Colditz, Willett, Hunter, et al., 1993), women whose mother and/or sister had breast cancer before the age of 40 were reported to have the highest risk of developing breast cancer [RR 2.5, 95 percent confidence interval (CI) 1.5-4.2], compared with women with a negative family history. Evaluation of women in the Iowa Women's Health Study (Sellers, Mink, Cerhan, et al., 1997) showed that use of HRT did not significantly impact the risk of breast cancer in women with a positive family history.

### Pregnancy History

The effect of pregnancy on the incidence of breast cancer appears to be influenced by the age at first pregnancy, age at menarche, and age at menopause. Risk of breast cancer increases with duration of estrogen exposure (Ford, Marcus, and Lum, 1999); therefore, women with longer periods of uninterrupted estrogen exposure are at higher risk for developing cancer. This includes women with early menarche (before age 12; RR 1.1-1.3) or late menopause (after age 55; RR 2.0). Nulliparous women and women who deliver their first child after the age of 30 also have increased risk of subsequent breast cancer (RR 1.3-1.9). The impact of pregnancy is not completely understood, as the short-term risk of breast cancer rises for up to 10 years after delivery (Ford, Marcus, and Lum, 1999; Lambe, Hsieh, Trichopoulos, et al., 1994).

### Hormone Replacement Therapy

Until recently, the perceived benefits of HRT for most women [decreased risks of osteoporosis (Felson, Zhang, Hannan, et al., 1993), coronary heart disease (Falkeborn, Persson, Adami, et al., 1992; Grady, Rubin, Petitti, et al., 1992; Hong, Romm, Reagan, et al., 1992; Psaty, Heckbert, Atkins, et al., 1994), stroke (Finucane, Madans, Bush, et al., 1993), menopausal symptoms (Hammond, 1996), and hyperlipidemia (Writing Group for the PEPI Trial. 1995)] were believed to outweigh the risks [increased risks of endometrial and breast cancer (Colditz, Hankinson, Hunter, et al., 1995; Grady, Rubin, Petitti, et al., 1992)]. Deciding whether to take HRT was particularly difficult for women with a significant risk of breast cancer, especially if they were also at increased risk for osteoporosis or heart disease. Recent studies, including the Heart and Estrogen/Progestin Replacement Study (HERS) (Hulley, Grady, Bush, et al., 1998) and the Estrogen Replacement and Atherosclerosis (ERA) study (Herrington, 2000; Interventional Cardiology, 2000) have shown an increase in short-term cardiovascular risk for postmenopausal women with preexisting cardiovascular disease who take HRT. These studies have further complicated the risk/benefit profile of HRT and will likely decrease the number of women taking HRT, at least until further studies are done. Current vs. previous use of HRT, unopposed estrogen vs. combination estrogen and progesterone (Stanford, Weiss, Voigt, et al., 1995; Speroff, 1996), and duration of HRT are factors that need to be considered in assessing a woman's risk of developing breast cancer (Schairer, Lubin, Troisi, et al., 2000; Gapstur, Morrow, and Sellers, 1999). The degree to which HRT increases the risk of breast cancer remains controversial.

There are numerous other potential risk factors for breast cancer, such as smoking, diet, alcohol, age of menarche, lactation, and genetic factors. Recent studies have shown that HER-2/neu gene overexpression in benign breast disease is associated with an increased risk of subsequent breast cancer (Stark, Hulka, Joens, et al., 2000). These areas were not listed in the questions posed by AHRQ; therefore, they were not covered in this report. They could, however, be included in an update of this systematic review.

## Risk Models

Several models predict an individual woman's risk of breast cancer, the two most common being the Gail model (Gail, Brinton, Byar, et al., 1989), and the Claus model (Claus, Risch, and Thompson, 1994). The Gail model was derived from data from the 280,000 women in the Breast Cancer Detection Demonstration Project (BCDDP). This model uses multivariate logistic regression to combine several risk factors and provide an individualized estimate of relative risk. The risk factors assessed include age, reproductive history, maternal family history, and history of benign breast disease. The Gail model has been validated in a prospective, randomized clinical trial (Costantino, Gail, Pee, et al., 1999); however, opinions vary regarding the utility of this tool (Daly, Lerman, Ross, et al., 1996; Ford, Marcus, and Lum, 1999). It may overestimate the risk associated with benign breast biopsies and underestimate paternal familial risk. Its applicability for minority populations is unconfirmed (Morrow, 2000). A revised model calculates incidence rates for African American and Caucasian women separately but does not allow calculation of risk for other ethnic groups, such as Asian or Hispanic women.

The Claus model, on the contrary, calculates risk based solely on family history. These tools do not provide a complete picture of an individual patient's risk of developing breast cancer. They are used mainly by genetic counselors, to educate their patients (Ford, Marcus, and Lum, 1999). These models, however, do not integrate risk factors with breast symptoms.

The triple test (TT) is a risk model that incorporates breast signs and clinical findings (Vetto, Pommier, Schmidt, et al., 1996). It consists of physical examination, mammography, and fine needle aspiration. A modified triple test (MTT) was developed for younger women, in which ultrasound was substituted for mammogram. When all three elements of the test are concordant (all indicating benign or all indicating malignant), the TT has been shown to have high sensitivity. While the TT and MTT may be useful clinical tools, one limitation is that they do not take risk factors into account.

## Mammographic Findings

As the number of women having screening mammography and the sensitivity of mammography have increased, more breast cancers are now detected by screening mammography. Cancers detected by mammographic screening tend to be found at an earlier stage, when they are not yet palpable and are assumed to be more easily curable (Sickles, 2000). However, the limited specificity of mammography leads to false positive mammograms and unnecessary biopsies. As the technology for breast cancer detection continues to improve, it is hoped that this trend toward earlier detection will continue and that specificity will improve.

When a patient presents with a breast abnormality, she will usually have a mammogram as soon as possible; not only to evaluate the area in question, but to look also for synchronous lesions elsewhere in the breasts (Bassett, Hendrick, Bassford, et al., 1994). Mammograms are less sensitive in women under the age of 40, due to the likelihood of denser breast tissue. If a woman under the age of 40 presents with a breast abnormality, depending on her exam and risk factor analysis, the type of imaging performed may be a modality other than mammography, such as ultrasound (Vetto, Pommier, Schmidt et al., 1996).

Radiologists report mammogram results in a variety of ways. The Breast Imaging Reporting and Data System (BI-RADS) terminology was developed for the purpose of standardizing mammogram reports (Liberman, Abramson, Squires, et al., 1998; see Appendix A). However, many studies report mammographic findings in more descriptive terms, such as calcifications, masses, parenchymal distortions, and densities. The degree of suspicion the radiologist reads in the mammographic lesion will highly influence further evaluation of the patient. Recommendations may range from immediate biopsy to conservative management and repeat mammogram at a specified time. One cannot rely solely on the mammogram results, however, as up to 10 to 15 percent of patients with breast cancer will have no visible abnormality on mammogram (Lumachi, Marzola, Zucchetta, et al., 1999). Other imaging modalities, such as digital mammography and magnetic resonance imaging (MRI), have increased the sensitivity of breast imaging. Their role in evaluating breast abnormalities is currently an area of intense interest for researchers (Simonetti, Cossu, Montanaro, et al., 1998).

In summary, our objective was to integrate risk factors with symptoms and/or mammographic findings to inform management decisions.

Question 2: What is the management of lobular carcinoma in situ and atypical hyperplasia?

### Lobular Carcinoma in Situ

The incidence of lobular carcinoma in situ (LCIS) is difficult to estimate, because it is generally an incidental finding and is therefore likely to be underdiagnosed (Zurrida, Bartoli, Galimberti, et al., 1996). Increasing use of core needle biopsy has lead to increased frequency of this diagnosis (Gabriel, 1999). The incidence of LCIS in biopsies that are otherwise benign is estimated at 0.5 to 3.8 percent (Lishman and Lakhani, 1999).

Consensus for management of LCIS has changed dramatically over the years. First described in 1941, LCIS was felt to be a premalignant lesion that would progress to invasive lobular carcinoma. Ipsilateral mastectomy was recommended for all patients (Foote and Stewart, 1941; Gump, Dinne, and Schwartz, 1998).

After patients with LCIS were followed for up to 25 years, it became apparent that most women with LCIS did not develop invasive cancer. Patients who did develop cancer did not necessarily develop it at the same site or even in the same breast as the LCIS. The estimated relative risk of LCIS patients (compared with patients without LCIS) developing cancer ranges from 5.9 to 12.0 (Bodian, Perzin, and Lattes, 1996). Most authorities now consider LCIS to be a proliferative disorder that identifies women at risk of developing invasive carcinoma but not a malignant or premalignant process in its own right (Bodian, Perzin, and Lattes, 1996). Some authors favor the term lobular neoplasia, rather than LCIS, to emphasize the fact that progression to malignancy is not inevitable (Carson, Sanchez-Forgach, and Stomper, 1994).

Current strategies for management of LCIS include observation, selective estrogen receptor modulator (SERM) therapy, radiation, ipsilateral mastectomy with contralateral biopsy, or bilateral mastectomy (Gump, Dinne, and Schwartz, 1998). Radiation and ipsilateral mastectomy are not generally recommended for management of LCIS, but in a survey sent to oncologists in 1996, 60 of the 541 respondents reported recommending radiation to their patients, and 180 discussed unilateral mastectomy (Gump, Dinne, and Schwartz, 1998). Given the wide range of potential treatments, it is essential to amass data to enable clinicians to make treatment recommendations based on evidence.

Ductal carcinoma in situ (DCIS), on the contrary, is considered to be a preinvasive lesion and is generally treated with local excision, often followed by breast irradiation (Ernster, Barclay, and Kerlikowske, 2000; White, Levine, Gustafson et al., 1995). Management of DCIS is not a focus of this report.

### Atypical Hyperplasia

Atypical hyperplasia (AH) is reported in 3-4 percent of biopsies performed by stereotactic core biopsy (Symmans, Weg, Gross, et al., 1999). Lesions containing AH are often histologically heterogeneous; therefore, sampling error may cause failure to diagnose cancer. Surgical biopsy allows histologic assessment of a larger volume of tissue, thus leading to more cancer diagnoses (Liberman, Cohen, Dershaw, et al., 1995). The prevalence of carcinoma at surgical biopsy after diagnosis of AH at stereotactic core biopsy (SCBX) is estimated at 33-87 percent (Brown, Wall, Christensen, et al., 1998). Due to the high incidence of coexistent carcinoma, it is recommended that excisional biopsy be done after SCBX diagnoses of atypical ductal hyperplasia (ADH) (Bassett, Winchester, Caplan, et al., 1997).

AH is considered to be a risk factor for breast cancer due to its association with increased risk of subsequent cancer in either breast (Moore, Hargett, Hanks, et al., 1997). The overall incidence of breast cancer after a biopsy of AH ranges from 5.1 to 9.8 percent (Fowble, Hanlon, Patchefsky, et al., 1998). Some studies distinguish between ADH and atypical lobular hyperplasia (ALH). When these two entities are considered separately, the RR in AH patients, compared with patients without AH, is reported as 4.7 for ADH and 5.8 for ALH (Fowble, Hanlon, Patchefsky, et al., 1998; Sparano and Mocharnuk, 1999).

Question 4: What are the indications for sentinel node biopsy?

### Sentinel Node Biopsy

After the diagnosis of breast cancer has been made, there remain many unanswered questions regarding subsequent evaluation and treatment. The status of regional lymph nodes is the most important prognostic factor for recurrence and survival of a patient with breast cancer (Albertini, Lyman, Cox, et al., 1996; Giuliano, Haigh, Brennan, et al., 2000; Veronesi, Paganelli, Galimberti, et al., 1997). Complete axillary lymph node dissection (ALND) is the gold standard for precise staging and prognostication for women with breast cancer (Cody, 1999), and the results are used to guide treatment decisions (Liberman, Sama, Susnik, et al., 1999). ALND is an invasive procedure, however, with significant potential for morbidity, including lymphedema and permanent numbness (Edge and Hurd, 1999). Chronic lymphedema occurs in 6 to 37 percent of patients after ALND (Giuliano, Haigh, Brennan, et al., 2000; McMasters, Tuttle, Carlson, et al., 2000). Chronic lymphedema has not been reported after sentinel lymph node dissection alone (Giuliano, Haigh, Brennan, et al., 2000). If ALND could be avoided in patients who have a low pretest probability of metastatic disease, significant physical, psychological, and monetary savings could result.

The sentinel lymph node (SLN) hypothesis is that the sentinel nodes are the first to drain solid tumors, and that the histologic status of the sentinel nodes is predictive of the status of the regional nodes (Liberman, Cody, Hill, et al., 1999). Sentinel node biopsy was first performed in 1977 to identify the first lymph node draining penile carcinoma (Cabanas, 1977), thereby avoiding deep inguinal node dissection. The procedure was subsequently used successfully to identify sentinel lymph nodes in cutaneous melanoma. It was first performed in breast cancer in 1993. The major unresolved issues concern whether SLN represents a safe alternative to axillary node dissection, how to identify optimal candidates for sentinel node biopsy, and which technique should be used.

It has been generally accepted that the best candidates for SLN biopsy are patients with small, solitary primary tumors (stages T1 or T2, see Appendix B), and clinically negative lymph nodes (Cody, 1999). Prior breast surgery may distort the architecture of the breast, decreasing the sensitivity of the procedure. Presence of a large hematoma or seroma similarly impedes SLN detection (Miner, Shriver, Jaques, et al., 1999). Tumor location is also a factor, because inner quadrant tumors may drain to the internal mammary, rather than the axillary lymph nodes. Metastases to the internal mammary nodes may not be detected by SLN biopsy, but they likewise would not be detected by ALND (Albertini, Lyman, Cox, et al., 1996; Cox, Pendas, Cox, et al., 1998).

The techniques used for sentinel node detection include vital blue dye, radiocolloid mapping, and a combination of dye plus isotope (Liberman, Cody, Hill, et al.,1999). The sensitivity and specificity of SLN dissection vary for different surgeons and improve as surgeons gain experience with the procedure (Gulec, Moffat, Carroll, et al., 1998). Current guidelines suggest that surgeons perform at least 20 to 30 SLN biopsies before they consider performing SLN biopsy without ALND (McMasters, Tuttle, Carlson, et al., 2000).

If SLN biopsy becomes standard of care, the only women who would need to undergo ALND would be those with positive sentinel nodes or unidentified sentinel nodes. Thus, the goal in reviewing the sentinel node literature is to identify which patients are optimal candidates for sentinel node biopsy.

Question 5: What are the costs associated with diagnosis and management of breast disease, as outlined above?

Cost-effectiveness analysis is not straightforward in the diagnosis and management of breast disease. The costs associated with medical consultations, surgical evaluations, mammography, other imaging modalities, and the numerous types of biopsies are widely disparate in different settings. Newer technologies, such as genetic testing, further increase costs. Long-term studies are required to determine whether these interventions are cost-effective in improving outcomes.