# Appendix B

Tumor Stages

T0 | No evidence of primary tumor
T1 | Tumor size < 2 cm
T2 | Tumor size > 2 - 5 cm
T3 | Tumor size > 5 cm
T4 | Tumor extended to chest wall or skin

From: American Cancer Society. Breast Cancer: Detection and Symptoms. http://www3.cancer.org/cancerinfo/load_cont.asp?ct=5&st=ds#stage (10 Sept. 1999). Used with permission.