# Appendix A

American College of Radiology (ACR) Breast Imaging Reporting and Data System (BI-RADS)

Category | Assessment | Description
1 | Negative | There is nothing on which to comment
2 | Benign finding | A definitely benign finding is described
3 | Probably benign finding | Very high probability of being benign; short term follow-up is recommended to establish stability.
4 | Suspicious abnormality | Not characteristic, but has a reasonable probability of being malignant; biopsy should be urged.
5 | Highly suggestive of malignancy | High probability of being cancer; appropriate action should be taken.

From: Liberman L, Abramson AF, Squires FB, et al. The breast imaging reporting and data system: Positive predictive value of mammographic features and final assessment categories. Am J Roentgenol. 1998; 171:35-40. Used with permission.