# Appendixes

Appendix A

Appendix B