# Evidence Tables

Evidence Table 1. Reporting of Patient Signs, Symptoms, and Other Characteristics Related to Lumbar Spinal Stenosis in Randomized Controlled Trials of Conservative Treatments

First Author and Year of Publication | Number of Patients in the Trial | Mean Age | Duration of Illness Prior to Treatment | Prior Surgery | Claudication | Back Pain | Leg Pain | Back and Leg Pain | Leg Weakness | Sensory Dysfunction | Relief of Pain by Flexion | Incontinence of Bowel or Bladder | Extent of Stenosis | Patients with Hip Disorder | Patients with Knee Disorder | Patients with Arthritis | Patients with Herniated Disks
Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 53 | Yes | Yes | No | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No
Eskola, Pohjolainen, Alaranta et al., 1992 | 39 | Yes | Yes | Yes | No | No | No | Yes | No | No | No | No | Yes | No | No | No | No
Cuckler, Bernini, Wiesel et al., 1985 | 37 | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 48 | Yes | Yes | No | No | Yes | No | No | No | No | No | No | No | No | No | No | No
Number of Trials Reporting | 4 | 4 | 4 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0

Evidence Table 2. Reporting of Patient Signs, Symptoms, and Other Characteristics Related to Lumbar Spinal Stenosis in Trials of Surgical Treatments

Trials Examining Surgical Patients with CentralLumbar Stenosis
First Author and Year of Publication | Number of Patients in the Trial | Mean Age | Duration of Illness Prior to Treatment | Mean Number of Vertebral Levels Involved | Prior Surgery | Claudication | Back Pain | Leg Pain | Back and Leg Pain | Leg Weakness | Sensory Dysfunction | Relief of Pain by Flexion | Incontinence of Bowel or Bladder | Extent of Stenosis | Patients with Hip Disorder | Patients with Knee Disorder | Patients with Arthritis | Patients with Herniated Disks
Randomized Controlled Trials
Grob, Humke, and Dvorak, 1995 | 45 | Yes | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | Yes
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 92 | Yes | Yes | No | Yes | No | No | No | No | No | Yes | Yes | Yes | No | No | No | No | No
Herno, Partanen, Talaslahti et al., 1999 | 80 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Hanakita, Suwa, and MIzuno, 1999 | 164 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Thomas, Rea, Pikul et al., 1997 | 38 | Yes | No | No | Yes | Yes | No | No | No | No | No | No | No | No | Yes | No | No | No
Yone, Sakou, Kawauchi et al., 1996 | 34 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Ray, 1982 | 65 | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Surin, Hedelin, and Smith, 1982 | 22 | Yes | No | No | No | Yes | No | No | No | No | Yes | No | No | Yes | No | No | No | No
Tajima, Fukazawa, and Ishio, 1980 | 27 | Yes | No | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Prospective Trials without Controls
Kleeman, Hiscoe, and Berg, 2000 | 54 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No | Yes | No
Weiner, Walker, Brower et al., 1999 | 30 | Yes | Yes | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No
diPierro, Helm, Shaffrey et al., 1996 | 35 | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 65 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | No | No | No | Yes
Matsui, Kanamori, Ishihara et al., 1997 | 27 | Yes | No | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | Yes
Airaksinen, Herno, Turunen et al., 1997 | 497 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No | Yes | Yes | Yes | Yes | No
Mullin, Rea, Irsik et al., 1996 | 72 | Yes | No | No | No | No | No | No | No | No | Yes | No | No | No | No | No | No | No
Ishac, Alhayek, Fournier et al., 1996 | 34 | Yes | No | Yes | No | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | Yes
Jonsson and Stromqvist, 1994 | 43 | Yes | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | Yes | Yes | No | No
Caputy and Luessenhop, 1992 | 100 | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | Yes | Yes | No | Yes
Dhar and Porter, 1992 | 36 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Chahal, Mundkur, Sancheti et al., 1982 | 32 | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | No | No | Yes
Rosomoff, 1981 | 50 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No
Getty, 1980 | 35 | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | No | No | No | No
Reale, Deifini, Gambacona et al., 1978 | 37 | Yes | No | No | No | No | No | No | No | Yes | Yes | No | Yes | No | No | No | No | Yes
Verbiest, 1977 | 116 | No | No | No | No | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | Yes
Case-series
Young, Veerapen, and O'Laoire, 1988 | 32 | No | No | No | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Kurihara, Tanaka, Tsumura et al., 1988 | 12 | Yes | No | No | No | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Hall, Bartleson, Onofrio et al., 1985 | 68 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | No | No | No | No | No | No
Weinstein, Scafuri, and McNeill, 1983 | 24 | No | No | Yes | No | No | No | No | Yes | No | No | No | No | No | No | No | No | No
Weir and De Leo, 1981 | 81 | Yes | No | No | No | Yes | No | No | No | No | No | No | No | Yes | No | No | No | No
Johnsson, Willner, and Pettersson, 1981 | 27 | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | No | No | No | No | Yes | No | No | No | No
Verbiest, 1979 | 11 | Yes | No | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | No | Yes | No | No | No | No
Salibi, 1976 | 20 | Yes | No | No | Yes | Yes | No | No | No | No | No | No | No | Yes | No | No | No | Yes
Number of Trials Reporting | 33 | 27 | 11 | 19 | 13 | 21 | 14 | 14 | 7 | 12 | 15 | 2 | 6 | 8 | 4 | 3 | 2 | 9
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized Controlled Trials
Lee and deBari, 1986 | 24 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 94 | Yes | Yes | No | Yes | No | No | Yes | No | No | Yes | No | No | No | No | No | No | No
Mikhael, Ciric, Tarkington et al., 1981 | 85 | Yes | Yes | No | No | Yes | No | Yes | No | Yes | Yes | Yes | Yes | No | No | No | No | Yes
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 66 | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | Yes
Baba, Uchida, Maezawa et al., 1996 | 31 | Yes | No | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Aryanpur and Ducker, 1990 | 32 | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No
Case-series
Choudhury and Taylor, 1977 | 28 | No | No | No | No | No | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | Yes
Epstein, Epstein, Rosenthal et al., 1972 | 15 | No | No | No | No | No | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Number of Trials Reporting | 8 | 6 | 3 | 3 | 2 | 2 | 4 | 6 | 0 | 5 | 6 | 1 | 2 | 0 | 0 | 0 | 0 | 2
Trials Examining Surgical Patients with Centralor Lateral Lumbar Stenosis type of stenosis unspecified or includes bothtypes of stenosis
Controlled Trials
Yone and Sakou, 1999 | 60 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Epstein, 1999 | 21 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Javid and Hadar, 1998 | 170 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Kalbarczyk, Lukes, and Seiler, 1998 | 148 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Pai and Kumar, 1996 | 55 | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
Kawauchi, Yone, and Sakou, 1996 | 36 | Yes | Yes | Yes | Yes | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Cinotti, Postacchini, and Weinstein, 1994 | 50 | Yes | Yes | No | No | Yes | No | No | No | Yes | No | Yes | No | No | No | No | No | No
Little and MacDonald, 1994 | 94 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Simpson, Silveri, Balderston et al., 1993 | 57 | Yes | No | No | No | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Jonsson and Stromqvist, 1993a | 39 | No | No | No | Yes | No | No | No | Yes | No | No | No | No | No | No | No | No | No
Nasca, 1989 | 114 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | Yes
Nather and Thomas, 1985 | 34 | Yes | No | No | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No | Yes | No | No | No | No
Paine, 1976 | 143 | No | No | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No
Shenkin and Hash, 1976 | 49 | Yes | No | No | Yes | No | Yes | Yes | Yes | No | No | No | No | Yes | No | No | No | No
Tile, McNeil, Zarins et al., 1976 | 26 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Retrospective Trials with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 34 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
Silvers, Lewis, and Asch, 1993 | 248 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No | No | Yes
Katz, Lipson, Larson et al., 1991 | 88 | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | No | No | No | Yes | No
Ganz, 1990 | 36 | Yes | No | Yes | No | Yes | No | No | No | No | No | Yes | No | No | No | No | No | Yes
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 70 | Yes | No | No | No | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | No
Guigui, Benoist, Delecourt et al., 1998 | 50 | Yes | No | Yes | No | No | No | Yes | No | Yes | No | No | No | Yes | No | No | No | Yes
Scholz, Firsching, and Lanksch, 1998 | 72 | Yes | Yes | No | No | Yes | No | No | Yes | No | Yes | No | No | No | Yes | No | Yes | No
Tsai, Yang, and Bray, 1998 | 62 | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No | No | No | No | No | Yes | No
Mackay and Wheelwright, 1998 | 50 | Yes | Yes | Yes | No | No | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | Yes
Whitecloud, Castro Jr, Brinker et al., 1998 | 35 | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | Yes
Spetzger, Bertalanffy, Reinges et al., 1997 | 29 | Yes | Yes | Yes | No | Yes | Yes | No | No | No | Yes | No | Yes | No | No | No | No | Yes
Katz, Lipson, Chang et al., 1996 | 88 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | Yes | No
Lehto and Honkanen, 1995 | 96 | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No
Stucki, Liang, Fossel et al., 1995 | 230 | Yes | No | No | No | No | No | Yes | Yes | Yes | Yes | No | No | No | No | No | No | No
Tuite, Stern, Doran et al., 1994 | 119 | Yes | No | Yes | Yes | No | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
McCullen, Bernini, Bernstein et al., 1994 | 193 | Yes | Yes | Yes | Yes | No | No | No | No | Yes | Yes | No | No | No | No | No | No | No
Simmons and Simmons, 1992 | 40 | Yes | No | No | No | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | No
Mauersberger and Nietgen, 1989 | 92 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Johnsson, Redlund-Johnell, Uden et al., 1989 | 61 | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Brodsky, Hendricks, Khalil et al., 1989 | 36 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Jalovaara, Lahde, Iikko et al., 1989 | 31 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No | Yes | No | No | No | No
Fast, Robin, and Floman, 1985 | 19 | Yes | No | No | No | Yes | Yes | Yes | No | No | No | Yes | No | No | No | No | No | No
Boccanera, Pellicioni, and Laus, 1984 | 25 | Yes | No | No | Yes | Yes | No | No | Yes | Yes | Yes | No | No | No | No | No | No | No
Hood and Weigl, 1983 | 21 | No | No | Yes | No | Yes | Yes | Yes | No | Yes | No | No | No | No | No | No | No | No
Scafuri and Weinstein, 1981 | 27 | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
Echeverria and Lockwood, 1979 | 35 | Yes | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No
Scapinelli, 1978 | 23 | No | No | No | No | Yes | Yes | Yes | No | No | Yes | No | Yes | No | No | No | No | No
Vestad and Naca, 1977 | 80 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
McKinley and Davis, 1976 | 32 | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
Teng and Papatheodorou, 1963 | 29 | No | No | Yes | No | No | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Epstein, Epstein, and Lavine, 1962 | 29 | No | No | No | No | No | No | No | No | No | No | No | Yes | No | No | No | No | No
Epstein, 1960 | 14 | No | No | No | No | No | Yes | No | No | Yes | Yes | No | Yes | No | No | No | No | No
Number of Trials Reporting | 47 | 36 | 17 | 22 | 17 | 22 | 23 | 20 | 7 | 20 | 20 | 5 | 9 | 5 | 1 | 0 | 4 | 7
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized Controlled Trials
Fischgrund, Mackay, Herkowitz et al., 1997 | 75 | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | No
Thomsen, Christensen, Eiskjaer et al., 1997 | 41 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Bridwell, Sedgewick, O'Brien et al., 1993 | 43 | Yes | No | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No
Herkowitz and Kurz, 1991 | 50 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Controlled Trials
Plotz and Benini, 1998 | 106 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Yuan, Garfin, Dickman et al., 1994 | 2684 | Yes | No | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | No | No
Satomi, Hirabayashi, Toyama et al., 1992 | 41 | Yes | Yes | No | No | Yes | Yes | Yes | No | No | No | No | Yes | Yes | No | No | No | No
Lombardi, Wiltse, Reynolds et al., 1985 | 47 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 23 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Rechtine, Sutterlin, Wood et al., 1996 | 18 | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Retrospective Trials with Consecutive Patients
Stambough, 1999 | 35 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Nishizawa and Fujimura, 1997 | 58 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Moller, Wittenberg, Nolte et al., 1992 | 37 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Marchesi, Thalgott, and Aebi, 1991 | 30 | Yes | No | No | No | Yes | No | No | No | No | No | No | No | Yes | No | No | No | No
Takahashi, Kitahara, Yamagata et al., 1990 | 39 | Yes | No | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No
Knox, Harvell, Nelson et al., 1989 | 39 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | No | No | No | No | No | Yes | No
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 49 | Yes | No | Yes | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No
McCulloch, 1998 | 21 | Yes | No | Yes | No | No | No | Yes | No | No | No | No | No | No | No | No | No | No
Epstein, 1998b | 28 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | Yes
Mochida, Toh, Suzuki et al., 1997 | 10 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Epstein, 1998a | 290 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | Yes
Grob, Humke, and Dvorak, 1996 | 18 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No
Herron and Trippi, 1989 | 24 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | No | No | No | No | No | No | No
Chang and McAfee, 1989 | 17 | Yes | No | No | No | No | Yes | No | No | No | No | No | No | No | No | No | No | No
Inoue, Watanabe, Goto et al., 1988 | 36 | Yes | No | No | No | Yes | Yes | Yes | No | No | Yes | No | No | No | No | No | No | Yes
Simmons and Capicotto, 1988 | 15 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Hanley, 1986 | 20 | Yes | No | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | No | No
Kaneda and Kazama, 1986 | 54 | Yes | No | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | Yes
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 50 | Yes | No | Yes | Yes | No | No | Yes | No | No | No | No | No | No | No | No | No | Yes
Dall and Rowe, 1985 | 26 | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No
Epstein, Epstein, Carras et al., 1983 | 60 | Yes | Yes | No | Yes | Yes | No | No | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes
Richardson and Brown, 1980 | 21 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Cauchoix, Benoist, and Chassaing, 1976 | 26 | No | No | Yes | No | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
Epstein, Epstein, Lavine et al., 1976 | 20 | No | No | No | No | Yes | Yes | No | No | No | Yes | Yes | Yes | No | No | No | No | No
Number of Trials Reporting | 34 | 31 | 4 | 21 | 11 | 14 | 12 | 11 | 2 | 5 | 5 | 1 | 3 | 5 | 1 | 1 | 2 | 6
Trials Examining Surgical Patients with LumbarStenosis and/or Degenerative Spondylolisthesis
Controlled Trials
Rompe, Eysel, Zollner et al., 1999 | 117 | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | No | No | No | No | No | No | No
Katz, Lipson, Lew et al., 1997 | 272 | Yes | Yes | Yes | Yes | No | No | No | No | Yes | Yes | No | No | No | No | No | No | No
Sato and Kikuchi, 1997 | 81 | Yes | Yes | Yes | No | Yes | No | No | No | No | No | No | No | Yes | No | No | No | No
Rompe, Eysel, Hopf et al., 1995 | 60 | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No | No | No | No | No | No | Yes
Sanderson and Wood, 1993 | 34 | Yes | Yes | Yes | No | Yes | No | Yes | No | No | No | No | No | Yes | No | No | No | No
Robertson, Grobler, Novotny et al., 1993 | 33 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Postacchini, Cinotti, Perugia et al., 1993 | 70 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Hirabayashi, Kumano, and Kuroki, 1991 | 53 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Herkowitz and Garfin, 1989 | 99 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Prospective Trials
Jonsson, Annertz, Sjoberg et al., 1997a | 105 | Yes | Yes | Yes | No | Yes | Yes | Yes | No | No | No | No | No | Yes | Yes | Yes | No | No
Postacchini and Conotti, 1992 | 88 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Retrospective Trials with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 80 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Postacchini, Cinotti, Gumina et al., 1993 | 64 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Case-series
Guigui, Barre, Benoist et al., 1999 | 28 | Yes | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Number of Trials Reporting | 14 | 12 | 6 | 11 | 3 | 4 | 2 | 2 | 1 | 3 | 3 | 0 | 0 | 4 | 1 | 1 | 0 | 1
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 55 | Yes | No | Yes | Yes | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Mariconda, Zanforlino, Celestino et al., 2000 | 37 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Johnsson, Uden, and Rosen, 1991 | 76 | Yes | Yes | Yes | Yes | Yes | No | Yes | No | No | No | No | No | Yes | No | No | No | No
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen T, Weber H, Nordal HJ et al., 2000 | 100 | No | No | No | Yes | No | No | Yes | No | No | No | No | No | Yes | No | No | No | No
Hurri, Slatis, Soini et al., 1998 | 134 | Yes | No | No | Yes | No | Yes | Yes | No | No | Yes | No | No | Yes | No | No | No | No
Atlas, Deyo, Keller et al., 1996 | 148 | Yes | No | No | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | No
Swezey, 1996 | 47 | Yes | Yes | No | No | Yes | No | No | No | No | No | No | No | No | No | No | No | No
Nagler and Bodack, 1993 | 100 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Herno, Airaksinen, Saari et al., 1996 | 57 | Yes | Yes | No | No | Yes | No | Yes | No | No | No | No | No | Yes | No | No | No | No
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 43 | Yes | No | No | No | No | Yes | No | No | No | No | No | No | No | No | No | No | No
Rosenberg, 1976 | 200 | Yes | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | Yes
Number of Trials Reporting | 11 | 10 | 4 | 3 | 5 | 5 | 4 | 6 | 0 | 2 | 3 | 0 | 0 | 5 | 0 | 0 | 0 | 1
Summary of All Surgical Trials Reporting Signs, Symptoms, and Patient CharacteristicsRelated to Treatment of Lumbar Spinal Stenosis
Total Number Reporting | 147 | 122 | 45 | 79 | 52 | 68 | 59 | 59 | 17 | 47 | 52 | 9 | 20 | 27 | 7 | 5 | 8 | 26
Percentage of Trials Reporting | 100% | 83% | 31% | 54% | 35% | 46% | 40% | 40% | 12% | 32% | 35% | 6% | 14% | 18% | 5% | 3% | 5% | 18%

Evidence Table 3. Reporting of Patient Signs, Symptoms, and Other Characteristics Related to Lumbar Spinal Stenosis in Trials Describing Only the Natural History of Lumbar Spinal Stenosis Patients

First Author and Year of Publication | Number of Patients in the Trial | Mean Age | Duration of Illness Prior to Treatment | Mean Number of Vertebral Levels Involved | Prior Surgery | Claudication | Back Pain | Leg Pain | Back and Leg Pain | Leg Weakness | Sensory Dysfunction | Relief of Pain by Flexion | Incontinence of Bowel or Bladder | Extent of Stenosis | Patients with Hip Disorder | Patients with Knee Disorder | Patients with Arthritis | Patients with Herniated Disks
Patients with Central Lumbar Stenosis
Hamdan and Al-Kaissie, 1994 | 75 | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No
Patients with Lateral Lumbar Stenosis
Jonsson and Stromqvist, 1993b | 100 | Yes | Yes | No | No | Yes | Yes | No | No | No | Yes | Yes | No | No | No | No | No | No
Patients with Degenerative Spondylolisthesis
Matsunaga, Sakou, Morizono et al., 1990 | 40 | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | No | No
Sato, Wakamatsu, Yoshizumi et al., 1989 | 355 | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No | No
Patients with Lumbar Stenosis and Spondylolisthesis
Radu and Menkes, 1998 | 62 | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Yes | No | No | No | No | No | No | Yes
Amundsen, Weber, Lilleas et al., 1995 | 100 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes
Johnsson, Uden, and Rosen, 1992 | 32 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No | Yes | No | No | No | No
Number of Trials Reporting | 7 | 6 | 4 | 2 | 2 | 6 | 6 | 5 | 2 | 4 | 5 | 3 | 3 | 3 | 0 | 0 | 0 | 1

Evidence Table 4. Reporting of Outcomes in Randomized Controlled Trials of Conservative Treatment

First Author and Year of Publication | Number of Patients in the Trial | Measured Back Pain | Measured Back Pain Relief | Measured Leg Pain | Measured Leg Pain Relief | Measured Walking Capacity | Measured Global Success of Treatment | Measured Ability to Work | Measured Quality of Life | Measured Mental Status | Measured Disability or Dependency | Measured Activities of Daily Living
Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 53 | No | No | No | No | Yes | No | No | No | No | No | No
Eskola, Pohjolainen, Alaranta et al., 1992 | 39 | Yes | No | No | No | Yes | No | No | No | No | No | No
Cuckler, Bernini, Wiesel et al., 1985 | 37 | No | No | No | No | No | Yes | No | No | No | No | No
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 48 | Yes | No | No | No | No | Yes | Yes | No | No | No | No
Number of Trials Reporting | 4 | 2 | 0 | 0 | 0 | 2 | 2 | 1 | 0 | 0 | 0 | 0

Evidence Table 5. Reporting of Outcomes Related to Treatment of Lumbar Spinal Stenosis in Trials of Surgical Treatment

Trials Examining Surgical Patients with Central Lumbar Stenosis
First Author and Year of Publication | Number of Patients in the Trial | Measured Back Pain | Measured Back Pain Relief | Measured Leg Pain | Measured Leg Pain Relief | Measured Walking Capacity | Measured Global Success of Treatment | Measured Ability to Work | Measured Quality of Life | Measured Mental Status | Measured Disability or Dependency | Measured Activities of Daily Living
Randomized Controlled Trials
Grob, Humke, and Dvorak, 1995 | 45 | Yes | Yes | No | Yes | Yes | Yes | No | No | No | No | No
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 92 | Yes | No | Yes | No | Yes | Yes | No | No | No | Yes | No
Herno, Partanen, Talaslahti et al., 1999 | 80 | No | No | No | No | Yes | Yes | No | No | No | Yes | No
Hanakita, Suwa, and MIzuno, 1999 | 164 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Thomas, Rea, Pikul et al., 1997 | 38 | No | No | No | No | Yes | No | No | No | No | No | No
Yone, Sakou, Kawauchi et al., 1996 | 34 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Ray, 1982 | 65 | No | No | No | No | No | Yes | No | No | No | No | No
Surin, Hedelin, and Smith, 1982 | 22 | No | No | No | No | No | No | No | No | No | No | No
Tajima, Fukazawa, and Ishio, 1980 | 27 | No | No | No | No | No | Yes | No | No | No | No | No
Prospective Trials without Controls
Kleeman, Hiscoe, and Berg, 2000 | 54 | No | Yes | No | Yes | Yes | Yes | No | No | No | No | No
Weiner, Walker, Brower et al., 1999 | 30 | No | No | No | No | Yes | Yes | No | No | No | No | No
diPierro, Helm, Shaffrey et al., 1996 | 35 | Yes | No | No | No | No | Yes | No | No | No | No | No
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 65 | Yes | No | Yes | No | Yes | No | No | No | No | No | No
Matsui, Kanamori, Ishihara et al., 1997 | 27 | Yes | No | No | No | No | Yes | No | No | No | No | No
Airaksinen, Herno, Turunen et al., 1997 | 497 | No | No | No | No | Yes | No | Yes | No | No | Yes | No
Mullin, Rea, Irsik et al., 1996 | 72 | No | No | No | No | Yes | Yes | No | No | No | No | No
Ishac, Alhayek, Fournier et al., 1996 | 34 | No | Yes | No | Yes | Yes | Yes | No | No | No | No | No
Jonsson and Stromqvist, 1994 | 43 | No | No | Yes | No | Yes | No | No | No | No | No | No
Caputy and Luessenhop, 1992 | 100 | No | No | No | No | No | Yes | No | No | No | No | No
Dhar and Porter, 1992 | 36 | No | No | No | No | No | Yes | No | No | No | No | No
Chahal, Mundkur, Sancheti et al., 1982 | 32 | No | No | No | No | No | Yes | No | No | No | No | No
Rosomoff, 1981 | 50 | No | No | No | No | No | Yes | No | No | No | No | No
Getty, 1980 | 35 | No | No | No | No | No | Yes | No | No | No | No | No
Reale, Deifini, Gambacona et al., 1978 | 37 | No | No | No | No | No | Yes | No | No | No | No | No
Verbiest, 1977 | 116 | No | No | No | No | No | Yes | No | No | No | No | No
Case-series
Young, Veerapen, and O'Laoire, 1988 | 32 | No | No | No | Yes | No | Yes | No | No | No | No | No
Kurihara, Tanaka, Tsumura et al., 1988 | 12 | No | No | No | No | No | Yes | No | No | No | No | No
Hall, Bartleson, Onofrio et al., 1985 | 68 | No | No | No | No | Yes | Yes | No | No | No | Yes | No
Weinstein, Scafuri, and McNeill, 1983 | 24 | No | No | No | No | No | Yes | No | No | No | No | No
Weir and De Leo, 1981 | 81 | No | No | No | No | No | Yes | No | No | No | No | No
Johnsson, Willner, and Pettersson, 1981 | 27 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Verbiest, 1979 | 11 | No | Yes | No | Yes | Yes | No | No | No | No | No | No
Salibi, 1976 | 20 | No | No | No | No | No | Yes | No | No | No | No | No
Number of Trials Reporting | 33 | 8 | 4 | 6 | 5 | 16 | 27 | 1 | 0 | 0 | 2 | 0
Randomized Controlled Trials
Lee and deBari, 1986 | 24 | No | No | No | No | No | Yes | No | No | No | No | No
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 94 | No | No | Yes | No | No | Yes | Yes | No | No | No | No
Mikhael, Ciric, Tarkington et al., 1981 | 85 | No | No | No | No | No | Yes | No | No | No | No | No
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 66 | No | No | Yes | No | Yes | Yes | Yes | No | No | No | No
Baba, Uchida, Maezawa et al., 1996 | 31 | No | Yes | No | Yes | Yes | Yes | No | No | No | No | No
Aryanpur and Ducker, 1990 | 32 | No | No | No | No | No | Yes | No | No | No | No | No
Case-series
Choudhury and Taylor, 1977 | 28 | Yes | No | Yes | No | No | Yes | Yes | No | No | No | No
Epstein, Epstein, Rosenthal et al., 1972 | 15 | No | No | No | No | No | Yes | No | No | No | No | No
Number of Trials Reporting | 8 | 1 | 1 | 3 | 1 | 2 | 8 | 3 | 0 | 0 | 0 | 0
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Controlled Trials
Yone and Sakou, 1999 | 60 | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No
Epstein, 1999 | 21 | No | No | No | No | No | Yes | No | No | No | No | No
Javid and Hadar, 1998 | 170 | Yes | No | Yes | No | Yes | Yes | Yes | No | No | No | No
Kalbarczyk, Lukes, and Seiler, 1998 | 148 | No | No | No | No | No | Yes | No | No | No | No | No
Pai and Kumar, 1996 | 55 | No | No | No | No | No | Yes | No | No | No | No | No
Kawauchi, Yone, and Sakou, 1996 | 36 | Yes | No | No | No | No | Yes | No | No | No | No | No
Cinotti, Postacchini, and Weinstein, 1994 | 50 | No | No | No | No | No | Yes | No | No | No | No | No
Little and MacDonald, 1994 | 94 | No | No | No | No | No | No | No | No | No | Yes | No
Simpson, Silveri, Balderston et al., 1993 | 57 | No | No | No | No | No | Yes | No | No | No | No | Yes
Jonsson and Stromqvist, 1993a | 39 | No | No | No | Yes | No | No | No | No | No | No | No
Nasca, 1989 | 114 | No | No | No | No | No | Yes | No | No | No | No | No
Nather and Thomas, 1985 | 34 | No | No | No | No | No | Yes | No | No | No | No | No
Paine, 1976 | 143 | No | No | No | No | No | Yes | No | No | No | No | No
Shenkin and Hash, 1976 | 49 | No | No | No | No | No | Yes | No | No | No | No | No
Tile, McNeil, Zarins et al., 1976 | 26 | No | No | No | No | No | Yes | No | No | No | No | No
Retrospective Trials with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 34 | No | No | No | No | No | Yes | No | No | No | No | No
Silvers, Lewis, and Asch, 1993 | 248 | No | Yes | No | No | No | Yes | No | No | No | No | Yes
Katz, Lipson, Larson et al., 1991 | 88 | Yes | No | No | No | Yes | Yes | No | No | No | No | No
Ganz, 1990 | 36 | No | Yes | No | Yes | No | Yes | No | No | No | No | No
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 70 | No | Yes | No | No | No | No | No | No | No | No | No
Guigui, Benoist, Delecourt et al., 1998 | 50 | No | No | No | No | No | Yes | No | No | No | No | No
Scholz, Firsching, and Lanksch, 1998 | 72 | No | Yes | No | No | No | Yes | No | No | No | No | No
Tsai, Yang, and Bray, 1998 | 62 | Yes | No | Yes | No | No | Yes | No | No | No | No | No
Mackay and Wheelwright, 1998 | 50 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Whitecloud, Castro Jr, Brinker et al., 1998 | 35 | Yes | No | No | No | No | No | Yes | No | No | No | No
Spetzger, Bertalanffy, Reinges et al., 1997 | 29 | No | Yes | No | No | No | Yes | No | No | No | No | No
Katz, Lipson, Chang et al., 1996 | 88 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Lehto and Honkanen, 1995 | 96 | No | No | No | No | No | Yes | No | No | No | No | No
Stucki, Liang, Fossel et al., 1995 | 230 | No | No | No | No | No | Yes | No | No | No | No | No
Tuite, Stern, Doran et al., 1994 | 119 | No | No | No | No | No | Yes | No | No | No | No | No
McCullen, Bernini, Bernstein et al., 1994 | 193 | Yes | Yes | No | No | No | Yes | No | No | No | No | Yes
Simmons and Simmons, 1992 | 40 | Yes | No | Yes | No | No | No | No | No | No | No | No
Mauersberger and Nietgen, 1989 | 92 | No | No | No | No | No | Yes | No | No | No | No | No
Johnsson, Redlund-Johnell, Uden et al., 1989 | 61 | No | No | No | No | No | Yes | No | No | No | No | No
Brodsky, Hendricks, Khalil et al., 1989 | 36 | No | No | No | No | No | Yes | No | No | No | No | No
Jalovaara, Lahde, Iikko et al., 1989 | 31 | No | No | No | No | No | Yes | No | No | No | No | No
Fast, Robin, and Floman, 1985 | 19 | No | Yes | No | No | Yes | No | No | No | No | No | No
Boccanera, Pellicioni, and Laus, 1984 | 25 | No | No | No | No | No | Yes | No | No | No | No | No
Hood and Weigl, 1983 | 21 | No | Yes | No | No | Yes | Yes | No | No | No | No | No
Scafuri and Weinstein, 1981 | 27 | No | No | No | No | No | Yes | No | No | No | No | No
Echeverria and Lockwood, 1979 | 35 | No | No | No | No | No | Yes | No | No | No | No | No
Scapinelli, 1978 | 23 | No | No | No | No | No | Yes | No | No | No | No | No
Vestad and Naca, 1977 | 80 | No | Yes | No | No | No | Yes | Yes | No | No | No | No
McKinley and Davis, 1976 | 32 | No | No | No | No | No | Yes | No | No | No | No | No
Teng and Papatheodorou, 1963 | 29 | No | No | No | No | No | Yes | No | No | No | No | No
Epstein, Epstein, and Lavine, 1962 | 29 | No | No | No | No | No | Yes | No | No | No | No | No
Epstein, 1960 | 14 | No | No | No | No | No | Yes | No | No | No | No | No
Number of Trials Reporting | 47 | 10 | 10 | 6 | 3 | 7 | 41 | 3 | 0 | 0 | 1 | 3
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trials
Fischgrund, Mackay, Herkowitz et al., 1997 | 75 | Yes | No | Yes | No | No | Yes | No | No | No | No | No
Thomsen, Christensen, Eiskjaer et al., 1997 | 41 | No | No | No | No | No | No | No | Yes | Yes | No | Yes
Bridwell, Sedgewick, O'Brien et al., 1993 | 43 | No | No | No | No | Yes | No | No | No | No | No | No
Herkowitz and Kurz, 1991 | 50 | Yes | No | Yes | No | No | Yes | No | No | No | No | No
Controlled Trials
Plotz and Benini, 1998 | 106 | No | Yes | No | Yes | No | Yes | No | No | No | No | No
Yuan, Garfin, Dickman et al., 1994 | 2684 | No | Yes | No | Yes | No | No | No | No | No | No | Yes
Satomi, Hirabayashi, Toyama et al., 1992 | 41 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Lombardi, Wiltse, Reynolds et al., 1985 | 47 | No | No | No | No | No | Yes | No | No | No | No | No
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 23 | No | No | No | No | No | Yes | No | No | No | No | No
Rechtine, Sutterlin, Wood et al., 1996 | 18 | No | Yes | No | No | No | No | Yes | No | No | No | Yes
Retrospective Trials with Consecutive Patients
Stambough, 1999 | 35 | Yes | No | Yes | No | No | No | No | No | No | No | No
Nishizawa and Fujimura, 1997 | 58 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Moller, Wittenberg, Nolte et al., 1992 | 37 | No | No | No | No | No | Yes | No | No | No | No | No
Marchesi, Thalgott, and Aebi, 1991 | 30 | No | No | No | No | No | Yes | No | No | No | No | No
Takahashi, Kitahara, Yamagata et al., 1990 | 39 | No | No | No | No | Yes | Yes | No | No | No | No | Yes
Knox, Harvell, Nelson et al., 1989 | 39 | Yes | No | Yes | No | Yes | Yes | Yes | No | No | No | No
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 49 | Yes | No | No | No | No | Yes | Yes | No | Yes | Yes | Yes
McCulloch, 1998 | 21 | No | No | No | No | No | Yes | No | No | No | No | No
Epstein, 1998b | 28 | No | No | No | No | No | Yes | No | No | No | No | No
Mochida, Toh, Suzuki et al., 1997 | 10 | No | No | No | No | No | Yes | No | No | No | No | No
Epstein, 1998a | 290 | No | No | No | No | No | Yes | No | No | No | No | No
Grob, Humke, and Dvorak, 1996 | 18 | Yes | No | No | No | Yes | No | Yes | No | No | No | No
Herron and Trippi, 1989 | 24 | No | Yes | No | Yes | No | Yes | No | No | No | No | No
Chang and McAfee, 1989 | 17 | No | No | No | No | No | Yes | No | No | No | No | No
Inoue, Watanabe, Goto et al., 1988 | 36 | Yes | No | Yes | No | Yes | No | No | No | No | No | Yes
Simmons and Capicotto, 1988 | 15 | No | No | No | No | No | No | No | No | No | No | No
Hanley, 1986 | 20 | No | No | No | No | No | Yes | No | No | No | No | No
Kaneda and Kazama, 1986 | 54 | No | No | No | No | No | Yes | No | No | No | No | No
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 50 | No | Yes | No | No | No | No | No | No | No | No | No
Dall and Rowe, 1985 | 26 | Yes | No | No | No | No | Yes | No | No | No | No | No
Epstein, Epstein, Carras et al., 1983 | 60 | No | No | No | No | No | Yes | No | No | No | No | No
Richardson and Brown, 1980 | 21 | No | No | No | No | No | Yes | No | No | No | No | No
Cauchoix, Benoist, and Chassaing, 1976 | 26 | No | No | No | No | No | Yes | No | No | No | No | No
Epstein, Epstein, Lavine et al., 1976 | 20 | No | No | No | No | No | No | No | No | No | No | No
Number of Trials Reporting | 34 | 1 | 4 | 7 | 3 | 7 | 24 | 4 | 1 | 2 | 1 | 6
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
Controlled Trials
Rompe, Eysel, Zollner et al., 1999 | 117 | Yes | Yes | No | No | Yes | Yes | No | No | No | No | Yes
Katz, Lipson, Lew et al., 1997 | 272 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Sato and Kikuchi, 1997 | 81 | Yes | Yes | Yes | No | No | No | No | No | No | No | No
Rompe, Eysel, Hopf et al., 1995 | 60 | Yes | No | No | No | No | Yes | No | No | No | No | No
Sanderson and Wood, 1993 | 34 | No | No | No | No | No | Yes | No | No | No | No | No
Robertson, Grobler, Novotny et al., 1993 | 33 | No | No | No | No | No | No | No | No | No | No | No
Postacchini, Cinotti, Perugia et al., 1993 | 70 | No | Yes | No | Yes | No | Yes | No | No | No | No | No
Hirabayashi, Kumano, and Kuroki, 1991 | 53 | No | No | No | No | No | Yes | No | No | No | No | No
Herkowitz and Garfin, 1989 | 99 | No | No | No | No | No | Yes | No | No | No | No | No
Prospective Trials
Jonsson, Annertz, Sjoberg et al., 1997a | 105 | Yes | No | No | No | Yes | Yes | No | No | No | No | No
Postacchini and Conotti, 1992 | 88 | No | No | No | No | No | Yes | No | No | No | No | No
Retrospective Trials with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 80 | No | No | No | No | No | No | No | No | No | No | Yes
Postacchini, Cinotti, Gumina et al., 1993 | 64 | No | No | No | No | No | Yes | No | No | No | No | No
Case-series
Guigui, Barre, Benoist et al., 1999 | 28 | No | No | No | No | No | Yes | No | No | No | No | No
Number of Trials Reporting | 14 | 5 | 3 | 2 | 1 | 3 | 11 | 0 | 0 | 0 | 0 | 2
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 55 | Yes | No | Yes | No | Yes | Yes | No | No | No | No | No
Mariconda, Zanforlino, Celestino et al., 2000 | 37 | Yes | No | Yes | No | Yes | Yes | No | Yes | No | No | No
Johnsson, Uden, and Rosen, 1991 | 76 | Yes | No | No | No | Yes | Yes | Yes | No | No | No | No
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundse, Weber, Nordal et al., 2000 | 100 | No | No | Yes | No | No | Yes | No | No | No | No | No
Hurri, Slatis, Soini et al., 1998 | 134 | No | No | No | No | No | Yes | No | No | No | Yes | No
Atlas, Deyo, Keller et al., 1996 | 148 | No | Yes | No | Yes | No | Yes | No | Yes | No | Yes | Yes
Swezey, 1996 | 47 | No | No | No | No | No | Yes | No | No | No | No | No
Nagler and Bodack, 1993 | 100 | No | No | No | No | No | Yes | No | No | No | No | No
Herno, Airaksinen, Saari et al., 1996 | 57 | No | No | No | No | No | No | No | No | No | Yes | Yes
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 43 | No | No | No | No | No | Yes | No | No | No | No | No
Rosenberg, 1976 | 200 | No | No | No | No | No | Yes | No | No | No | No | No
Number of Trials Reporting | 11 | 3 | 1 | 3 | 1 | 3 | 10 | 1 | 2 | 0 | 3 | 2
Summary of All Surgical Trials Reporting Outcomes Related to Treatment of Lumbar Spinal Stenosis
Total Number Reporting | 147 | 37 | 23 | 27 | 14 | 38 | 122 | 12 | 3 | 2 | 7 | 13
Percentage of Trials Reporting | 100% | 25% | 16% | 18% | 10% | 26% | 83% | 8% | 2% | 1% | 5% | 9%

Evidence Table 6. General Study Design Information for Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized Controlled Trials of Patients Receiving Conservative Treatments
First Author and Year of Publication | Number of Patients in the Trial | Years When Trial was Conducted | Number of Trial Centers | Institution of First Author | Country Where Trial was Conducted | Funding Source for Trial
Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 53 | | Single | Nagasaki Rosai Hospital | Japan | Not Stated
Eskola, Pohjolainen, Alaranta et al., 1992 | 39 | | Single | The Orthopaedic Hospital of the Invalid Foundation, Helsinki, Finland | Finland | Not Stated
Cuckler, Bernini, Wiesel et al., 1985 | 37 | | | Pennsylvania Hospital | United States
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 48 | | Single | Mayo Clinic | United States
Trials Examining Surgical Patients with Central Lumbar Stenosis
Randomized controlled Trial
Grob, Humke, and Dvorak, 1995 | 45 | 1989-1990 | Single | Schulthess Hospital | Switzerland | No funds were received in support of this study.
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 92 | 1985-1988 | Single | Kuopio University Hospital | Finland | Not reported
Herno, Partanen, Talaslahti et al., 1999 | 80 | 1982-1984 | Single | Kuopio University Hospital | Finland | Not reported
Hanakita, Suwa, and MIzuno, 1999 | 164 | 1990-1998 | Single | Shizuoka Gneral Hospital | Japan | Not reported
Thomas, Rea, Pikul et al., 1997 | 38 | 1990-1992 | Single | Ohio State University | United States | not reported
Yone, Sakou, Kawauchi et al., 1996 | 34 | 1988-1992 | Single | Kagoshima University | Japan | Not reported
Ray, 1982 | 65 | 1978-1980 | Single | Institute for Low Back Care, Sister Kenny Institute, Minnesota | United States | Not reported
Surin, Hedelin, and Smith, 1982 | 22 | 1974-1980 | Single | Central Hospital, Boras, Sweden | Sweden
Tajima, Fukazawa, and Ishio, 1980 | 27 | 1977-1980 | Single | Miyazaki Medical College | Japan | Not reported
Prospective Trials
Kleeman, Hiscoe, and Berg, 2000 | 54 | 1992-1995 | Single | New Hampshire Spine Institute | United States | Not reported
Weiner, Walker, Brower et al., 1999 | 30 | 1996-1997 | Single | Spinal Unit, Northeastern Ohio Universities, College of Medicine | United States | Not reported
diPierro, Helm, Shaffrey et al., 1996 | 35 | 1990-1992 | Single | Virginia Neurological Institute, University of Virginia Health Sciences Center | United States | Not reported
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 65 | 1990-1996 | Single | University of Louisville School of Medicine | United States | Not reported
Matsui, Kanamori, Ishihara et al., 1997 | 27 | 1984-1992 | Single | Toyama Medical and Pharmaceutical University | Japan | Not reported
Airaksinen, Herno, Turunen et al., 1997 | 497 | 1974-1988 | Single | Kuopio University Hospital | Finland | Not reported
Mullin, Rea, Irsik et al., 1996 | 72 | 1986-1990 | Single | The Ohio State University | United States | Not reported
Ishac, Alhayek, Fournier et al., 1996 | 34 | 1979-1994 | Single | Teaching Hospital Angers France | France | Not reporting
Jonsson and Stromqvist, 1994 | 43 | 1991-1992 | Single | University Hospital Lund | Sweden | Sewdish Medical Research Council
Caputy and Luessenhop, 1992 | 100 | 1980-1984 | Single | Georgetown University Medical Center | United States | Not reported
Dhar and Porter, 1992 | 36 | 1980-1984 | Single | Doncaster Royal Infirmary | England | Not reported
Chahal, Mundkur, Sancheti et al., 1982 | 32 | 1978-1980 | Single | Armed Forces Medical College | India | Not reported
Rosomoff, 1981 | 50 | 1972-1980 | Single | University of Miami School of Medicine | United States | Not reported
Getty, 1980 | 35 | 1968-1978 | Single | Nordolk and Norwich Hospital | England | Not reported
Reale, Deifini, Gambacona et al., 1978 | 37 | 1974-1976 | Single | University of Siena | Italy | Not reported
Verbiest, 1977 | 116 | 1948-1976 | Single | University of Utrecht | Netherlands | Not reported
Case-series
Young, Veerapen, and O'Laoire, 1988 | 32 | | Multiple <5 | National Neurosurgery Centre and Richmond Institute of Neurology and Neurosurgery, Beaumont Hospital, Dublin, Eire | Ireland
Kurihara, Tanaka, Tsumura et al., 1988 | 12 | 1966-1984 | Single | Kobe Rosai Hospital, Kobe, Japan | Japan
Hall, Bartleson, Onofrio et al., 1985 | 68 | 1978-1980 | Single | Mayo Clinic and Mayo Foundation, Rochester, MN, United States | United States
Weinstein, Scafuri, and McNeill, 1983 | 24 | 1976-1980 | Single | Rush-Presbyterian St. Luke's Medical Center | United States | Not reported
Weir and De Leo, 1981 | 81 | 1968-1980 | Single | University of Alberta | Canada | Not reported
Johnsson, Willner, and Pettersson, 1981 | 27 | 1973-1980 | Single | Malmo General Hospital, Sweden | Sweden
Verbiest, 1979 | 11 | 1960-1976 | Single | State University of Utrecht, Utrecht, The Netherlands | Netherlands
Salibi, 1976 | 20 | 1970-1974 | Single | Marshfield Clinic and Marshfield Medical Foundation, Inc., Marshfield, Wisconsin, United States | United States
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized controlled Trial
Lee and deBari, 1986 | 24 | 1977-1984 | Single | New Jersey Medical School | United States | Not reported
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 94 | 1967-1978 | Single | University Hospital, Saskatoon | Canada | Not reported
Mikhael, Ciric, Tarkington et al., 1981 | 85 | 1976-1980 | Single | Evanston Hospital, Northwestern University | United States | Not reported
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 66 | 1982-1988 | Single | Northern General Hospital | England | Not reported
Baba, Uchida, Maezawa et al., 1996 | 31 | 1988-1996 | Single | Fuku Medical School | Japan | Not reported
Aryanpur and Ducker, 1990 | 32 | 1985-1988 | Single | John Hopkins Hospital | United States | Not reported
Case-series
Choudhury and Taylor, 1977 | 28 | 1974-1976 | Single | Derbyshire Royal Infirmary, Derby, England | England
Epstein, Epstein, Rosenthal et al., 1972 | 15 | 1967-1972 | Single | Long Island Jewish Medical Center, New Hyde Park, New York, United States | United States
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes bothtypes of stenosis
Controlled Trial
Yone and Sakou, 1999 | 60 | 1986-1996 | | Kagoshima University, Jakgshima, Japan | Japan
Epstein, 1999 | 21 | 1986-1996 | Single | North Shore University Hospital, Manhasset, NY, United States | United States
Javid and Hadar, 1998 | 170 | 1984-1996 | Single | University of Wisconsin Hospital and Clinics | United States | Not reported
Kalbarczyk, Lukes, and Seiler, 1998 | 148 | | Single | Inselspital, Bern, Switzerland | Switzerland
Pai and Kumar, 1996 | 55 | 1980-1984 | Single | Kasturba Medical College, Manipal, Karnataka, India | India
Kawauchi, Yone, and Sakou, 1996 | 36 | 1990-1996 | Single | Kagoshima University | Japan
Cinotti, Postacchini, and Weinstein, 1994 | 50 | | Multiple <5 | Orthoaedic Clinic, University of Rome | Italy and the United States | No funds from commercial party.
Little and MacDonald, 1994 | 94 | 1987-1992 | Single | Sydney Adventist Hospital | Australia | Not reported
Simpson, Silveri, Balderston et al., 1993 | 57 | 1982-1988 | Single | Tuckahoe Orthopaedic Associates and The Rothman Institute, Pennsylvania Hospital | United States | No funds were received in support of this study.
Jonsson and Stromqvist, 1993a | 39 | | Single | University Hospital Lund | Sweden | Swedish Medical Research Council, Medical Faculty of Lund, the Thelma Aoegas Fund
Nasca, 1989 | 114 | 1979-1986 | Single | University of Alabama at Birmingham, Birmingham, Alabama, United States | United States
Nather and Thomas, 1985 | 34 | 1973-1980 | Single | Singapore General Hospital | Singapore
Paine, 1976 | 143 | | Single | University Hospital, Saskatoon, Saskatchewan, Canada
Shenkin and Hash, 1976 | 49 | 1968-1972 | Single | Episcopal Hospital | United States | Not reported
Tile, McNeil, Zarins et al., 1976 | 26 | 1957-1974 | Single | St. Joseph's Hospital | Canada | Not reported
Retrospective Trial with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 34 | 1988-1992 | Single | Spinal Disorder Unit, Cromwell Hospital | United Kingdom | Not reported
Silvers, Lewis, and Asch, 1993 | 248 | 1978-1992 | Single | Southtowns Neurological Surgeons Association, Buffalo, NY | United States | Not reported
Katz, Lipson, Larson et al., 1991 | 88 | 1983-1986 | Single | Bringham and Women's Hospital, Robert B. Brigham Multipurpose Arthritis Center | United States | NIH grant
Ganz, 1990 | 36 | 1981-1986 | Single | Haukeland Hospital | Norway | Not reported
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 70 | 1996-1996 | Single | University of Texas Medical Branch, Galveston, TX, United States | United States
Guigui, Benoist, Delecourt et al., 1998 | 50 | | | Hospital Beaujon, Clichy, France | France
Scholz, Firsching, and Lanksch, 1998 | 72 | 1987-1990 | Single | Free University of Berlin | Germany
Tsai, Yang, and Bray, 1998 | 62 | | Single | Garfield Medical Center, Monterey Park, CA, United States | United States
Mackay and Wheelwright, 1998 | 50 | 1992-1996 | Single | Stobhill Hospital, Glasgow, UK | UK
Whitecloud, Castro Jr, Brinker et al., 1998 | 35 | 1993-1994 | Multiple <5 | Tulane University School of Medicine, New Orleans, LA, United States | United States
Spetzger, Bertalanffy, Reinges et al., 1997 | 29 | | Single | Technical University of Aachen, Aachen, Federal Republic of Germany | Germany
Katz, Lipson, Chang et al., 1996 | 88 | 1983-1986 | Multiple <5 | Brigham and Women's Hospital | United States | NIH Grant#AR36308, a Summer Medical Student Research Grant from the American College of Rheumatology
Lehto and Honkanen, 1995 | 96 | 1980-1988 | Single | Tampere University, Tampere, Finland | Finland
Stucki, Liang, Fossel et al., 1995 | 230 | | Multiple <5 | University of Zurich, Zurich, Switzerland | Switzerland
Tuite, Stern, Doran et al., 1994 | 380 | 1983-1990 | Multiple <5 | University of Michigan Hospital | United States
McCullen, Bernini, Bernstein et al., 1994 | 193 | 1980-1992 | | Dartmouth-Hitchcock Medical Center, Lebanon, NH, United States | United States
Simmons and Simmons, 1992 | 40 | | Single | Buffalo General Hospital | United States | Not reported
Mauersberger and Nietgen, 1989 | 92 | 1979-1986 | Multiple <5 | University Hospital, Bonn, Germany | Germany
Johnsson, Redlund-Johnell, Uden et al., 1989 | 61 | 1972-1986 | | Malmo General Hospital, Lund University, Malmo, Sweden | Sweden
Brodsky, Hendricks, Khalil et al., 1989 | 36 | | Single | Baylor College of Medicine, Houston, TX, United States | United States
Jalovaara, Lahde, Iikko et al., 1989 | 31 | 1978-1982 | Single | University of Oulu, Finland | Finland
Fast, Robin, and Floman, 1985 | 19 | 1980-1984 | Multiple <5 | Ichilov Hospital, Tel Aviv Medical Center, Tel Aviv, Israel | Israel
Boccanera, Pellicioni, and Laus, 1984 | 25 | 1977-1981 | Single | Traumatical and Orthopaedic Centre, Bologna | Italy
Hood and Weigl, 1983 | 21 | 1975-1980 | Single | Hasharon Hospital | Israel
Scafuri and Weinstein, 1981 | 27 | 1977-1980 | Single | Rush-Presbyterian-St. Luke's Medical Center | United States | Not reported
Echeverria and Lockwood, 1979 | 35 | 1966-1976 | Single | Upstate Medical Center, Syracuse, NY, United States | United States
Scapinelli, 1978 | 23 | 1966-1978 | Single | Unicersita degli Studi di Chieti, Chieti, Italy | Italy
Vestad and Naca, 1977 | 80 | 1955-1970 | Single | Sophies Minde Orthopaedic Hospital, University of Oslo, Oslo, Norway | Norway
McKinley and Davis, 1976 | 32 | 1963-1972 | Single | Ochsner Clinic, New Orleans, LA, United States | United States
Teng and Papatheodorou, 1963 | 29 | | Single | The Kaiser Foundation Hospitals | United States
Epstein, Epstein, and Lavine, 1962 | 29 | | Single | Long Island Jewish Hospital, New Hyde Park, NY, United States | United States
Epstein, 1960 | 14 | | Single | Long Island Jewish Hospital, New Hyde Park, NY, United States | United States
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trial
Fischgrund, Mackay, Herkowitz et al., 1997 | 75 | | Single | William Beaumont Hospital | Michigan, United States | No funds were received in support of this study.
Thomsen, Christensen, Eiskjaer et al., 1997 | 41 | 1992-1994 | Multiple <5 | University Hospital of Aarhus | Denmark | The Danish Rheumatism Association and Arosia Spine Research Foundation
Bridwell, Sedgewick, O'Brien et al., 1993 | 43 | 1985-1990 | Single | Washington University School of Medicine, St. Louis | United States | No outside funding
Herkowitz and Kurz, 1991 | 50 | | Single | William Beaumont Hospital | United States | No funds were received in support of this study
Controlled Trials
Plotz and Benini, 1998 | 106 | 1979-1992 | | Schulthess Clinic, Zurich, Switzerland | Switzerland
Yuan, Garfin, Dickman et al., 1994 | 2684 | 1990-1992 | Multiple >5 | State University of New York | United States, Canada, Europe | FDA
Satomi, Hirabayashi, Toyama et al., 1992 | 41 | 1981-1988 | Single | Keio University School of Medicine | Japan | Not reported
Lombardi, Wiltse, Reynolds et al., 1985 | 47 | 1971-1984 | Single | Memorial Hospital Medical Center of Long Beach, California, United States | United States
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 23 | 1986-1992 | Single | Fujita Health University | Japan | Not reported
Rechtine, Sutterlin, Wood et al., 1996 | 18 | 1989-1990 | Multiple <5 | Florida Orthopedic Institute | United States | Sofamor Danek United States; maker of the pedicle/screw system used in the trial
Retrospective Trial with Consecutive Patients
Stambough, 1999 | 35 | 1986-1994 | Single | Back Treatment Center, Deaconess Hospital, Cincinnati | United States | Not reported
Nishizawa and Fujimura, 1997 | 58 | 1982-1992 | Single | Keio University School of Medicine | Japan | Not reported
Moller, Wittenberg, Nolte et al., 1992 | 37 | 1981-1992 | Single | Department of Surgery, Augusta-Krankenanstallen | Germany | Not reported
Marchesi, Thalgott, and Aebi, 1991 | 30 | 1984-1988 | Multiple <5 | University of Bern | Switzerland and United States
Takahashi, Kitahara, Yamagata et al., 1990 | 39 | 1958-1988 | Single | Chiba University School of Medicine | Japan | Not reported
Knox, Harvell, Nelson et al., 1989 | 39 | 1983-1988 | Single | Orthopaedic Surgery and Neurosurgery, University of Pittsburgh | United States | Not reported
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 49 | | Single | Washington University School of Medicine, St. Louis, Missouri, United States | United States
McCulloch, 1998 | 21 | 1993-1996 | Single | Northeastern Ohio Universities College of Medicine, Rootstown OH, United States | United States
Epstein, 1998b | 28 | 1991-1996 | Single | North Shore University Hospital, Manhasset, NY, United States | United States
Mochida, Toh, Suzuki et al., 1997 | 10 | 1990-1996 | Single | Tokai University School of Medicine, Kanagawa, Japan | Japan
Epstein, 1998a | 290 | 1966-1996 | Multiple <5 | Cornell University Medical College, Ithaca, NY, United States | United States
Grob, Humke, and Dvorak, 1996 | 18 | 1987-1992 | Single | Schulthess Hospital, Zurich, Switzerland | Switzerland
Herron and Trippi, 1989 | 24 | 1980-1986 | Single | Central Coast Spine Institute, San Luis Obispo, CA, United States | United States
Chang and McAfee, 1989 | 17 | | Single | 803 Army General Hospital, Taiwan, R.O.C. | United States
Inoue, Watanabe, Goto et al., 1988 | 36 | 1958-1984 | Single | School of Medicine, Chiba University, Chiba, Japan | Japan
Simmons and Capicotto, 1988 | 15 | | Single | State University of New York at Buffalo and Buffalo General Hospital, Buffalo, NY, United States | United States
Hanley, 1986 | 20 | | | University of Pittsburgh, Pittsburgh, PA, United States | United States
Kaneda and Kazama, 1986 | 54 | 1978-1984 | Single | Hokkaido University School of Medicine, Sapporo, Japan | Japan
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 50 | 1972-1984 | Single | Bowman Gray School of Medicine, Wake Forest University, Winston-Salem, NC, United States | United States
Dall and Rowe, 1985 | 26 | 1977-1980 | Multiple <5 | Michigan State University, Kalamazoo, MI, United States | United States
Epstein, Epstein, Carras et al., 1983 | 60 | 1971-1982 | Single | Long Island Jewish-Hillside Medical Center | United States | Not reported
Richardson and Brown, 1980 | 21 | 1976-1980 | Single | Piedmont Hospital and Georgia Baptist Hospital | United States | Not reported
Cauchoix, Benoist, and Chassaing, 1976 | 26 | | Single | Clinique Orthopedique de l'Hopital Boujon. Faculte de Medecine Xavier Bichat, Universite de Paris, VIII, Paris, France | France
Epstein, Epstein, Lavine et al., 1976 | 20 | 1965-1974 | Single | Long Island Jewish Hospital, New Hyde Park, NY, United States | United States
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
Controlled Trial
Rompe, Eysel, Zollner et al., 1999 | 117 | 1987-1992 | Single | Johannes Gutenberg Medical School | Germany | Not reported
Katz, Lipson, Lew et al., 1997 | 272 | 1989-1992 | Multiple >5 | Brigham and Women's Hospital, Boston, Massachusetts | United States | NIH grant and an Arthritis Foundation Investigator award to Dr. Katz
Sato and Kikuchi, 1997 | 81 | 1989-1996 | Single | Fukushima Medical College, Japan | Japan | Fukushima Society for the Promotion of Medicine
Rompe, Eysel, Hopf et al., 1995 | 60 | 1986-1992 | Single | Johannes Gutenberg University Hospital, Mainz, Federal Republic of Germany | Germany
Sanderson and Wood, 1993 | 34 | 1984-1988 | Single | Wrightington Hospital | England | Not reported
Robertson, Grobler, Novotny et al., 1993 | 33 | | Multiple <5 | McClure Musculoskeletal Research Center, Spine Institute of New England | United States | Spine Institute of New England Surgeons Research Fund, Arthritis Foundation, NIH grant
Postacchini, Cinotti, Perugia et al., 1993 | 70 | 1987-1992 | Single | University of Modena | Italy | Not reported
Hirabayashi, Kumano, and Kuroki, 1991 | 53 | 1986-1988 | Single | Kantoh Rosai Hospital | Japan | Not reported
Herkowitz and Garfin, 1989 | 99 | | Single | William Beaumont Hospital, Royal Oak, MI, United States | United States
Prospective Trials
Jonsson, Annertz, Sjoberg et al., 1997a | 105 | 1986-1992 | Single | Lund University Hospital, Lund, Sweden | Sweden | Swedish Medical Research Council
Postacchini and Conotti, 1992 | 88 | 1972-1984 | Single | University of Modena | Italy | Not reported
Retrospective Trial with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 80 | 1983-1990 | Single | Fukui Medical School | Japan | Not reported
Postacchini, Cinotti, Gumina et al., 1993 | 64 | 1972-1988 | Multiple <5 | University of Modena | Italy | Not reported
Case-series
Guigui, Barre, Benoist et al., 1999 | 28 | 1984-1988 | Single | Hospital Beaujon | France | Not reported
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 55 | 1992-1998 | Single | Physical Medicine and Rehabilitation Service, Hospital for Special Surgery, NY | United States | Not reported
Mariconda, Zanforlino, Celestino et al., 2000 | 37 | 1994-1996 | Single | University of Catanzaro Magna Graecia School of Medicine | Italy | Not reported
Johnsson, Uden, and Rosen, 1991 | 76 | 1974-1984 | Single | Malmo General Hospital, Lund University | Sweden | Herman Jamhardt, Greta and Johan Kock, and Alfred Osterlund Foundation
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen T, Weber H, Nordal HJ et al., 2000 | 100 | 1984-1996 | Single | Ulleval Hospital, Oslo, Norway | Norway | Clinical Research Forum, Ulleval University Hospital, Oslo, Norway
Hurri, Slatis, Soini et al., 1998 | 134 | 1978-1982 | Single | Orthopaedic Hospital of the Invalid Foundation | Finland | Not reported
Atlas, Deyo, Keller et al., 1996 | 148 | 1990-1992 | Multiple >5 | Massachusetts General Hospital, Harvard Medical School | United States | Agency for Health Care Policy and Research grant
Atlas, Keller, Robson et al., 2000 | 119 | Four year followup of Atlas, Deyo, Keller et al., 1996
Swezey, 1996 | 47 | 1986-1988 | Single | Arthritis and Back Pain Center, Swezey Institute | United States | Not Reported
Nagler and Bodack, 1993 | 100 | 1980-1983 | Single | The New York Hospital - Cornell University | United States | Not reported
Herno, Airaksinen, Saari et al., 1996 | 57 | 1980-1988 | Single | Kuopio University Hospital | Finland | Not reported
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 43 | 1953-1970 | Single | Spinal Research Unit, Royal National Orthopaedic Hospital | England | Not reported
Rosenberg, 1976 | 200 | 1956-1968 | Single | Mount Sinai Hospital, Cleveland | United States | Not reported
Trials Describing Only the Natural History of Lumbar Spinal Stenosis Patients
Patients with Central Lumbar Stenosis
Hamdan and Al-Kaissie, 1994 | 75 | 1990-1992 | Single | Basrah University Hospital | Iraq | Not reported
Patients with Lateral Lumbar Stenosis
Jonsson and Stromqvist, 1993b | 100 | 1986-1992 | Single | Lund University Hospital | Sweden | Swedish Medical Research Council
Patients with Degenerative Spondylolisthesis
Matsunaga, Sakou, Morizono et al., 1990 | 40 | 1975-1990 | Single | Kagoshima University | Japan | Not reported
Sato, Wakamatsu, Yoshizumi et al., 1989 | 355 | 1983-1984 | Single | Akita University School of Medicine | Japan | Not reported
Patients with Lumbar Stenosis and Spondylolisthesis
Radu and Menkes, 1998 | 62 | 1995-1996 | Single | School of Medicine of the Sao Paulo University | France | Conselho Nacional de desenvolvimento Cientifico e tecnologico CNPq
Amundsen, Weber, Lilleas et al., 1995 | 100 | 1984-1988 | Single | Ulleval Hospital, Oslo | Norway | Not reported
Johnsson, Uden, and Rosen, 1992 | 32 | 1981-1988 | Single | Malmo General Hospital, Lund University, Malmo, Sweden | Sweden

Evidence Table 7. Specific Study Design Information for Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized controlled Trials of Patients Receiving Conservative Treatments
First Author and Year of Publication | Number of Patients in the Trial | Imaging Method Used in Study | Randomization Method | Blinding Method | Described Dropouts and Withdrawals | Reported Prior Conservative Treatment
Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 53 | MRI/CT | Not Stated | Investigator only | Yes | Not reported
Eskola, Pohjolainen, Alaranta et al., 1992 | 39 | X-ray Myelography and CT | Men and women were randomized separately. Method not stated. | Double | No | Not reported
Cuckler, Bernini, Wiesel et al., 1985 | 37 | | Not Stated | Double | No | At least 2 weeks
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 48 | Plain radiograph | Not reported | Open | No | Not reported
Trials Examining Surgical Patients with Central Lumbar Stenosis
Randomized controlled Trial
Grob, Humke, and Dvorak, 1995 | 45 | Plain radiograph, X-ray Myelography, CT, and MRI | Randomly assigned on the basis of the day of admission to the hospital. | Investigator only | Yes | Not reported
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 92 | Computerized Tomography CT | None | Double | No | Not reported
Herno, Partanen, Talaslahti et al., 1999 | 80 | X-ray Myelography and CT | None | Double | Yes | Not reported
Hanakita, Suwa, and MIzuno, 1999 | 164 | Plain radiograph | None | Open | No | Not reported
Thomas, Rea, Pikul et al., 1997 | 38 | Plain radiograph and MRI | None | Investigator only | Yes | Not reported
Yone, Sakou, Kawauchi et al., 1996 | 34 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Ray, 1982 | 65 | Computerized Tomography CT | None | Open | No | Not reported
Surin, Hedelin, and Smith, 1982 | 22 | X-ray Myelography | none | none | No | Not reported
Tajima, Fukazawa, and Ishio, 1980 | 27 | Plain radiograph | None | Open | No | Not reported
Prospective Trials
Kleeman, Hiscoe, and Berg, 2000 | 54 | MRI/CT | None | Investigator only | Yes | Yes
Weiner, Walker, Brower et al., 1999 | 30 | MRI/CT | None | Investigator only | Yes | Yes
diPierro, Helm, Shaffrey et al., 1996 | 35 | X-ray Myelography and CT | None | Investigator only | Yes | Not reported
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 65 | Plain radiograph and X-ray Myelography | None | Open | Yes | Adequate trial
Matsui, Kanamori, Ishihara et al., 1997 | 27 | Plain radiograph, X-ray Myelography, and CT | None | Open | No | Not reported
Airaksinen, Herno, Turunen et al., 1997 | 497 | X-ray Myelography and CT | None | Double | Yes | Not reported
Mullin, Rea, Irsik et al., 1996 | 72 | Plain radiograph | None | Investigator only | Yes | Not reported
Ishac, Alhayek, Fournier et al., 1996 | 34 | X-ray Myelography and CT | None | Open | No | Not reported
Jonsson and Stromqvist, 1994 | 43 | Plain radiograph, X-ray Myelography, CT, and MRI | None | Investigator only | Yes | Not reported
Caputy and Luessenhop, 1992 | 100 | X-ray Myelography | None | Investigator only | Yes | 1 month to 12 years
Dhar and Porter, 1992 | 36 | Plain radiograph and CT | None | Open | No | Not reported
Chahal, Mundkur, Sancheti et al., 1982 | 32 | Plain radiograph and X-ray Myelography | None | Open | No | Some months
Rosomoff, 1981 | 50 | Plain radiograph, and X-ray Myelography | None | Open | No | Not reported
Getty, 1980 | 35 | Plain radiograph and X-ray MyelographyI | None | Open | Yes | Some period of conservative treatment
Reale, Deifini, Gambacona et al., 1978 | 37 | X-ray Myelography | None | Open | Yes | Not reported
Verbiest, 1977 | 116 | X-ray Myelography | None | Open | Yes | Not reported
Case-series
Young, Veerapen, and O'Laoire, 1988 | 32 | X-ray Myelography and CT | None | Open | No | Not reported
Kurihara, Tanaka, Tsumura et al., 1988 | 12 | Plain radiograph | None | Open | No | Not reported
Hall, Bartleson, Onofrio et al., 1985 | 68 | X-ray Myelography and CT | None | Open | Yes | Not reported
Weinstein, Scafuri, and McNeill, 1983 | 24 | Plain radiograph, X-ray Myelography, and CT | None | Investigator only | No | Not reported
Weir and De Leo, 1981 | 81 | X-ray Myelography and CT | None | Open | No | Not reported
Johnsson, Willner, and Pettersson, 1981 | 27 | Plain X-ray, X-ray Myelography, and CT | none | none | No | Not reported
Verbiest, 1979 | 11 | Plain radiograph | None | Open | No | Not reported
Salibi, 1976 | 20 | X-ray Myelography | None | Open | Yes | Not reported
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized controlled Trial
Lee and deBari, 1986 | 24 | Plain radiograph | No method reported | Open | No | Not reported
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 94 | Plain radiograph | None | Open | No | Not reported
Mikhael, Ciric, Tarkington et al., 1981 | 85 | Plain radiograph, X-ray Myelography, and CT | None | Open | No | Not reported
Retrospective Trials with Consecutive Patients
Sanderson and Getty, 1996 | 66 | Computerized Tomography CT | None | Investigator only | Yes | Not reported
Baba, Uchida, Maezawa et al., 1996 | 31 | Plain radiograph, CT, and MRI | None | Investigator only | No | Not reported
Aryanpur and Ducker, 1990 | 32 | MRI/CT | None | Open | No | Not reported
Case-series
Choudhury and Taylor, 1977 | 28 | X-ray Myelography | None | Open | No | Not reported
Epstein, Epstein, Rosenthal et al., 1972 | 15 | X-ray Myelography | None | Open | No | Not reported
Trials Examining Surgical Patients with Centralor Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Controlled Trial
Yone and Sakou, 1999 | 60 | X-ray Myelography, CT, and MRI | None. Patients with instability received fusion or not by their own choice. | Open | No | Not reported
Epstein, 1999 | 21 | X-ray Myelography and CT | None | Open | No | Not reported
Javid and Hadar, 1998 | 170 | CT myelography scanning and/or MRI | None | Open | Yes | Not reported
Kalbarczyk, Lukes, and Seiler, 1998 | 148 | X-ray Myelography, CT, and MRI | None | Open | Yes | Not reported
Pai and Kumar, 1996 | 55 | Plain radiograph | None | Open | Yes | At least 3 months
Kawauchi, Yone, and Sakou, 1996 | 36 | X-ray Myelography and myeloscopy | none | none | No | Reported but no time period provided.
Cinotti, Postacchini, and Weinstein, 1994 | 50 | X-ray Myelography, CT, and MRI | None | Open | Yes | At least 3 months
Little and MacDonald, 1994 | 94 | | None | Open | No | Not reported
Jonsson and Stromqvist, 1993a | 39 | Plain radiograph, X-ray Myelography, CT, and MRI | None | Open | Yes | Not required
Nasca, 1989 | 114 | X-ray Myelography and CT | None | Open | No | Not reported
Nather and Thomas, 1985 | 34 | X-ray Myelography | None | Open | No | Not reported
Paine, 1976 | 143 | X-ray Myelography | None | Open | No | Not reported
Shenkin and Hash, 1976 | 49 | X-ray Myelography | None | Open | Yes | Not reported
Tile, McNeil, Zarins et al., 1976 | 26 | Plain radiograph | None | Investigator only | Yes | Not reported
Retrospective Trial with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 34 | Plain radiograph and MRI | None | Open | No | All patients failed to respond, not time reported
Simpson, Silveri, Balderston et al., 1993 | 57 | X-ray Myelography, CT, and MRI | None | Investigator only | Yes | Not reported
Silvers, Lewis, and Asch, 1993 | 248 | X-ray Myelography, CT, and MRI | None | Open | Yes | 1 month to several years
Katz, Lipson, Larson et al., 1991 | 88 | Plain radiograph, X-ray Myelography and CT | None | Investigator only | Yes | Not reported
Ganz, 1990 | 36 | X-ray Myelography | None | Open | Yes | Not reported
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 70 | | None | Open | No | Not reported
Guigui, Benoist, Delecourt et al., 1998 | 50 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Scholz, Firsching, and Lanksch, 1998 | 72 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Tsai, Yang, and Bray, 1998 | 62 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Mackay and Wheelwright, 1998 | 50 | X-ray Myelography, CT, and MRI | None | Open | Yes | Not reported
Whitecloud, Castro Jr, Brinker et al., 1998 | 35 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Spetzger, Bertalanffy, Reinges et al., 1997 | 29 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Katz, Lipson, Chang et al., 1996 | 88 | X-ray Myelography, CT, and MRI | None | Open | Yes | Not reported
Lehto and Honkanen, 1995 | 96 | X-ray Myelography and CT | None | Open | Yes | Not reported
Stucki, Liang, Fossel et al., 1995 | 230 | X-ray Myelography, CT, and MRI | None | Open | Yes | Not reported
Tuite, Stern, Doran et al., 1994 | 380 | MRI/CT | None | Open | No | Not reported
McCullen, Bernini, Bernstein et al., 1994 | 193 | X-ray Myelography and CT | None | Open | No | Not reported
Simmons and Simmons, 1992 | 40 | Plain radiograph | None | Open | Yes | Not reported
Mauersberger and Nietgen, 1989 | 92 | X-ray Myelography and CT | None | Open | Yes | Not reported
Johnsson, Redlund-Johnell, Uden et al., 1989 | 61 | X-ray Myelography | None | Open | No | Not reported
Brodsky, Hendricks, Khalil et al., 1989 | 36 | Computerized Tomography CT | None | Open | No | Not reported
Jalovaara, Lahde, Iikko et al., 1989 | 31 | X-ray Myelography and CT | none | none | No | Not reported
Fast, Robin, and Floman, 1985 | 19 | X-ray Myelography and CT | None | Open | No | Not reported
Boccanera, Pellicioni, and Laus, 1984 | 25 | X-ray Myelography and CT | None | Open | No | Not reported
Hood and Weigl, 1983 | 21 | X-ray Myelography | None | Open | Yes | Not reported
Scafuri and Weinstein, 1981 | 27 | X-ray Myelography and CT | None | Open | No | Not reported
Echeverria and Lockwood, 1979 | 35 | X-ray Myelography | None | Open | No | Not reported
Scapinelli, 1978 | 23 | X-ray Myelography | None | Open | No | Not reported
Vestad and Naca, 1977 | 80 | Plain radiograph | None | Open | No | Not reported
McKinley and Davis, 1976 | 32 | X-ray Myelography | None | Open | No | Not reported
Teng and Papatheodorou, 1963 | 29 | X-ray Myelography | None | Open | No | Not reported
Epstein, Epstein, and Lavine, 1962 | 29 | X-ray Myelography | None | Open | No | Not reported
Epstein, 1960 | 14 | X-ray Myelography | None | Open | No | Not reported
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trial
Fischgrund, Mackay, Herkowitz et al., 1997 | 75 | Plain radiograph, X-ray Myelography, CT, and MRI | Withdrawal of card from envelope performed by assistant not the treating physician. | Investigator only | Yes | At least 3 months
Thomsen, Christensen, Eiskjaer et al., 1997 | 41 | Plain radiograph, X-ray Myelography, CT, and MRI | 20 number per block randomization procedure with two surgical procedures concealed in two envelopes. | Double | Yes | Not reported
Bridwell, Sedgewick, O'Brien et al., 1993 | 43 | X-ray Myelography, CT, and MRI | Not described. | Double | No | Not reported
Herkowitz and Kurz, 1991 | 50 | Plain radiograph, X-ray Myelography, CT, and MRI | Assigned alternately | Open | Yes | Not reported
Controlled Trials
Plotz and Benini, 1998 | 106 | X-ray Myelography | None | Open | No | Not reported
Yuan, Garfin, Dickman et al., 1994 | 2684 | Plain radiograph | None | Open | Yes | Not reported
Satomi, Hirabayashi, Toyama et al., 1992 | 41 | Plain radiograph, X-ray Myelography, and CT | None | Open | No | Not reported
Lombardi, Wiltse, Reynolds et al., 1985 | 47 | X-ray Myelography and CT | None | Open | No | Not reported
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 23 | Plain radiograph | None | Open | Yes | Not reported
Rechtine, Sutterlin, Wood et al., 1996 | 18 | Plain radiograph | None | Investigator only | Yes | Not reported
Retrospective Trial with Consecutive Patients
Stambough, 1999 | 35 | Plain radiograph and CT | None | Investigator only | No | 6 weeks to 16 years
Nishizawa and Fujimura, 1997 | 58 | Plain radiograph, X-ray Myelography, and CT | None | Open | No | Not reported
Moller, Wittenberg, Nolte et al., 1992 | 37 | Plain radiograph, CT, and MRI | None | Open | Yes | At least 1 year
Marchesi, Thalgott, and Aebi, 1991 | 30 | Plain radiograph | None | Open | No | Not reported
Takahashi, Kitahara, Yamagata et al., 1990 | 39 | Plain radiograph, X-ray Myelography, and CT | None | Open | Yes | Not reported
Knox, Harvell, Nelson et al., 1989 | 39 | Plain radiograph and X-ray Myelography | None | Open | Yes | Not reported
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 49 | Plain radiograph | None | Open | No | Not reported
McCulloch, 1998 | 21 | MRI/CT | None | Open | No | Not reported
Epstein, 1998b | 28 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Mochida, Toh, Suzuki et al., 1997 | 10 | X-ray Myelography | none | Open | No | Not reported
Epstein, 1998a | 290 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Grob, Humke, and Dvorak, 1996 | 18 | X-ray Myelography and CT | None | Open | Yes | Not reported
Herron and Trippi, 1989 | 24 | X-ray Myelography and CT | None | Open | No | Not reported
Chang and McAfee, 1989 | 17 | X-ray Myelography | None | Open | No | Not reported
Inoue, Watanabe, Goto et al., 1988 | 36 | X-ray Myelography | None | Open | No | Not reported
Simmons and Capicotto, 1988 | 15 | X-ray Myelography and CT | Not Stated | Open | No | Not reported
Hanley, 1986 | 20 | X-ray Myelography and CT | None | Open | No | Not reported
Kaneda and Kazama, 1986 | 54 | X-ray Myelography and CT | None | Open | No | Not reported
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 50 | X-ray Myelography | None | Open | Yes | Not reported
Dall and Rowe, 1985 | 26 | X-ray Myelography and CT | None | Open | Yes | Not reported
Epstein, Epstein, Carras et al., 1983 | 60 | Plain radiograph, X-ray Myelography, and CT | None | Open | No | Not reported
Richardson and Brown, 1980 | 21 | Plain radiograph | None | Open | Yes | Not reported
Cauchoix, Benoist, and Chassaing, 1976 | 26 | X-ray Myelography | None | Open | No | Not reported
Epstein, Epstein, Lavine et al., 1976 | 20 | X-ray Myelography | None | Open | No | Not reported
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
Controlled Trial
Rompe, Eysel, Zollner et al., 1999 | 117 | X-ray Myelography, CT, and MRI | None | Open | Yes | Not reported
Katz, Lipson, Lew et al., 1997 | 272 | X-ray Myelography, CT, and MRI | None | Investigator only | Yes | Not reported
Sato and Kikuchi, 1997 | 81 | | None | None | No | Not reported
Rompe, Eysel, Hopf et al., 1995 | 60 | Computerized Tomography CT | None | Open | No | Not reported
Sanderson and Wood, 1993 | 34 | X-ray Myelography and CT | None | Open | Yes | Not reported
Postacchini, Cinotti, Perugia et al., 1993 | 70 | X-ray Myelography, CT, and MRI | Alternate assignment | Investigator only | Yes | Not reported
Robertson, Grobler, Novotny et al., 1993 | 33 | MRI/CT | None | Open | No | Not reported
Hirabayashi, Kumano, and Kuroki, 1991 | 53 | X-ray Myelography | None | Open | No | Not reported
Herkowitz and Garfin, 1989 | 99 | X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Prospective Trial
Jonsson, Annertz, Sjoberg et al., 1997a | 105 | X-ray Myelography, CT, and MRI | None | Investigator only radiologist only | Yes | Not reported
Postacchini and Conotti, 1992 | 88 | Plain X-ray, CT, and MRI | None | Open | Yes | Not reported
Retrospective Trial with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 80 | X-ray Myelography | None | Investigator only | Yes | Not reported
Postacchini, Cinotti, Gumina et al., 1993 | 64 | Plain X-ray, CT, and MRI | None | Open | No | Not reported
Case-series
Guigui, Barre, Benoist et al., 1999 | 28 | Plain radiograph and CT | None | Investigator only | Yes | Not reported
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 55 | CT and MRI | None | Open | Yes | At least 6 weeks
Mariconda, Zanforlino, Celestino et al., 2000 | 37 | Plain X-ray, CT, and MRI | None | Investigator only | Yes | Not reported
Johnsson, Uden, and Rosen, 1991 | 76 | X-ray Myelography | None | Open | Yes | Not reported
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen, Weber, Nordal et al., 2000 | 100 | Plain radiograph, X-ray Myelography, and CT | Block randomization using tables of random numbers | Open | Yes | No
Hurri, Slatis, Soini et al., 1998 | 134 | X-ray Myelography | None | Investigator only | Yes | Not reported
Atlas, Deyo, Keller et al., 1996 | 148 | | None | Open | Yes | At least 2 weeks
Atlas, Keller, Robson et al., 2000 | 119 | Four year followup to Atlas, Deyo, Keller et al., 1996
Swezey, 1996 | 47 | MRI/CT | None | Open | Yes | Not reported
Nagler and Bodack, 1993 | 100 | Computerized Tomography CT | None | Open | Yes | Not reported
Herno, Airaksinen, Saari et al., 1996 | 57 | X-ray Myelography | None | Investigator only | Yes | Not reported
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 43 | Plain radiograph | None | Open | No | Not reported
Rosenberg, 1976 | 200 | Plain radiograph | None | Open | No | Not reported
Trials Describing Only the Natural History of Lumbar Spinal Stenosis Patients
Patients with Central Lumbar Stenosis
Hamdan and Al-Kaissie, 1994 | 75 | Plan X-ray and X-ray Myelography | None | Open | No | Reported but no time period was given
Patients with Lateral Lumbar Stenosis
Jonsson and Stromqvist, 1993b | 100 | Plain radiograph, X-ray Myelography, CT, and MRI | None | Open | No | Not reported
Patients with Degenerative Spondylolisthesis
Matsunaga, Sakou, Morizono et al., 1990 | 40 | Plain radiograph | None | Open | No | Not required
Sato, Wakamatsu, Yoshizumi et al., 1989 | 355 | Plain X-ray and Computerized Tomography CT | None | Open | No | Not reported
Patients with Lumbar Stenosis and Spondylolisthesis
Radu and Menkes, 1998 | 62 | Plain radiograph, CT, and MRI | None | Open | No | Not required
Amundsen, Weber, Lilleas et al., 1995 | 100 | Plain radiograph, X-ray Myelography, and CT | None | Investigator only | No | Not reported
Johnsson, Uden, and Rosen, 1992 | 32 | X-ray Myelography | None | None | Yes | Not required

Evidence Table 8. Inclusion and Exclusion Criteria and Comments on Study Design for Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized controlled Trials of Patients Receiving Conservative Treatments
First Author and Year of Publication | Number of Patients in the Trial | Inclusion Criteria | Exclusion Criteria | Comments
Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 53 | Lumbar spinal stenosis with pseudoclaudication | Vascular claudication
Eskola, Pohjolainen, Alaranta et al., 1992 | 39 | Back pain and pain radiating to the lower extremities, inability to walk more than 1500 meters on a treadmill.Sagittal diameter of lumbar spinal canal <10mm. | Vascular claudication. Patients receiving hormones, cardiovascular or hypertensive medication. | Trial originally included 40 patients.One was given the wrong dose of calcitonin at the beginning of treatment, and was excluded. Study has poor design. 2-month washout period was insufficient. Patient scores had not reverted to baseline.
Cuckler, Bernini, Wiesel et al., 1985 | 37 | Neurogenic claudication, relieved by change in posture. Unrelieved by 2 weeks of bed rest and NSAIDS. Findings on tomography epidural veinography or myelography consistent with symptoms. | Evidence of compression of cauda equina or a progressive neural deficit. Patients with prior lumbar surgery excluded unless symptoms clearly different from pre-surgery and there was a 6-month symptom-free period. | Many 7-14 of 17 patients in the placebo group actually received treatment. Numbers are inconsistently reported.
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 48 | Nonsurgical patients with nontraumatic back pain and lumbar spondylolisthesis. | None Stated | 3-month data is the same as Gramse, Sinaki, and Ilstrup, 1980 not in database, except for dropouts. No indication of whether all patients were reviewed, or just selected ones. Patient pain ratings were significantly different at baseline between groups.
Trials Examining Surgical Patients with Central Lumbar Stenosis
Randomized controlled Trial
Grob, Humke, and Dvorak, 1995 | 45 | Degenerative spinal stenosis on the basis of history and clinical examination as well as CT scans after myelography or MRI. | Patients with obvious lumbar spine instability diagnosed on the basis of slip of a vertebrae more than 5 mm, spondylolysis with an osseous defect of the pars interarticularis, or previous operation on the lumbar spine. | Pain was measured but the location, back or leg, was not defined. The pain data was entered in the Back Pain Table. The levels of surgery were presented for the entire group of patients 5 single, 30 at two levels, and 10 at three levels.
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 92 | Preoperative diagnosis of lumbar spinal stenosis based on the patient's symptoms and signs leg pain, limited walking, neural deficits and confirmed by CT or myelography. Patients with no previous back surgery and had pre and post operative CT scans. | None reported. | Patients were divided post surgically into Stenosis and No Stenosis patients based on CT.
Herno, Partanen, Talaslahti et al., 1999 | 80 | Patients treated surgically for lumbar spinal stenosis for the first time during the period 1982-1984 at Kuopio Hospital in Finland. | None reported | 80 patients were operated on from 1982-1984, but only 56 patients were available for followup ten years later.These 56 patients were divided into Stenosis and No Stenosis groups based on an MRI evaluation at the 10 year followup.
Hanakita, Suwa, and MIzuno, 1999 | 164 | Patients with lumbar canal stenosis surgically treated at the Department of Neurosurgery, Shizuoka General Hospital between 1990 and 1998. Patients received laminectomy plus fusion if the slip distance was over 10 mm or the slip angle was over 15 degrees. | None reported. | Too few patients older than 64 were included in the partial hemilaminectomy and laminectomy plus fusion groups to be extracted into the database. No preoperative patient information, including average ages, were reported.The age range was 19 to 84 years.76% of patients responded to the followup questionnaire, but dropouts are not reported for each patient group.The mean followup time for each patient group is not reported. The followup time could be anywhere from 1 to 8 years.
Thomas, Rea, Pikul et al., 1997 | 38 | Diagnosed as having acquired lumbar spinal stenosis and subsequently underwent surgery between 1990 and 1993. | Significant degenerative spondylolisthesis requiring stabilization using pedicle or facet screws, underwent simultaneous lumbar discectomies, previous surgery for stenosis, prisoners, or history of schizophrenia. | This is a retrospective trial comparing two surgical approaches. Of 38 potential patients, 12 were not able to enter the study 3 dead, 7 distance or health problems, 2 not located.
Yone, Sakou, Kawauchi et al., 1996 | 34 | Patients 60 years or older at time of surgery for lumbar spinal stenosis and were followed for more than 2 years. | Patients who had undergone multiple lumbar operations and those with spondylolysis or spondylolytic spondylolisthesis. | The study had three groups of patients based on preoperative instability and the type of surgery performed.The fusion group contained 10 patients, the nonfusion instability group had 7 patients, and the nonfusion noninstability group had 17 patients.
Ray, 1982 | 65 | Patients in which the "wedge" procedures had been performed. | None reported.
Surin, Hedelin, and Smith, 1982 | 22 | Patients operated on for lumbar spinal stenosis who were available for followup 22 of 33 patients; one patients died prior to followup. | Patients with previous lumbar spine surgery and spondylitic isthmic spondylolisthesis | Patients were group by degree of stenosis; Group 1: Marked AP diameter < or =10 mm, Group 2: AP diameter 11-14 mm. The number of surgical levels was not stratified by patient group: single level n=4, 2 levels n=12, more than 2 levels n=6.
Tajima, Fukazawa, and Ishio, 1980 | 27 | Patients who had been surgically operated for lumbar disease at the Department of Orthopaedic Surgery of the Nagasaki Mitsubishi Hospital. | Patients with tumors, inflammatory diseases, and traumas. | Average age was estimated from data in a histogram.Patient data are part of a larger study examining the ligamentum flavum and spinal canal stenosis.Only immediate post-op results at approximately 3 months were reported.
Prospective Trials
Kleeman, Hiscoe, and Berg, 2000 | 54 | Each patient had 1 neurogenic claudication as defined by leg pain limiting standing, ambulation, or both; 2 a history of exercise intolerance; 3 MRI or CT confirmation of compressive central stenosis with or without lateral recess stenosis; 4 failure of conservative therapy after an adequate trial. | Patients with 1 previous spinal surgery at the same level; 2 isthmic spondylolisthesis; 3 congenital spinal stenosis caused by short pedicles; and 4 an active workers' compensation claim or other litigation. | Prospective evaluation of the outcome of a decompressive procedure for lumbar spinal stenosis designed to preserve spinal stability. Procedure classified in the data base as a partial laminectomy. These patients could be considered severe based on their symptoms.
Weiner, Walker, Brower et al., 1999 | 30 | Symptoms of neurogenic claudication referable to the lumbar spine brought on by walking or standing, relieved by sitting or flexing in the absence of vascular or neuropathic pathology.Failure of a minimum of 3 months of conservative treatment. MRI demonstrating neurological compression by hypertrophied ligamentum flavum, osteophytic facet joints, and annular bulging. Absence of associated pathology such as congenital stenosis, disc herniation, or spondylolisthesis. | None specified | This study describes a microdecompression technique categorized in the database as a partial laminectomy.
diPierro, Helm, Shaffrey et al., 1996 | 35 | Symptomatic lumbar spinal stenosis, complained of low-back pain in addition to neurogenic claudication and/or radicular pain.None had obtained relief from conservative therapy. | None reported
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 65 | Patients older than 75 years of age who underwent surgery for lumbar spinal stenosis secondary to spondylolisthesis at Norton Hospital in Louisville from November 1990 to May 1996. | None reported | All patients were older than 75 years.50 of 65 cases of decompression with fusion, 15 decompression only.
Matsui, Kanamori, Ishihara et al., 1997 | 27 | Patients with degenerative lumbar stenosis who received expansive laminoplasty at the University Hospital between 1984 and 1995. | Patients whose age at operation was over 70 and patients with less than 2 years followup time.
Airaksinen, Herno, Turunen et al., 1997 | 497 | Patients that under went surgery for lumbar spinal stenosis between 1974 and 1987 at Kuopio University Hospital. | None Reported | 14 patients had developmental stenosis and 115 patients had a combination of developmental and degenerative stenosis.Extent of disease based on AP diameter of spinal canal.
Mullin, Rea, Irsik et al., 1996 | 72 | Patients who had undergone decompressive lumbar laminectomy with medial facetectomy for lumbar spinal stenosis between 1986 and 1990. | None reported | 72 patients could have entered the study, but losses due to death, medical reasons, and lost to followup prevented all but 37 from returning. Of these 37, 13 patients were excluded for undergoing a fusion at the time of the operation or subsequently. This left 24 in the study.
Ishac, Alhayek, Fournier et al., 1996 | 34 | Patients 80 years or older who underwent surgery for spinal stenosis between 1979 and 1994. | Patients less than 80 years old. | All patients were 80 years or older.
Jonsson and Stromqvist, 1994 | 43 | Patients older than 70 years who underwent decompressive surgery for central lumbar stenosis. | None
Caputy and Luessenhop, 1992 | 100 | Patients who underwent surgery for symptoms of degenerative lumbar spinal stenosis at Georgetown University Hospital from 1980-1985. | None reported
Dhar and Porter, 1992 | 36 | Patients who had spinal surgery between January 1980 and December 1984 at Doncaster Royal Infirmary. | None reported. | Very little patient information. Only patients reported as poor were examined in depth.
Chahal, Mundkur, Sancheti et al., 1982 | 32 | Patients presented with low back pain, were diagnosed and operated on for lumbar canal stenosis. | None reported
Rosomoff, 1981 | 50 | A series of 50 patients with continuing observation since the inception of the study in 1972 using neural arch resection. | None reported
Getty, 1980 | 35 | Surgically treated for lumbar spinal stenosis at the Norfolk and Norwich Hospital between 1968 and 1978 | None reported | Mean age of onset of symptoms was 52 years which included 3 young patients 10-30 year.
Reale, Deifini, Gambacona et al., 1978 | 37 | Patients who have undergone surgery for congenital stenosis of the lumbar spinal canal. | Spondylolisthesis, root cyst, and iatrogenic stenosis of the canal were excluded because there were too few cases. | Part of a larger study comparing spinal stenosis patients to spondylosis patients and disk herniation patients.
Verbiest, 1977 | 116 | Patients operated on for developmental lumbar spinal stenosis between 1948 and 1975 and in whom the mid-sagittal diameters of the whole area of stenosis was measured. | Patients with less than 1 year followup. | This study failed to give the mean age of patients, only the youngest and oldest. Other details on patient characteristics are also missing.The study is not clearly reported.
Case-series
Young, Veerapen, and O'Laoire, 1988 | 32 | Lumbar canal stenosis | Not Stated
Kurihara, Tanaka, Tsumura et al., 1988 | 12 | Hyperostotic lumbar spinal stenosis | Not Stated
Hall, Bartleson, Onofrio et al., 1985 | 68 | Myelographic demonstration of total or subtotal obstruction to the passage of contrast medium in the lumbar spine | Previous lumbar surgery, tumor, abscess, predominant disk protrusion or extrusion as a cause of symptoms.
Weinstein, Scafuri, and McNeill, 1983 | 24 | Only the spinal stenosis patients who had surgical decompression, had more than 1 year since surgical treatment, and were willing to return for reexamination by a second examiner. | Not reported.
Weir and De Leo, 1981 | 81 | Clinical-radiological diagnosis of lumbar stenosis | None reported
Johnsson, Willner, and Pettersson, 1981 | 27 | Patients who underwent laminectomies and extensive facetectomies | None reported
Verbiest, 1979 | 11 | Not Stated | None reported | Patients had spondylolytic, isthmic and congenital spondylolisthesis. Most had spina bifida.
Salibi, 1976 | 20 | Not Stated | Patients with herniated disks and no evidence of stenosis were excluded from analysis. | Six patients had disk herniation requiring disk removal as well as stenosis. 16 patients received wide bilateral laminectomy while 3 others received unilateral laminectomy. One patient refused surgery. No followup period is reported.
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized controlled Trial
Lee and deBari, 1986 | 24 | Diagnosis of multiple level foraminal stenosis | Not reported | Separate patient characteristics by treatment groups are not reported.
Controlled
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 94 | Patients who had 1 isolated lateral stenosis 2 lateral stenosis with disk herniation 3 lateral and central stenosis and 4 lateral and central stenosis with disk herniation. Only patients who did not respond to conservative therapy were operated on. | Spondylolisthesis or had undergone a previous spinal surgery.
Mikhael, Ciric, Tarkington et al., 1981 | 85 | Patients with lateral recess stenosis.Asymptomatic patients are not described. | None reported | 50 symptomatic patients are not described. Very little patient data on lateral recess stenosis patients are reported.The only patient described as poor was diabetic and had multiple prior laminectomies. Mean age and duration are presented for all patients.
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 66 | Patients undergoing partial undercutting facetectomy for lumbar lateral recess stenosis between 1982 and 1988 at Northern General Hospital, Sheffield, England. | None reported.
Baba, Uchida, Maezawa et al., 1996 | 31 | Patients who had undergone microsurgical nerve root canal widening for lumbosacral foraminal stenosis with a minimum of 1 year followup. | Patients presenting with symptomatic spondylolysis and isthmic or degenerative spondylolisthesis showing osteocartilaginous nerve root compression with the neural foramen were excluded.
Aryanpur and Ducker, 1990 | 32 | Those patients with radiographic evidence of multilevel lateral canal stenosis that correlated with their symptoms and who lacked a significant central of pan-stenosis were considered appropriate candidates for multilevel decompressive laminotomies. | History of previous spinal surgery
Case-series
Choudhury and Taylor, 1977 | 28 | Lateral lumbar stenosis. Diagnostic guidelines were given, but these were not inclusion criteria. | Overt Central stenosis.
Epstein, Epstein, Rosenthal et al., 1972 | 15 | Sciatic pain with no surgical evidence of herniated disk. | Not Stated | Final diagnosis was made when exploratory surgery could find no disk herniations.
Trials Examining Surgical Patients with Centralor Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Controlled Trial
Yone and Sakou, 1999 | 60 | Lumbar spinal stenosis. Classification as stable/unstable by Posner scale. | Patients who had undergone multiple lumbar operations and those with spondylolysis or spondylolytic spondylolisthesis were excluded. | This study compares outcomes among patients with instability who got fusion with those who didn't. Also reports on patients without instability who just received decompression.
Epstein, 1999 | 21 | Ossification of the Yellow Ligament or the Posterior Longitudinal Ligament with vertebral canal intrusion. | Not Stated | One patient in each group was excluded from analysis because of thoracic stenosis.Data for followup time includes these patients. Outcomes, Age and Sex data do no include these patients.
Javid and Hadar, 1998 | 170 | All patients from January 1984 who underwent decompressive laminectomy for stenosis confirmed by CT and/or MRI. | Patients who had undergone previous surgery for stenosis were excluded. | 3 patient groups: Central Stenosis, Central Stenosis and Herniated Disk, Lateral Stenosis. Dropouts were reported for the entire group at the long-term followup: 10 patients died of unrelated diseases, and 14 patients were lost to followup.
Kalbarczyk, Lukes, and Seiler, 1998 | 148 | Over age 70 | Patients undergoing simultaneous removal of a herniated disk were excluded. | Three different operations, depending on symptoms.Outcomes were reported separately.Patient characteristics are present for the entire group of patients. Average number of vertebral levels receiving surgery was 1.78.
Pai and Kumar, 1996 | 55 | Claudication pain which caused significant functional disability, not relieved by conservative treatment, progressive neurological deficit, and cauda equina syndrome. | Not Stated | Sex distribution 44 Men and 9 Women and age ranges 20-68 were reported only for combined groups. First followup was by examine, later followup by questionnaire.Two patients were lost to followup at 1st followup, 7 more at 2nd followup.
Kawauchi, Yone, and Sakou, 1996 | 36 | Patients with LSS whose symptoms had not been improved by conservative treatment | None reported | Patients were grouped according to degree of adhesive arachnoiditis of the cauda equina slight, moderate, marked.Patient diagnosis: degeneration LSS n=17 [10 with spondylolisthesis], combined type LSS n=15, and 4 with post-traumatic causes.
Cinotti, Postacchini, and Weinstein, 1994 | 50 | Clinical symptoms of lumbar stenosis not improved by conservative treatment for more than 3 months with imaging evidence of a central or lateral stenosis. | Patients with diabetes type 1 or 2 were excluded if not requiring insulin or oral medication which started at least 3 years before the surgery. | Nondiabetic patients compared to diabetic patients.
Little and MacDonald, 1994 | 94 | Patients who completed the Oswestry Low Back Pain Questionnaire both pre and post surgery. | Patients were excluded if a pre and post disability index was not recorded. | Part of a larger series of back surgery patients who had filled out the Oswestry Low Back Pain Questionnaire.Central and lateral stenosis patients were reported to have had decompressive laminectomy and fusion but the numbers in the tables do not match for diagnosis groups and surgery groups.Mean age is for the larger group.Very little information on patient characteristics is reported.
Simpson, Silveri, Balderston et al., 1993 | 57 | Preoperative diagnosis of diabetes mellitus and spinal stenosis. All patients had failed to improved adequately after nonoperative management. | Workers' Compensation or involved in litigation. | This is a retrospective study comparing patients with diabetes and spinal stenosis with age and sex matched nondiabetic patients with spinal stenosis. Herniated disk patients were reported separately except for mean ages and range.
Jonsson and Stromqvist, 1993a | 39 | Patients had at least one previous lumbar spinal surgery and underwent a second operation for persistence or recurrence of back and leg pain. | None reported. | Trial was specifically designed to examine patients with recurrence of back and leg pain after at least one previous lumbar spinal operation. Patient characteristics are reported for a combined previous disk and stenosis surgery patients.
Nasca, 1989 | 114 | Patients surgically treated for lumbar spinal stenosis. | Not Stated
Nather and Thomas, 1985 | 34 | Must have signs of stenosis at surgery and have either clinical or radiological features of stenosis. | Not Stated | Several diagnoses and several treatments.Outcomes are reported separately by diagnosis. Complications and ability to work are reported for entire patient group. Only two diagnoses had sufficient number of patients to include in the database.
Paine, 1976 | 143 | Not Stated | Not Stated | One patient died from complications of surgery, but the inclusion of this patientin one of the categories included in this analysis is not know.
Shenkin and Hash, 1976 | 49 | Spinal stenosis patients incapacitated with intractable pain and had not responded to other therapeutic measures. | Patients with soft disk herniations in addition to spondylosis were excluded. | Patients were divided according to prior surgery or no prior surgery. The 21 patients with prior surgery had been operated on for herniated disks.
Tile, McNeil, Zarins et al., 1976 | 26 | Spinal stenosis cases from St. Joseph Hospital in Toronto, Canada. | None reported. | Some surgical patients may have received fusion as well as standard wide laminectomy but results were reported as similar.No separate patients characteristics were reported for the stenosis surgery group.
Retrospective Trial with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 34 | Patients with congenital or advanced degenerative central and lateral lumbar stenosis in which 3 or more inter-laminal spaces were decompressed. Patients had a combined central and lateral stenosis and bilateral foraminal and nerve root canal decompressions. | Not reported | This is a special group of patients in which 3 or more inter-laminal spaces were decompressed.
Silvers, Lewis, and Asch, 1993 | 248 | All patients received conservative therapy prior to surgery but had inconsistent responses. Lumbar myelography correlated with the clinical finding of neurogenic claudication and failure to respond to conservative therapy resulted in a recommendation for laminectomy. | None reported. | Long-term followup had 120 dropouts from 244 patients in the short-term followup. 26 patients were involved in worker's compensation claims.
Katz, Lipson, Larson et al., 1991 | 88 | Patients 55 and over who had a laminectomy with or without fusion for degenerative lumbar stenosis at Brigham and Women's' Hospital between 1983 and 1986. | Patients with prior laminectomy or spinal arthrodesis of both were excluded. | 22 patients had degenerative spondylolisthesis with at least 5 mm of forward slip.
Ganz, 1990 | 36 | Patients who underwent surgery for lumbar spinal stenosis between January 1981 and December 1986. Selection criteria for surgery included a marked clinical disturbance and a myelogram showing the changes of spinal stenosis. | None reported | 29 patients had standard wide laminectomy, 3 patients had hemilaminectomy with disk removal, and 1 had unilateral hemilaminectomy.The group is recorded in the database as standard wide laminectomy.
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 70 | Chronic at least 6 months lumbar stenosis.Multilevel lumbar decompression, instrumentation and fusion. | Stenosis from acute fractures, infectious processes or neoplastic disease. | This study is primarily concerned with somatosensory evoked potential recordings.
Guigui, Benoist, Delecourt et al., 1998 | 50 | Consecutive patients operated on for lumbar spinal stenosis with severe motor deficit. | Not Stated | Various types of stenosis, treated with various types of surgery. Outcomes not separately reported.
Scholz, Firsching, and Lanksch, 1998 | 72 | Neuroradiological and intraoperative findings suggested stenosis | Not Stated | Followup was provided by examination 2.5 years after surgery, and by mailed questionnaire at 8 years. 25 patients were lost to followup at 8 years.
Tsai, Yang, and Bray, 1998 | 62 | Symptomatic degeneration. LS, include. Patients with mild deformity w/o gross instability degenerative scoliosis of <20deg., grade 1 spondylolisthesis w/o segmental instability, i.e., <4mm translation or <11deg. Angulation on flex./extension. | Prior back surgery, pure disk protrusion, cauda equina syndrome, congenital or developmental stenosis, Paget's disease, achondroplasia, total block on myelogram, <100mm^2 of canal area, scoliosis>20deg., grade 2 or + stenosis, segmental instability. | Data is provided only for the 50 patients not lost to followup.
Mackay and Wheelwright, 1998 | 50 | All patients presented with symptoms and signs consistent with nerve root entrapment. CT, MRI or myelogram was obtained to confirm the diagnosis. | Not Stated
Whitecloud, Castro Jr, Brinker et al., 1998 | 35 | Degenerative Conditions of the Lumbar Spine | Not Stated
Spetzger, Bertalanffy, Reinges et al., 1997 | 29 | Patients with symptomatic lumbar spinal stenosis who were operated on by a unilateral and bilateral decompression. | Not Stated | Two patients received discectomy as well as decompressive laminotomy. All patients were examined at discharge and at 8-10 weeks. Final evaluation was by telephone at 6 to 26 months, mean 18 months.
Katz, Lipson, Chang et al., 1996 | 88 | Clinical and radiographic evidence of degenerative lumbar spinal stenosis, underwent decompressive laminotomy with or without arthrodesis from 1983-1986, were older than 55 at time of surgery, had no prior surgery for lumbar spinal stenosis. | Not stated | No useful pretreatment data.
Lehto and Honkanen, 1995 | 96 | Symptomatic Lumbar Spinal Stenosis. | Not Stated | Mixed diagnoses, mixed surgeries, all reported together.
Stucki, Liang, Fossel et al., 1995 | 230 | Age>50years, pain in the low back, buttock and lower extremity exacerbated by lumbar extension, and evidence of central or central-lateral compression of the cauda equina by a degenerative lesion of the facet joint, disk, or ligamentum flavum. | Patients unable to complete questionnaires because of cognitive or language difficulties were excluded.
Tuite, Stern, Doran et al., 1994 | 380 | Patients who underwent decompressive lumbar laminectomy in Washentaw county, MI between July 1983 and July, 1990.Must have a radiographically confirmed diagnosis of lumbar spinal stenosis. | Incomplete documentation, previous lumbar surgery, interlaminar decompression, total facetectomy, fusion, or instrumentation. Patients excluded for incomplete documentation would be more properly considered lost to followup. | An unknown and possibly large number of patients were excluded because they did not have sufficient pretreatment data.These patients should be marked lost to followup greater than 75%. Provides data as percentages which, due to rounding, do not account for all patients in each group. Patients which form a sub-group of 119 are presented in the database.
McCullen, Bernini, Bernstein et al., 1994 | 193 | Patient received decompressive surgery for stenosis after cons. Treatment Failed, imaging shows compression consistent with symptoms. | Pending litigation, Pending workers' comp. Claims, infection, tumor previous spine surgery, dementia, stroke, requiring complete facetectomy. | Combined various etiologies and various surgeries.Some data on prognostic factors is reported.
Simmons and Simmons, 1992 | 40 | Patients having a significant lumbar scoliosis associated with spinal stenosis with symptoms of neurogenic claudication and having been treated with posterior decompression and pedicular screw fixation. | None reported
Mauersberger and Nietgen, 1989 | 92 | Lumbar stenosis | Not stated | Mixed diagnoses, mixed treatments, and sparse descriptions. 49% of patients did not receive conservative treatment prior to surgery.
Johnsson, Redlund-Johnell, Uden et al., 1989 | 61 | Patients operated on for lumbar spinal stenosis. | Patients with an AP diameter of the dural sack of more than 11cm and patients with impaired circulation in the legs.
Brodsky, Hendricks, Khalil et al., 1989 | 36 | Not Stated | Not Stated | Almost no information is provided.
Jalovaara, Lahde, Iikko et al., 1989 | 31 | Myelographic demonstration of total or subtotal obstruction s to the passage of the contrast medium in the lumbar spinal canal. | Patients with spondylolytic spondylolisthesis, prior lumbar surgery, tumor, infection, and lumbar disk herniation | Two patients had prior intervention lumbar sympathectomy. Degree of stenosis was measured by myelography as the midsagittal diameter at the most constricted level. Number of surgical levels involved: single level n=11, 2 levels n=7, more than 2 levels n=13.
Fast, Robin, and Floman, 1985 | 19 | Patients with spinal stenosis who were "found suitable for surgery". | Not Stated, but 41 patients apparently were found unsuitable for surgery.
Boccanera, Pellicioni, and Laus, 1984 | 25 | Lumbar stenosis, including developmental, degenerative and mixed. | Spondylolisthesis
Hood and Weigl, 1983 | 21 | Patients over age 50 with lumbar spinal stenosis requiring surgery. | Not Stated
Scafuri and Weinstein, 1981 | 27 | Lumbar spinal stenosis | None reported.
Echeverria and Lockwood, 1979 | 35 | Patients with lumbar stenosis operated on between 1966 and 1976. | Not Stated | Two patients categorized as having "miscellaneous" stenosis were excluded by us because 1 had stenosis due to giant-cell tumor. Another 5 were excluded because they may have had herniated disks. This is in addition to the 8 patients already lost to followup.
Scapinelli, 1978 | 23 | Patients with lumbar spinal stenosis. | Patients found to have disk protrusions at operation. | Patient information is given for all 42 patients with stenosis. Only 23 had surgery.Etiology of stenosis varied, but treatment was the same.
Vestad and Naca, 1977 | 80 | Spondylolisthesis | Not Stated | Includes multiple etiologies, some patients were fused while others were not.
McKinley and Davis, 1976 | 32 | Narrow Lumbar Spinal Canal or Lumbar Spinal Stenosis. | Not Stated | Poor study with a large dropout rate 44%.Only 18 of 32 Patients followed up.No useful outcome measures were reported.
Teng and Papatheodorou, 1963 | 29 | Lumbar spondylosis with Compression of Cauda Equina | Not Stated | One patient had discectomy and laminotomy.28 had laminectomy.
Epstein, Epstein, and Lavine, 1962 | 29 | Symptoms of nerve root compression causally related to narrowing of the lumbar spinal canal. | Not Stated | Different patients received different surgery: Interlaminar laminotomy, Complete hemilaminectomy, Total laminectomy.
Epstein, 1960 | 14 | Spondylosis of the lumbar spine. | Not Stated
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trial
Fischgrund, Mackay, Herkowitz et al., 1997 | 75 | All patients had a clinical diagnosis of single-level degenerative spondylolisthesis and spinal stenosis. | Prior lumbar surgery.
Thomsen, Christensen, Eiskjaer et al., 1997 | 41 | All patients had lumbar or lumbosacral instability, defined by severe, chronic motion-induced back pain | Age less than 20 or greater than 70. Metabolic bone disease osteoporosis, comorbidity, and psychosocial instability. | The 41 patients with degenerative spondylolisthesis were part of a larger study of spondylolisthesis in 130 patients.Patient characteristics were only available for the larger group. Patients were excluded if over 70 years of age.Data on fusion levels were presented for the entire larger patient group.
Bridwell, Sedgewick, O'Brien et al., 1993 | 43 | Patients with primary surgery for spinal claudication caused by spinal stenosis at the level of the degenerative spondylolisthesis. | Prior surgery. | Patients with pathological motion were automatically randomized to fusion and instrumentation. Patient group 1, no fusion, has only 9 patients, but data was entered for completeness. Analysis can be performed between Group 2, fusion, and Group 3, fusion and instrumentation.
Herkowitz and Kurz, 1991 | 50 | Clinical diagnosis of degenerative spondylolisthesis and spinal stenosis, symptoms unresponsive to an adequate trial of nonoperative treatment, single level of Spondylolisthesis, imaging studies consisting of plain x-ry and either myelogram, CT, or MRI. | None reported
Controlled Trials
Plotz and Benini, 1998 | 106 | One or two vertebrae slipped forward at least 5% of their diameter. | Not Stated | Different numbers of patients age given for different outcomes. Patients who had 2nd surgery not included in analysis, except the global outcome, in which they were called "Worse". Most patient data given for combined groups only. Average slippage reported for all patients, 20%, range 12.5% to 44%.
Yuan, Garfin, Dickman et al., 1994 | 2684 | Any patient with a diagnosis of degenerative spondylolisthesis, no prior fusion or instrumentation surgery at the same level, and posterior fixation and fusion surgery. Patient must have radicular pain and/or neurogenic claudication. | Prior fusion attempts at the operative site, involvement of more than 2 levels, surgery involving anterior fixation. Dysplastic, Isthmic, or Pathological etiology. | Data on exact followup times are not presented.This is a large cohort study with patient data provided by 314 surgeons. Data was provided by each surgeon on a standardized questionnaire.
Satomi, Hirabayashi, Toyama et al., 1992 | 41 | Patients with degenerative spondylolisthesis who exhibited displacement greater than 5% by the Marique-Taillard method and were treated surgically. | None reported. | This study used the Japanese Orthopaedic Association JOA Questionnaire. Severity was based on Grades 1 no indention of dural sac, 2, and 3 complete block spondylolisthesis.
Lombardi, Wiltse, Reynolds et al., 1985 | 47 | Degenerative Spondylolisthesis treated conservatively for an adequate period. | Previous surgery, involvement in litigation, significant lesions at other spinal levels, inadequate followup. | One group of 6 patients was too small to be included.
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 23 | Patients with spondylolisthesis who had undergone posterior lumbar intervertebral fusion. | None reported
Rechtine, Sutterlin, Wood et al., 1996 | 18 | Patients with grade I or II degenerative spondylolisthesis treated with the ISF system and using 100% autogenous bone graft. Subluxation of one vertebra over another in the lateral radiographs, causing spinal stenosis or claudication and pain.Older than 17. | No slip noted on radiograph, a stable motion segment unit, and an asymptomatic condition.
Retrospective Trial with Consecutive Patients
Stambough, 1999 | 35 | Cases of lumbosacral transpedicular screw fixation between 1986 and 1994. All cases had conservative and/or nonoperative care including bed rest, limited activities, physiotherapy, nonsteroidal AI, muscle relaxants, narcotics, epidural steroids and other treatments. | None reported | Part of a larger group of patients who received decompression, fusion, and instrumentation for variousback disorders. Mean age is from the larger study.
Nishizawa and Fujimura, 1997 | 58 | Patients with degenerative spondylolisthesis who underwent anterior lumbar interbody fusion from 1982 through 1993 and who were followed a minimum of 2 years. | None reported | 48 of 58 patients received screws as well as fusion.
Moller, Wittenberg, Nolte et al., 1992 | 37 | Patients treated at the Department of Orthopedic Surgery, Ruhr University of Bochum for the treatment of degenerative lumbar spine diseases. Unsuccessful intensive conservative treatment for at least 1 year including local injections and physiotherapy and were trained in the back school. | Patients showing nerve root compression signs on EMG, evoked potentials, CT, or MRI were excluded. | Part of a larger study that included failed-back surgery and lumbar instability patients. Mean age is for the entire group of 147 patients.
Marchesi, Thalgott, and Aebi, 1991 | 30 | Patients treated with AO spinal internal fixation system for nontraumatic indications at the author's institutions. | None reported | Part of a larger study. Not all spondylolisthesis patients are degenerative.
Takahashi, Kitahara, Yamagata et al., 1990 | 39 | Patients with degenerative spondylolisthesis who underwent anterior interbody fusion. | None reported | CT was used in 22 patients.
Knox, Harvell, Nelson et al., 1989 | 39 | Included all patients treated with bilateral laminectomy, fusion, and Luque rectangle for degenerative spondylolisthesis from 1983 to 1988. Nonsteroidal antiinflammatory medication, corsetry, and physical therapy did not generally provide relief. | None reported | Patient's levels of satisfaction have 3 "improved" levels and 1 level for "same or not improved".
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 49 | Degenerative spondylolisthesis, No prior surgery, severe neurogenic claudication, treated similarly. | Not Stated | Reporting of back or leg pain not the pain scale was entered as Back Pain.
McCulloch, 1998 | 21 | Patients had leg pain dominant over back pain, failed conservative care, were <80 years old, in reasonable health, had single or 2 level microsurgical laminotomy with single level uninstrumented intertransverse fusion using soft tissue envelope technique | Not Stated | Measured back and leg pain on analog scale, but did not report results.
Epstein, 1998b | 28 | "Unstable" Degen. Spondylo.: More than 4mm of translation and >10-12 degrees of angulation at the level of olisthy. | Not Stated | These patients had "Unstable" degenerative spondylolisthesis.
Mochida, Toh, Suzuki et al., 1997 | 10 | Unstable lumbar spine | Patients with less than 2 years followup were excluded. | Patients with degenerative canal stenosis and herniated disks were also reported on, but did not have at least 10 patients/group. Another 4 patients were excluded for getting a different treatment.
Epstein, 1998a | 290 | Not Stated | Not Stated
Grob, Humke, and Dvorak, 1996 | 18 | Anterior slippage of at least 25% in the olisthetic segment and advanced stage of disk resorption with reduction of disk height by at least 75%. | Not described
Herron and Trippi, 1989 | 24 | Patients with L4-5 Degenerative Spondylolisthesis with slip of at least 4mm or 10%, Followup at least 18 months. | Death before 1-year followup, Compensation or litigation issues, prior surgery at L4-5 level.
Chang and McAfee, 1989 | 17 | Patients with degenerative spondylolisthesis or scoliosis with at least 1 year of followup. None had previous lumbar surgery, but it is not clear if this was a requirement. | Not Stated | Three of the patients had degenerative scoliosis, not spondylolisthesis and were not reported separately. Some patients may have been rejected because the followup was not long enough.
Inoue, Watanabe, Goto et al., 1988 | 36 | Degenerative spondylolisthesis | Not stated | Patients were given fusion, but no mention is made of decompression.
Simmons and Capicotto, 1988 | 15 | A select high-risk group of patients with a primary diagnosis of degenerative spondylolisthesis. | Not Stated | No useful treatment outcomes were measured.
Hanley, 1986 | 20 | Localized L4-5 degenerative spondylolisthesis treated with the same technique, having at least 2 years of followup. | Evidence of disk herniation. | An additional 19 patients were treated the same way for the same condition. These patients may have been lost to followup or they may have had less than the required 2 years of followup at the time of publication.
Kaneda and Kazama, 1986 | 54 | Degenerative unstable spondylolisthesis | Not Stated
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 50 | Intact Arch Spondylolisthesis | Not Stated | Outcomes are not reported for 5 patients because they were operated on within 4 months of publication.
Dall and Rowe, 1985 | 26 | Treated for degenerative Spondylolisthesis at Bronson and Borgess hospitals. | Not Stated
Epstein, Epstein, Carras et al., 1983 | 60 | Degenerative spondylolisthesis patients were selected after having shown no response to prolonged conservative care. | None reported. | Multiple decompression techniques were used over a 12 year period. Patients had no response to prolonged conservative care. Followup for 40 patients was 1-12 mo, and for 20 patients 13 mo to 7.5 years.
Richardson and Brown, 1980 | 21 | Patients who underwent decompression and fusion for spondylolisthesis between 1976 and 1979. | Nor reported | Poorly reported study. Does not provide patient ages except to say they were adults.
Cauchoix, Benoist, and Chassaing, 1976 | 26 | Degenerative Spondylolisthesis | Not Stated
Epstein, Epstein, Lavine et al., 1976 | 20 | Not Stated | Not Stated | Study did not provide outcomes of surgical treatment.
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
Controlled Trial
Rompe, Eysel, Zollner et al., 1999 | 117 | Age greater than or equal to 45; presence of back, buttock and/or leg pain; radiographic evidence of degenerative spinal stenosis; surgeon's opinion that the patient suffered from clinically significant degenerative lumbar spinal stenosis. | Previous lumbar spine surgery. | Patients were asked about pain and did not distinguish between back and leg separately. Pain scores are reported in the back pain outcomes table.
Katz, Lipson, Lew et al., 1997 | 272 | Age >49 and the presence of one of the following: 1 back, buttock and/or lower extremity pain; 2 radiographic evidence of compression of the cauda equina or exiting nerve roots by ligamentum flavum, facet joints, osteophytes, and/or disk material; and 3 the surgeon's judgment that patients had significant degenerative lumbar spinal stenosis. | Patients with previous back surgery for stenosis.Patients who could not answer questionnaires because of language or cognitive limitations were excluded. | Dropouts are reported for the entire study patient population and not for the three treatment groups. 310 consecutive patients were initially eligible, 38 refused and 272 entered the study. At 6 months 2 patients had died and 34 refused to continue; 236 patients completed 6 months. At 24 months 8 patients had died and 29 refused to continue; 199 patients continued. Within the treatment groups, the patients receiving fusion had significantly fewer levels decompressed and greater frequency of spondylolisthesis.
Sato and Kikuchi, 1997 | 81 | Consecutive patients with neurogenic intermittent claudication NIC induced by spinal canal stenosis due to spondylosis and degenerative spondylolisthesis of the L4 vertebra. | Not reported | Patient grouping based on number of levels involved; Group 1= 2-levels; Group 2 = 1-level; Preoperative patient were stratified by type of claudication: radicular n=7, Gp1; n=25, Gp2, caudal n=5, Gp1; n=9, Gp2, and mixed n=16, Gp1, n=19, Gp2
Rompe, Eysel, Hopf et al., 1995 | 60 | Degenerative stenosis of the central lumbar spinal canal. | Patients with previous lumbar surgery, vascular disease of the legs, or compensation issues. | Two diagnoses and 2 types of surgery.Patients were reported separately, grouped by diagnosis. Patients in either group may have received either treatment. Some outcomes were reported separately for the 2 surgeries.
Sanderson and Wood, 1993 | 34 | Patients aged 65 and over who received decompressive surgery for degenerative spinal stenosis at Wrightington Hospital between 1984 and 1989. | None reported | Reported central, lateral, and spondylolisthesis patients. Central and lateral patients were combined due to small sample size.
Robertson, Grobler, Novotny et al., 1993 | 33 | Undergoing spinal decompression without fusion for symptomatic spinal stenosis at L4-5. | None reported.
Postacchini, Cinotti, Perugia et al., 1993 | 70 | Patients with central lumbar stenosis requiring surgery. | None reported | Patients had one of four types of stenosis: developmental, degenerative, combined developmental and degenerative, degenerative spondylolisthesis. Patients were shifted from multiple laminotomy to total laminectomy for a would not allow adequate neural decompression, b risk of neural damage because of severe narrowing of the spinal canal, and c an inadequate bony bridge remained between laminotomies risking mobility of the residual laminae and spinous process.
Hirabayashi, Kumano, and Kuroki, 1991 | 53 | Patients who underwent surgery using the Cotrel-Dubousset pedicle screw system at Kantoh Rosai Hospital between August 1986 and November 1989. | None reported | Part of a larger study. Mean age and range are based on the larger study.
Herkowitz and Garfin, 1989 | 99 | Patients who had decompression for symptomatic and myelographically confirmed spinal stenosis. | Not Stated | Most of the patient information is for all groups, including those with scoliosis.
Prospective Trial
Jonsson, Annertz, Sjoberg et al., 1997a | 105 | Consecutive patients for surgical decompression for central lumbar spinal stenosis | None | Study reported mean anterior-posterior diameter of dural sac v. walking, v. stenosis/stenosis + spondylolisthesis. Study reported the number of levels with anterior-posterior diameter < or =10 mm.
Postacchini and Conotti, 1992 | 88 | Surgery for lumbar spinal stenosis at the Orthopaedic Clinic of La Sapienza University of Rome between 1972 and 1985. | None reported. | Development, degenerative, and combined stenosis patients were evaluated. 48 patients out of 88 were not available for followup. 16 patients had spondylolisthesis. Total laminectomy 32 patients and bilateral laminotomy 8 patients were combined. 10 patients were fused. 21 patients were not examined because they did not have an immediate postoperative radiograph.
Retrospective Trial with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 80 | Patients with lumbar spinal stenosis who underwent decompressive surgery at the Department of Orthopaedic Surgery, Fukui Medical School between 1983 and 1990. | Patients with diseases such as diffuse idiopathic skeletal hyperostosis. | Several forms of stenosis and several surgical treatments. 15 degenerative stenosis, 13 combined degenerative and developmental stenosis, 14 degenerative spondylolisthesis, and 6 isthmic spondylolisthesis. 13 total laminectomy, 35 partial laminectomy.
Postacchini, Cinotti, Gumina et al., 1993 | 64 | Patients who received surgery for lumbar spinal stenosis between 1972 and 1988 at the Orthopedic Clinic of the University of Modena and the Orthopedic Clinic of the University of Rome.Patients were followed at least 6 months. | None reported. | Development, degenerative, and combined stenosis patients were evaluated. 25 patients had spondylolisthesis. Total laminectomy 28 patients and bilateral laminotomy 19 patients were combined.17 patients were fused.Study did not report patient ages.
Case-series
Guigui, Barre, Benoist et al., 1999 | 28 | Patients with lumbar spinal stenosis who underwent decompressive surgery between November 1984 and January 1988 in the authors' department Orthopaedic Department, Hospital Beaujon, Clichy, France. | None reported. | Outcomes are not reported per type of spinal stenosis or type of surgery. 17 patients had degenerative lumbar stenosis without spondylolisthesis and 6 patients had degenerative lumbar stenosis with spondylolisthesis.2 patients had fusion.Randomly selected 28 patients from a pool of 76 patients.
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 55 | Only patients over 50 years of age were included.Diagnosis of lumbar spinal stenosis based on radiographic and clinical findings. All patients had disabling back, buttock, or leg pain with at least one level of central lumbar spinal stenosis. | Patients with previous back surgery. | This is a cohort study of originally nonoperated patients. 6 patients dropped out one died during the study, 9 needed surgery, and 40 remained on conservative therapy.
Mariconda, Zanforlino, Celestino et al., 2000 | 37 | Radicular pain with or without low back pain, stenosis classified as degenerative or combined, age more than 40 years, and narrowing of the central portion of the spinal canal with the area of the dural sac less than 130 mm2 at one or more intervertebral levels. | Congenital or constitutional stenosis, pure lateral stenosis, previous back surgery, and age less than 40 years. | The patient characteristics are reported for the entire group before dividing into operated and nonoperated patients.Each of the outcomes is part of the scoring system for the Beaujon Scoring System.
Johnsson, Uden, and Rosen, 1991 | 76 | Patients who from 1974 to 1985 were treated surgically because of spinal stenosis and patients not so treated because the anesthesiologist refused to administer anesthesia because of advance cardiovascular disease 2 patients or the patients refused surgery 18 patients. | The only untreated patient with severe stenosis was not reported in order to obtain comparable patient groups untreated with moderate stenosis, surgery with moderate stenosis, surgery with severe stenosis. Patients who had undergone previous spinal surgery, had impaired circulation in the legs, or had a minimal midsagittal diameter of the dural sac of greater than or equal to 12 mm. | Whether the study was performed prospectively or retrospectively is unclear. Walking capacity in meters was subjectively assessed at diagnosis and at followup suggesting that the study was prospectively conducted.None of the untreated patients were lost to followup, but 7 of the surgical patients died, and 5 patients did not participate. The dropouts from the surgical group were not distinguished as moderate or severe stenosis.
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen, Weber, Nordal et al., 2000 | 100 | Participants had sciatic pain in the leg s, with or without pain in the back, together with radiologic signs of stensosis and compression of the clinically afflicted nerve root s | Patients were excluded if they had a bulging or herniated disk, spondylolysis, coxarthosis, gonarthosis, arterial insufficiency in the legs, polyneuropathy, concomitant serious disease, or previous surgery on the back | Study randomized patients with moderate symptoms to either conservative or surgical treatment. Patients with severe symptoms were given surgery and patients with mild symptoms were given conservative treatmen
Hurri, Slatis, Soini et al., 1998 | 134 | Functional myelography diagnostic of spinal stenosis between 1978 and 1982 and interviewed by telephone in 1993.Based on the narrowest sagittal diameter on functional myelography, the diameter must be 10.5 mm or less. | Those with narrow dural sac without indentations were excluded, because they were considered to represent a constitutional form of narrow dural sac. | Of the original 134 patients, 48 died during the 12 year followup period, and 9 could not be traced.
Atlas, Deyo, Keller et al., 1996 | 148 | Diagnosis of lumbar spinal stenosis based on appropriate symptoms and radiographic findings consistent with spinal stenosis, including patients with spina stenosis associated with a herniated lumbar disk. | Exclusion criteria included prior lumbar spine surgery, cauda equina syndrome, developmental spinal deformities, vertebral fractures, spine infection or tumor, inflammatory spondylopathy, pregnancy, or age younger than 18 years. | Practices of orthopedic surgeons and neurosurgeons from Maine were recruited to provide patient information.No estimate of potential patients who did not enter the study. 71 of 81 surgery patients received laminectomy; the other 10 had open discectomy only 7 or laminectomy and fusion 3. 60% of surgical patients and 68% of nonsurgical patients had comorbid illnesses, but specific incidences were not reported. Patients with spinal stenosis due to herniated disk were included.
Atlas, Keller, Robson et al., 2000 | 119 | Four year followup to Atlas, Deyo, Keller et al., 1996
Swezey, 1996 | 47 | Sequential patients diagnosed in 1986-1987 who met the clinical criteria of neurogenic claudication secondary to lumbar spinal stenosis and were available for telephone interview or reexamination in 1993. | 4 of 51 patients had mild stenosis by CT or MRI and were excluded. | Patient characteristics are only available for the entire patient group and are not listed by treatment. A surgical group 11 patients and a nonsurgical group 36 patients were examined. Within the nonsurgical group are patients given pelvic traction.
Nagler and Bodack, 1993 | 100 | All patients diagnosed as having lumbar spinal stenosis who attended the Department of Rehabilitation Medicine at the New York Hospital - Cornell University Medical Center form January 1, 1980 to December 31, 1983. Inclusion in the study required clinical symptoms at the time of initial evaluation of pain, numbness, and weakness in the lower back and extremities which was typically worse with standing or walking and which was relieved by sitting or lying, and a positive CT scan and/or myelogram. Surgical patients were a selected group with fewer concomitant medical problems. | Patient were excluded if they had a predominant extrusion or protrusion of a disk as the cause of their symptoms. | Of an original 100 patients only 80 could be contacted for followup information. No individual patient signs and symptoms were reported. The anterior-posterior diameter of the lumbar spinal canal was measured and the mean reported according to improvement aftertreatment not by treatment groups: Excellent n=12, 10.00 mm; Good n=13, 10.08 mm; Fair n=6, 10.48 mm; Slight n=4, 10.32 mm; Same n=7, 10.00 mm.
Herno, Airaksinen, Saari et al., 1996 | 57 | Nonoperative lumbar spinal stenosis patients who had undergone myelography were identified. | Prior back surgery. | The conservatively treated patients were selected as patched pairs to surgical patients. The surgical patients were part of a larger group of patients undergoing surgery that are reported elsewhere in this database.
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 43 | Patients referred initially to a special back clinic with symptomatic degenerative spondylolisthesis. | None reported | This is a retrospective trial in which the control conservatively treated group has a less severe condition than the surgical group.
Rosenberg, 1976 | 200 | Patients with degenerative spondylolisthesis examined between 1956 and 1968. | Patients with less than 5% slipping were excluded. | Retrospective study of nonsurgical and surgical patients with little actual patient information or outcome measurements.Of 200 patients, 159 were female, mean age 61 years, range 44 to 89.
Trials Describing Only the Natural History of Lumbar Spinal Stenosis Patients
Patients with Central Lumbar Stenosis
Hamdan and Al-Kaissie, 1994 | 75 | 50 patients were selected at random method not defined from 1500 cases attending the orthopedic clinic in Basrah University Hospital. All had back ache and/or sciatica. 25 patients with lumbar canal stenosis were included for comparison and seem to have come from the 50 randomly selected patients. 50 normal patients were selected from patients attending the radiological departments with complaints other than back problems. | Not reported. | Surgical outcome data were not extracted because only 17 of 25 patients received surgery and the patient conditions/characteristics were not defined. Several different surgical approaches were used. 50 normal patients were used for spinal measurements only and no patient characteristics data are available. Only range data is provided for the canal ratio measurement and this only for the normal group.
Patients with Lateral Lumbar Stenosis
Jonsson and Stromqvist, 1993b | 100 | First 100 patients from 1986 admitted for decompressive surgery of the lumbar spine and had lateral stenosis. | None reported. | Only the lateral stenosis patients were extracted.The central stenosis patients were probably part of an update published in 1997 Jonsson, Annertz, Sjoberg et al., 1997a; Jonsson, Annertz, Sjoberg et al., 1997b that also described patient characteristics prior to surgery for central stenosis patients only from 1986 to 1991.
Patients with Degenerative Spondylolisthesis
Matsunaga, Sakou, Morizono et al., 1990 | 40 | Patients with degenerative spondylolisthesis and slippage of 5% or more for the past 15 years without surgery or long-term conservative therapy. | None reported | 40 patients were followed who did not have surgery or long-term conservative therapy. 3 patients were trauma cases.
Sato, Wakamatsu, Yoshizumi et al., 1989 | 355 | Patients with a forward slip of L4 onto L5 of more than 3 mm on lateral radiographs. | Patients with transitional vertebrae were excluded. | Little information is available on the control group of patients who had low-back pain but no spondylolisthesis.
Patients with Lumbar Stenosis and Spondylolisthesis
Radu and Menkes, 1998 | 62 | Patients admitted to the Cochin Teaching Hospital Rheumatology Unit between July 1995 and June 1996 for lumbar spinal stenosis. | A 12 year old with congenital lumbar spinal stenosis was excluded. | Comorbidity was high. Duration was given per years, 21% less than 1 year, 21% greater than 5 years. Of 62 patients only 8 went on to surgery.
Amundsen, Weber, Lilleas et al., 1995 | 100 | Sciatic pain with or without pain in the back.Radiologic signs of compression on the clinically afflicted nerve root s. | Excluded if nerve root compression was primarily caused by a bulging or herniated disk, tumor, or infection. Previous back surgery, Spondylolysis or lytic spondylolisthesis, arterial insufficiency, polyneuropathy, concomitant serious disease. | Pretreatment data only. Distribution of conditions: 51 lateral and 49 central stenosis; 72 degenerative, 13 developmental, and 15 combined. 12 patients had degenerative spondylolisthesis.No correlation between degree of stenosis and degree of pain Chi-square P value of 0.6
Johnsson, Uden, and Rosen, 1992 | 32 | Patients with spinal stenosis who were observed only i.e.., no surgery during the study period. | Prior spinal surgery; impaired circulation in the legs; canal AP diameter >11 mm | Observational study of a "no treatment" group of spinal stenosis patients; Reported pre- post symptoms for all patients followed and also stratified by anterior-posterior canal diameter, pain level and walking distance by outcomes.

Evidence Table 9. Patient Treatment Information for Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized controlled Trials of Patients Receiving Conservative Treatments
First Author and Year of Publication | Patient Group | N | Treatment | Description of Treatment
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 1 | 16 | Epidural Saline | Three epidural injections of 8ml saline over 1 week as a control treatment.
Fukusaki, Kobayashi, Hara et al., 1998 | 2 | 18 | Epidural Anesthetics | Three epidural injections of 8ml of 1% mepivacaine over 1 week.
Fukusaki, Kobayashi, Hara et al., 1998 | 3 | 19 | Epidural Anesthetics and Steroids | Three epidural injections of 1% mepivacaine and 40mg methylprednisolone over 1 week.
Eskola, Pohjolainen, Alaranta et al., 1992 | 1 | 20 | Calcitonin Injections | Patients were injected with 100 IU of calcitonin every 2 days for 4 weeks. After a 2-month washout, patients were injected with placebo on the same schedule.Blind, cross over design.
Eskola, Pohjolainen, Alaranta et al., 1992 | 2 | 19 | Calcitonin Injections | Patients were injected with placebo every 2 days for 4 weeks. After a 2-month washout, patients were injected with 100 IU of calcitonin on the same schedule. Blind, cross over design.
Cuckler, 1985 Cuckler, Bernini, Wiesel et al., 1985 | 1 | 20 | Epidural Anesthetics and Steroids | 7 ml of fluid was injected into the epidural space between the third and fourth lumbar vertebrae containing 2 ml with 80 mg of methylprednisolone acetate and 5 ml of 1% procaine.
Cuckler, 1985 Cuckler, Bernini, Wiesel et al., 1985 | 2 | 17 | Epidural Anesthetics | 7 ml of fluid was injected into the epidural space between the third and fourth lumbar vertebrae containing 2 ml of sterile water and 5 ml of 1% procaine.
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 1 | 29 | Exercise/flexion | Flexion exercises- Abdominal Strengthening, Pelvic Tilt, Chest-to-thigh position.
Sinaki, Lutness, Ilstrup et al., 1989 | 2 | 19 | Exercise/extension | Extension exercises- Upper back extension from prone position, Hip extension from prone position.

Trials Examining Surgical Patients with CentralLumbar Stenosis
First Author and Year of Publication | Patient Group | N | Treatment and Specific or Unique Condition | Type of Fusion | Type of Instrumentation | Concurrent Therapy
Randomized controlled Trial
Grob, Humke, and Dvorak, 1995 | 1 | 15 | Partial laminectomy or hemilaminectomy | None | None | If necessary herniated disk were removed.
Grob, Humke, and Dvorak, 1995 | 2 | 15 | Partial laminectomy with fusion and instrumentation for single level | Arthrodesis of the most stenotic segment, autologous bone graft from the iliac crest | Fixed with a translaminar screw | If necessary herniated disk were removed.
Grob, Humke, and Dvorak, 1995 | 3 | 15 | Partial laminectomy with fusion and instrumentation for multiple levels | Arthrodesis of multiple segments, autologous bone graft from the iliac crest | Cotrel-Dubousset instrumentation with screws in 8 patients, the AO system in 7 patients. | If necessary herniated disk were removed.
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 1 | 35 | Mixed Decompression Techniques - no post-surgery stenosis | None | None | None
Herno, Saari, Suomalainen et al., 1999 | 2 | 57 | Mixed Decompression Techniques - post-surgery stenosis | None | None | None
Herno, Partanen, Talaslahti et al., 1999 | 1 | 41 | Standard Wide Decompressive Laminectomy post surgery stenosis | None | None | None
Herno, Partanen, Talaslahti et al., 1999 | 2 | | Standard Wide Decompressive Laminectomy no post surgery stenosis | None | None | None
Hanakita, Suwa, and MIzuno, 1999 | 1 | 59 | Standard Wide Decompressive Laminectomy SWDL | None | None | None
Hanakita, Suwa, and MIzuno, 1999 | 2 | 61 | Standard Wide Decompressive Laminectomy | None | None | None
Hanakita, Suwa, and MIzuno, 1999 | 3 | 16 | Partial laminectomy or hemilaminectomy | None | None | None
Hanakita, Suwa, and MIzuno, 1999 | 4 | 20 | SWDL with Fusion Arthrodesis | None | None | None
Thomas, Rea, Pikul et al., 1997 | 1 | 12 | Standard Wide Decompressive Laminectomy | None | None | None
Thomas, Rea, Pikul et al., 1997 | 2 | 14 | Laminotomy | None | None | None
Yone, Sakou, Kawauchi et al., 1996 | 1 | 10 | SWDL with Fusion and Instrumentation | Posterior-lateral fusion | Steffee plate and Diapason in 5 patients, Knodt distraction rod in 5 patients | None
Yone, Sakou, Kawauchi et al., 1996 | 2 | 17 | Laminotomy | None | None | None
Ray, 1982 | 1 | 48 | Standard Wide Decompressive Laminectomy | None | None | None
Ray, 1982 | 2 | 17 | Partial laminectomy or hemilaminectomy | None | None | None
Surin, Hedelin, and Smith, 1982 | 1 | 15 | Standard Wide Decompressive Laminectomy - marked stenosis | None | None | None
Surin, Hedelin, and Smith, 1982 | 2 | 7 | Standard Wide Decompressive Laminectomy - moderate stenosis | None | None | None
Tajima, Fukazawa, and Ishio, 1980 | 1 | 13 | Mixed Decompression Techniques | 11 patients given wide laminectomy, 2 patients given laminectomy and fusion | None | None reported
| 2 | 14 | Mixed Decompression Techniques - disk lesion | 6 patients with laminectomy only, 5 patients with laminectomy and fusion, 3 patients with Love's method | None | All patients had a herniated disk.No other therapies were reported.
Prospective Trials
Weiner, Walker, Brower et al., 1999 | 1 | 54 | Partial Laminectomy | None | None | None
diPierro, Helm, Shaffrey et al., 1996 | 1 | 30 | Partial Laminectomy | None | None | None
diPierro, Helm, Shaffrey et al., 1996 | 1 | 35 | Hemilaminectomy and fusion | Contralateral fusion using bone chips from the hemilaminectomy | None | In-house physical therapy and outpatient physical therapy.
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 1 | 65 | Mixed Decompression Techniques | Posterior spinal fusion | Pedicle screw fixation | None
Matsui, Kanamori, Ishihara et al., 1997 | 1 | 27 | SWDL with Fusion Arthrodesis | Bone graft harvested from the spinous process are placed on the open gap and tied with a steel wire. Bone graft and chips from the posterior ilium are placed on the laminae and facet joint surfaces. | None | Body cast for 1 month and soft brace for 2-3 months.
Airaksinen, Herno, Turunen et al., 1997 | 1 | 497 | Standard Wide Decompressive Laminectomy | None | None | None
Mullin, Rea, Irsik et al., 1996 | 1 | 72 | Standard Wide Decompressive Laminectomy | None | None | None
Ishac, Alhayek, Fournier et al., 1996 | 1 | 34 | Standard Wide Decompressive Laminectomy | None | None | None
Jonsson and Stromqvist, 1994 | 1 | 43 | Partial laminectomy or hemilaminectomy | None | None | None
Caputy and Luessenhop, 1992 | 1 | 100 | Standard Wide Decompressive Laminectomy | None | None | None
Dhar and Porter, 1992 | 1 | 36 | Standard Wide Decompressive Laminectomy | None | None | None
Chahal, Mundkur, Sancheti et al., 1982 | 1 | 32 | Standard Wide Decompressive Laminectomy | None | None | None
Rosomoff, 1981 | 1 | 50 | Standard Wide Decompressive Laminectomy | None | None | None
Getty, 1980 | 1 | 35 | Standard Wide Decompressive Laminectomy | None | None | None
Reale, Deifini, Gambacona et al., 1978 | 1 | 37 | Standard Wide Decompressive Laminectomy - congenital stenosis | None | None | None
Verbiest, 1977 | 1 | 116 | Standard Wide Decompressive Laminectomy - congenital stenosis | None | None | None
Case-series
Young, Veerapen, and O'Laoire, 1988 | 1 | 32 | Decompressive Surgery | None | None | None
Kurihara, Tanaka, Tsumura et al., 1988 | 1 | 12 | Standard Wide Decompressive Laminectomy - hyperostotic stenosis | None | None | None
Hall, Bartleson, Onofrio et al., 1985 | 1 | 68 | Standard Wide Decompressive Laminectomy | None | None | None
Weinstein, Scafuri, and McNeill, 1983 | 1 | 24 | Standard Wide Decompressive Laminectomy | 1 patient required supplemental posterolateral fusion | None | None
Weir and De Leo, 1981 | 1 | 81 | Standard Wide Decompressive Laminectomy | None | None | None
Johnsson, Willner, and Pettersson, 1981 | 1 | 27 | Standard Wide Decompressive Laminectomy | None | None | None
Verbiest, 1979 | 1 | 11 | SWDL with Fusion Arthrodesis - congenital lumbar stenosis | Anterior console lumbosacral fusion | None | None
Salibi, 1976 | 1 | 19 | Standard wide laminectomy 16 patients and unilateral laminectomy 3 patients | None | None | None
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized controlled Trials
Lee and deBari, 1986 | 1 | 12 | SWDL with Fusion Arthrodesis | Bilateral-lateral fusion from L3 to the sacrum | None | Progressive ambulation training and physical therapy.Some patients were allowed to wear elastic lumbosacral corsets postoperatively, but no rigid braces were allowed.
Lee and deBari, 1986 | 2 | 12 | SWDL with Fusion and Instrumentation | Bilateral-lateral fusion from L3 to the sacrum | Knodt distraction rods | Progressive ambulation training and physical therapy.Some patients were allowed to wear elastic lumbosacral corsets postoperatively, but no rigid braces were allowed.
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 1 | 20 | Partial laminectomy or hemilaminectomy | None | None | None
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 2 | 32 | Partial laminectomy or hemilaminectomy - with disk herniation | None | None | None
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 3 | 21 | Partial laminectomy or hemilaminectomy - Lateral and Central Stenosis | None | None | None
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 4 | 21 | Partial laminectomy or hemilaminectomy - Lateral and Central Stenosis and disk herniation | None | None | None
Mikhael, Ciric, Tarkington et al., 1981 | 1 | 35 | Standard Wide Decompressive Laminectomy | None | None | None
Mikhael, Ciric, Tarkington et al., 1981 | 2 | 50 | Control/Placebo/None | None | None | None
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 1 | 66 | Laminotomy | None | None | None
Baba, Uchida, Maezawa et al., 1996 | 1 | 31 | Laminotomy | None | None | None
Aryanpur and Ducker, 1990 | 1 | 32 | Laminotomy | None | None | None
Case-series
Choudhury and Taylor, 1977 | 1 | 28 | Standard Wide Decompressive Laminectomy | None | None | If a disk prolapse was found it was removed.
Epstein, Epstein, Rosenthal et al., 1972 | 1 | 15 | Foraminotomy/nerve root decompression | None | None | None
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes bothtypes of stenosis
Controlled Trial
Yone and Sakou, 1999 | 1 | 14 | Laminotomy - patients with instability | None | None | None
Yone and Sakou, 1999 | 2 | 19 | Laminotomy with Fusion and Instrumentation - patients with instability | Posterolateral spinal fusion | 16 Diapason pedicle screw system, and 3 Knodt distraction rod. | None
Yone and Sakou, 1999 | 3 | 27 | Laminotomy - patients without instability | None | None | None
Epstein, 1999 | 1 | 10 | Standard Wide Decompressive Laminectomy - patients with Ossification of the Posterior Longitudinal Ligament | None | None | None
Epstein, 1999 | 2 | 11 | Standard Wide Decompressive Laminectomy - patients with Ossification of the Yellow Ligament | None | None | None
Javid and Hadar, 1998 | 1 | 86 | Standard Wide Decompressive Laminectomy - patients with central stenosis | 9 patients received fusion. | None | None
Javid and Hadar, 1998 | 2 | 61 | Standard Wide Decompressive Laminectomy - patients with central stenosis and herniated disks | None | None | None
Javid and Hadar, 1998 | 3 | 23 | Standard Wide Decompressive Laminectomy - patients with lateral stenosis | None | None | None
Kalbarczyk, Lukes, and Seiler, 1998 | 1 | 93 | Standard Wide Decompressive Laminectomy - patients without instability | None | None | None
Kalbarczyk, Lukes, and Seiler, 1998 | 2 | 46 | Partial laminectomy or hemilaminectomy - patients with mild instability | None | None | Note: Patients in this group had low grade Meyerding grade 0 or 1 spondylolisthesis; no fusion was done.
Kalbarczyk, Lukes, and Seiler, 1998 | 3 | 9 | Partial laminectomy and fusion - patients with high instability | Not described | None | Note: Patients in this group had high grade Meyerding grade 2 or higher spondylolisthesis. Fusion was done.
Pai and Kumar, 1996 | 1 | 30 | Decompressive Surgery - patients with congenital stenosis | None | None | None
Pai and Kumar, 1996 | 2 | 23 | Decompressive Surgery - patients with degenerative stenosis | None | None | None
Kawauchi, Yone, and Sakou, 1996 | 1 | 7 | Partial laminectomy and fusion - patients with slight adhesions | None | None | None
Kawauchi, Yone, and Sakou, 1996 | 2 | 16 | Partial laminectomy and fusion- patients with moderate adhesions | None | None | None
Kawauchi, Yone, and Sakou, 1996 | 3 | 13 | Partial laminectomy and fusion- patients with marked adhesions | None | None | None
Cinotti, Postacchini, and Weinstein, 1994 | 1 | 25 | Standard Wide Decompressive Laminectomy - patients with diabetes | None | None | None
Cinotti, Postacchini, and Weinstein, 1994 | 2 | 25 | Standard Wide Decompressive Laminectomy - patients without diabetes | None | None | None
Little and MacDonald, 1994 | 1 | 60 | SWDL with Fusion Arthrodesis | Not described | None | None
Little and MacDonald, 1994 | 2 | 34 | SWDL with Fusion Arthrodesis | Not described | None | None
Jonsson and Stromqvist, 1993a | 1 | 20 | Partial laminectomy or hemilaminectomy - patients with central stenosis | None | None | None
Jonsson and Stromqvist, 1993a | 2 | 19 | Partial laminectomy or hemilaminectomy - patients with lateral stenosis | None | None | None
Simpson, Silveri, Balderston et al., 1993 | 1 | 33 | Standard Wide Decompressive Laminectomy - patients with diabetes | None | None | These are diabetic patients treated with insulin or oral anti-diabetic medications.
Simpson, Silveri, Balderston et al., 1993 | 2 | 24 | Standard Wide Decompressive Laminectomy - patients without diabetes | None | None | None
Nasca, 1989 | 1 | 15 | Decompressive Surgery - patients with lateral lumbar stenosis | 2 patients required posterior-lateral fusion 1 and 3 years later. | None | None
Nasca, 1989 | 2 | 29 | Decompressive Surgery - patients with central or combined lumbar stenosis | None | None | None
Nasca, 1989 | 3 | 16 | Decompressive Surgery with fusion and instrumentation - patients with central or combined lumbar stenosis | Posterior-lateral fusion | 7 had Knodt rods, the rest had no instrumentation
Nasca, 1989 | 4 | 21 | Decompressive Surgery - patients with postsurgical stenosis | None | None | None
Nasca, 1989 | 5 | 22 | Decompressive Surgery with fusion and instrumentation - patients with instability | Posterior-lateral | 16 had instrumentation. Type not stated.
Nasca, 1989 | 6 | 11 | Decompressive Surgery with fusion and instrumentation - patients with degenerative stenosis and scoliosis | | Harrington-Moe rods. 2 patients had no instrumentation.
Nather and Thomas, 1985 | 1 | 11 | Decompressive surgery with or without fusion - patients with degenerative lumbar stenosis
Nather and Thomas, 1985 | 2 | 14 | Decompressive surgery with or without fusion - patients with combined degenerative and congenital lumbar stenosis
Paine, 1976 | 1 | 95 | Standard Wide Decompressive Laminectomy - patients with degenerative stenosis
Paine, 1976 | 2 | 48 | Standard Wide Decompressive Laminectomy- patients with degenerative stenosis and disk herniation
Shenkin and Hash, 1976 | 1 | 49 | Standard Wide Decompressive Laminectomy - patients with no prior surgery | None | None | None
Shenkin and Hash, 1976 | 2 | 21 | Standard Wide Decompressive Laminectomy - patients with prior surgery for herniated disk | None | None | None
Tile, McNeil, Zarins et al., 1976 | 1 | 26 | Mixed Decompression Techniques - patients with lumbar stenosis | 2 patients were fused.
Tile, McNeil, Zarins et al., 1976 | 2 | 18 | Standard Wide Decompressive Laminectomy - patients with congenital stenosis
Retrospective Trial with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 1 | 34 | Partial laminectomy or hemilaminectomy | None | None | Low dose aspirin 75 mg aspirin or 100 mg dispirin CV was prescribed to be taken daily fro 3-4 months following the operation to facilitate the micro-circulation of the cauda equina and nerve roots.
Silvers, Lewis, and Asch, 1993 | 1 | 248 | Standard Wide Decompressive Laminectomy | Two patients had fusion | None | None
Katz, Lipson, Larson et al., 1991 | 1 | 88 | Mixed Decompression Techniques | 8 patients had bilateral lateral arthrodesis, supplemented by grafting of autogenous cancellous bone from the iliac crest | None | None
Ganz, 1990 | 1 | 36 | Standard Wide Decompressive Laminectomy | None | None | None
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 1 | 70 | Decompressive Surgery with fusion and instrumentation | Not Reported | Not Reported | None
Guigui, Benoist, Delecourt et al., 1998 | 1 | 50 | Decompressive surgery | None | None | None
Scholz, Firsching, and Lanksch, 1998 | 1 | 72 | Decompressive Surgery | None | None | None
Tsai, Yang, and Bray, 1998 | 1 | 62 | Laminotomy | None | None | None
Mackay and Wheelwright, 1998 | 1 | 50 | Partial laminectomy or hemilaminectomy | No patient received fusion. | None | None
Whitecloud, Castro Jr, Brinker et al., 1998 | 1 | 35 | SWDL with Fusion and Instrumentation | Sequential anterior and posterior fusion | Titanium cages | None
Spetzger, Bertalanffy, Reinges et al., 1997 | 1 | 29 | Laminotomy | None | None | None
Katz, Lipson, Chang et al., 1996 | 1 | 88 | Standard Wide Decompressive Laminectomy | 5 patients received arthrodesis by grafting autogenous cancellous bone from the iliac crest. | None | None
Lehto and Honkanen, 1995 | 1 | 96 | Decompressive Surgery | None | None | None
Stucki, Liang, Fossel et al., 1995 | 1 | 203 | Decompressive Surgery | No description of actual surgery was reported.
Tuite, Stern, Doran et al., 1994 | 1 | 119 | Standard Wide Decompressive Laminectomy | None | None | None
McCullen, Bernini, Bernstein et al., 1994 | 1 | 193 | Decompressive Surgery | None | None | Rest, Physiotherapy, and antiinflammatory medication.
Simmons and Simmons, 1992 | 1 | 40 | SWDL with Fusion and Instrumentation | Bilateral posterolateral with bone grafting with the use of autogenous and allograft bone | Zielke 24 patients, Cotrel-Dubousset 8 patients, Texas Scottish Rite Hospital 8 patients | None
Mauersberger and Nietgen, 1989 | 1 | 92 | Decompressive surgery with or without fusion | Not described | None | None
Johnsson, Redlund-Johnell, Uden et al., 1989 | 1 | 61 | Standard Wide Decompressive Laminectomy | None | None | None
Brodsky, Hendricks, Khalil et al., 1989 | 1 | 34 | Fusion | Not described | None | None
Jalovaara, Lahde, Iikko et al., 1989 | 1 | 31 | Standard Wide Decompressive Laminectomy | None | None | None
Fast, Robin, and Floman, 1985 | 1 | 19 | Standard Wide Decompressive Laminectomy | 1 patient received a bilateral lateral fusion
Boccanera, Pellicioni, and Laus, 1984 | 1 | 25 | Standard Wide Decompressive Laminectomy
Hood and Weigl, 1983 | 1 | 21 | Standard Wide Decompressive Laminectomy
Scafuri and Weinstein, 1981 | 1 | 27 | Standard Wide Decompressive Laminectomy
Echeverria and Lockwood, 1979 | 1 | 35 | Standard Wide Decompressive Laminectomy | Surgery poorly described. All patients received wide and thorough decompression, including foraminotomy when indicated. No fusion was attempted.
Scapinelli, 1978 | 1 | 23 | Standard Wide Decompressive Laminectomy | | | Lumbo-sacral support and physical therapy
Vestad and Naca, 1977 | 1 | 80 | Standard Wide Decompressive Laminectomy | 16 posterior intercorporal, intertransversal, or dorsal, 1 anterior fusion.
McKinley and Davis, 1976 | 1 | 32 | Standard Wide Decompressive Laminectomy
Teng and Papatheodorou, 1963 | 1 | 29 | SWDL-Standard Wide Decompressive Laminectomy | | | One patient is included in the patient information despite not having undergone any surgery. He or she is still under conservative care, which was not described.
Epstein, Epstein, and Lavine, 1962 | 1 | 29 | Mixed Decompression Techniques
Epstein, 1960 | 1 | 14 | Standard Wide Decompressive Laminectomy
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trial
Fischgrund, Mackay, Herkowitz et al., 1997 | 1 | 40 | SWDL with Fusion and Instrumentation | Autogenous bilateral lateral intertransverse process arthrodesis | Pedicle screws, VSP, Acromed, Cleveland, Ohio | None
Fischgrund, Mackay, Herkowitz et al., 1997 | 2 | 35 | SWDL with Fusion Arthrodesis | Autogenous bilateral lateral intertransverse process arthrodesis | None | None
Thomsen, Christensen, Eiskjaer et al., 1997 | 1 | 20 | Partial laminectomy with fusion and instrumentation | Posterolateral intertransverse fusion with autologous bone transplantation from the right iliac wing | Cotrel-Dubousset system for pedicle screw fixation. | None
Thomsen, Christensen, Eiskjaer et al., 1997 | 2 | 21 | Partial laminectomy and fusion | Posterolateral intertransverse fusion with autologous bone transplantation from the right iliac wing | None | None
Bridwell, Sedgewick, O'Brien et al., 1993 | 1 | 9 | Partial laminectomy or hemilaminectomy | None | None | None
Bridwell, Sedgewick, O'Brien et al., 1993 | 2 | 10 | Partial laminectomy and fusion | Posterolateral transverse processes, autogenous iliac bone graft | None | None
Bridwell, Sedgewick, O'Brien et al., 1993 | 3 | 24 | Partial laminectomy with fusion and instrumentation | Posterolateral transverse processes, autogenous iliac bone graft | Pedicle fixation using Steffee plates | None
Herkowitz and Kurz, 1991 | 1 | 25 | SWDL-Standard Wide Decompressive Laminectomy | None | None | None
Herkowitz and Kurz, 1991 | 2 | 25 | SWDL with Fusion Arthrodesis | Single level bilateral intertransverse-process arthrodesis with autologous bone from the iliac crest | None | None
Controlled Trials
Plotz and Benini, 1998 | 1 | 17 | Decompressive Surgery without fusion
Plotz and Benini, 1998 | 2 | 18 | Decompressive Surgery with fusion and Translaminar Screw Fixation | | Translaminar Screw Fixation
Plotz and Benini, 1998 | 3 | 71 | Decompressive Surgery with fusion and AO Internal Fixator | | AO Internal Fixator of Dick
Yuan, Garfin, Dickman et al., 1994 | 1 | 2177 | Fusion and Pedical Screw Fixation | Posterior autograft | Screws or bolts that could be inserted into spinal pedicles for the fixation of the spine | None
Yuan, Garfin, Dickman et al., 1994 | 2 | 456 | Fusion | Posterior autograft | None | None
Satomi, Hirabayashi, Toyama et al., 1992 | 1 | 27 | Fusion and instrumentation | Anterior lumbar interbody fusion | 21 of 27 patients received AO screwing and wiring | None
Satomi, Hirabayashi, Toyama et al., 1992 | 2 | 14 | Mixed Decompression Techniques | 8 interlaminal fenestration, 5 laminectomy, 1 fusion and Luque rods. | None | None
Lombardi, Wiltse, Reynolds et al., 1985 | 1 | 20 | SWDL-Standard Wide Decompressive Laminectomy
Lombardi, Wiltse, Reynolds et al., 1985 | 2 | 21 | SWDL with Fusion Arthrodesis
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 1 | 23 | Fusion only | Posterior lumbar intervertebral fusion without laminectomy preserving the interspinous process ligament.
Rechtine, Sutterlin, Wood et al., 1996 | 1 | 18 | SWDL with Fusion and Instrumentation | transverse processes posterolateral autogenous bone grafts | Interpedicular Segmental Fixation system from Sofamor Danek United States | None
Retrospective Trial with Consecutive Patients
Stambough, 1999 | 1 | 35 | SWDL with Fusion and Instrumentation | Autogenous bone graft with some fresh frozen allographic augmentation | Wide variety of pedicular screw fixation and instrumentation | Custom-molded thoracolumbosacral brace
Nishizawa and Fujimura, 1997 | 1 | 58 | Fusion and instrumentation | Anterior lumbar interbody fusion, grafts of cortico-cancellous bone were taken from the anterior iliac crest | A-O screws and wire were used in 48 of 58 patients | Body cast for 27 to 43 days, corset for 3 to 9 months
Moller, Wittenberg, Nolte et al., 1992 | 1 | 37 | Fusion | Posterolateral fusion with an autologous corticocancellous H-graft from the iliac crest wedged between the spinous processesL4 and S1. | None | A lumbar brace was used for an average of 4.9 months.Patients had intense isometric training to strengthen the trunk muscles.
Marchesi, Thalgott, and Aebi, 1991 | 1 | 30 | SWDL with Fusion and Instrumentation | Not described | AO internal fixation system using screws | Some patients were put in braces
Takahashi, Kitahara, Yamagata et al., 1990 | 1 | 39 | Fusion | Anterior interbody fusion | None | None
Knox, Harvell, Nelson et al., 1989 | 1 | 39 | SWDL with Fusion and Instrumentation | Autogenous iliac crest bone graft | 16 -gauge wire and Luque rectangle | Corset was worn for 3 months. Of the final 24 that were available to return and fill out questionnaires 13 were women and 11 were men.
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 1 | 49 | Partial laminectomy with fusion and instrumentation | Intertransverse process fusion | Constrained pedicle screw-plate or rod systems
McCulloch, 1998 | 1 | 21 | Partial laminectomy and fusion | Unilateral fusion with autograft bon
Epstein, 1998b | 1 | 28 | SWDL with Fusion and Instrumentation | Texas Scottish Rite Hospital Instrumented Fusion | Not Stated
Mochida, Toh, Suzuki et al., 1997 | 1 | 10 | Partial laminectomy with fusion and instrumentation | Posterior Lumbar Interbody Fusion | Leeds-Keio artificial ligament
Epstein, 1998a | 1 | 290 | Mixed Decompression Techniques
Grob, Humke, and Dvorak, 1996 | 1 | 18 | SWDL with Fusion and Instrumentation | posterolateral fusion with bone graft from the iliac crest. | Two 6.5mm spongious screws | Physiotherapy, epidural injection, brace, anti-inflammatory medication. Soft brace for 3 months.
Herron and Trippi, 1989 | 1 | 24 | Standard Wide Decompressive Laminectomy
Chang and McAfee, 1989 | 1 | 17 | SWDL with Fusion and Instrumentation | bilateral posterolateral fusion | combination segmental rod-plate and transpedicular spinal fixator | 3 patients had scoliosis rather than spondylolisthesis.
Inoue, Watanabe, Goto et al., 1988 | 1 | 36 | Fusion
Simmons and Capicotto, 1988 | 1 | 15 | SWDL with Fusion and Instrumentation | Bilateral posterolateral bone graft of the instrumented segments | Zielke screws and rods.
Hanley, 1986 | 1 | 20 | SWDL with Fusion and Instrumentation | Autologous iliac crest bone graft over the decorticated transverse process and lateral aspects of the pedicles and facet joints at the operated segments | Harrington distraction rods with #1254 hooks inferiorly and #1253 hooks superiorly
Kaneda and Kazama, 1986 | 1 | 54 | SWDL with Fusion and Instrumentation | Posterolateral | Combined distraction and compression rod instrumentation.
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 1 | 50 | Standard Wide Decompressive Laminectomy | 4 patients had undescribed fusion.
Dall and Rowe, 1985 | 1 | 26 | SWDL-Standard Wide Decompressive Laminectomy
Epstein, Epstein, Carras et al., 1983 | 1 | 60 | Mixed Decompression Techniques
Richardson and Brown, 1980 | 1 | 21 | SWDL with Fusion Arthrodesis | Posterolateral fusion | None | None
Cauchoix, Benoist, and Chassaing, 1976 | 1 | 26 | SWDL-Standard Wide Decompressive Laminectomy | None | None | Not described. Text stated that conservative care was adequate for some patients.
Epstein, Epstein, Lavine et al., 1976 | 1 | 20 | Mixed Decompression Techniques | 2 patients had fusion | None | None
Trials Examining Surgical Patients with LumbarStenosis and/or Degenerative Spondylolisthesis
Controlled Trial
Rompe, Eysel, Zollner et al., 1999 | 1 | 39 | Partial laminectomy or hemilaminectomy - patients with central lumbar stenosis | None | None | None
Rompe, Eysel, Zollner et al., 1999 | 2 | 51 | SWDL-Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | None | None | None
Rompe, Eysel, Zollner et al., 1999 | 3 | 27 | SWDL with Fusion and Instrumentation - patients with degenerative spondylolisthesis | Intertransverse autogenous bone graft | Cotrel-Dubousset-pedicle screw fixation. | None
Katz, Lipson, Lew et al., 1997 | 1 | 194 | Standard Wide Decompressive Laminectomy | None | None | None
Katz, Lipson, Lew et al., 1997 | 2 | 37 | SWDL with Fusion Arthrodesis | Intertransverse autogenous bone graft. | None | None
Katz, Lipson, Lew et al., 1997 | 3 | 41 | SWDL with Fusion and Instrumentation | Intertransverse autogenous bone graft. | Several types | None
Sato and Kikuchi, 1997 | 1 | 28 | Laminotomy - 2 level stenosis
Sato and Kikuchi, 1997 | 2 | 53 | Laminotomy - 1 level stenosis
Rompe, Eysel, Hopf et al., 1995 | 1 | 24 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis | 4 patients with posterior fusion and supplemental bone grafting | 4 patients with Cotrel-Dubousset-Instrumentation pedicle screws | None
Rompe, Eysel, Hopf et al., 1995 | 2 | 24 | Standard Wide Decompressive Laminectomy - patients with lumbar stenosis | None | None | None
Rompe, Eysel, Hopf et al., 1995 | 3 | 12 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis and spondylolisthesis | posterior fusion | 9 patients with Cotrel-Dubousset-Instrumentation pedicle screws, 3 patients with hook system | None
Sanderson and Wood, 1993 | 1 | 19 | Partial laminectomy or hemilaminectomy - patients with Degenerative Spondylolisthesis | None | None | None
Sanderson and Wood, 1993 | 2 | 12 | SWDL-Standard Wide Decompressive Laminectomy - patients with lumbar spinal stenosis | None | None | None
Robertson, Grobler, Novotny et al., 1993 | 1 | 22 | SWDL-Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | None | None | None
Robertson, Grobler, Novotny et al., 1993 | 2 | 11 | SWDL-Standard Wide Decompressive Laminectomy - patients with degenerative spondylolisthesis | None | None | None
Postacchini, Cinotti, Perugia et al., 1993 | 1 | 26 | Laminotomy - patients with congenital or degenerative stenosis, combined, or degenerative spondylolisthesis | 4 patients with deg. spondylolisthesis had intertransverse fusion | None
Postacchini, Cinotti, Perugia et al., 1993 | 2 | 41 | Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | 8 patients with deg. spondylolisthesis had intertransverse fusion | None
Hirabayashi, Kumano, and Kuroki, 1991 | 1 | 32 | SWDL with Fusion and Instrumentation - patients with degenerative spondylolisthesis | posterior lumbar interbody fusion | Cotrel-Dubousset pedicle screw system | None
Hirabayashi, Kumano, and Kuroki, 1991 | 2 | 21 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis | posterior lumbar interbody fusion | Cotrel-Dubousset pedicle screw system | None
Herkowitz and Garfin, 1989 | 1 | 58 | Standard Wide Decompressive Laminectomy - patients with degenerative stenosis
Herkowitz and Garfin, 1989 | 2 | 41 | Standard Wide Decompressive Laminectomy - patients with degenerative spondylolisthesis
Prospective Trial
Jonsson, Annertz, Sjoberg et al., 1997a | 1 | 105 | Partial laminectomy or hemilaminectomy - patients with Central Spinal Stenosis and Degenerative Spondylolisthesis | None
Postacchini and Conotti, 1992 | 1 | 88 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined, with or without Spondylolisthesis | 10 patients had intertransverse fusion
Retrospective Trial with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 1 | 80 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined stenosis, or degenerative or isthmic spondylolisthesis | 20 patients with spondylolisthesis had a intertransverse fusion | 8 patients had Cotrel Dubousset transpedicular fixation | None
Postacchini, Cinotti, Gumina et al., 1993 | 1 | 64 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined, with or without spondylolisthesis | 17 patients with intertransverse fusion | None | None
Case-series
Guigui, Barre, Benoist et al., 1999 | 1 | 28 | SWDL-Standard Wide Decompressive Laminectomy | 2 patients had posterolateral fusion | None | None
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 1 | 40 | Conservative - various treatment | | | 1 to 2 weeks of bed rest for patients with acute motor weakness, oral corticosteroids on a 7-day tapering schedule for significant radiculopathy, epidural corticosteroid injections for nonresponding patients, NSAIDs for less severe patients. All patients were placed in a physical rehabilitation program with a physical therapist and instructed to perform a flexion-biased lumbar stabilization exercise on a daily basis.
Simotas, Dorey, Hansraj et al., 2000 | 2 | 9 | Surgery - not described | | | Conservative therapy lasted a mean of 13 months, range 2 to 41 before these 9 patients needed surgery. All patients were placed in a physical rehabilitation program with a physical therapist and instructed to perform a flexion-biased lumbar stabilization exercise on a daily basis.
Mariconda, Zanforlino, Celestino et al., 2000 | 1 | 20 | Standard Wide Decompressive Laminectomy
Mariconda, Zanforlino, Celestino et al., 2000 | 2 | 17 | Untreated
Johnsson, Uden, and Rosen, 1991 | 1 | 20 | Conservative-not described | None | None | Not described
Johnsson, Uden, and Rosen, 1991 | 2 | 30 | Standard Wide Decompressive Laminectomy - patients with moderate stenosis | None | None | None
Johnsson, Uden, and Rosen, 1991 | 3 | 14 | Standard Wide Decompressive Laminectomy - patients with severe stenosis | None | None | None
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen, Weber, Nordal et al., 2000 | 1 | 19 | Standard wide decompressive laminectomy | None | | After 1 to 2 days patients received a brace; rehabilitation lasted 1 month followed by back school
Amundsen, Weber, Nordal et al., 2000 | 2 | 50 | Conservative - various treatments | | | Patients were fitted with a brace, given rehabilitation for 1 month, and "back school" training; after 2 months physiotherapy was started, including general physical training
Amundsen, Weber, Nordal et al., 2000 | 3 | 13 | Standard wide decompressive laminectomy | None | | After 1 to 2 days patients received a brace; rehabilitation lasted 1 month followed by back school
Amundsen, Weber, Nordal et al., 2000 | 4 | 18 | Conservative - various treatments | | | Patients were fitted with a brace, given rehabilitation for 1 month, and "back school" training; after 2 months physiotherapy was started, including general physical training
Hurri, Slatis, Soini et al., 1998 | 1 | 57 | SWDL-Standard Wide Decompressive Laminectomy | None | None | None
Hurri, Slatis, Soini et al., 1998 | 2 | 18 | Conservative-not described | None | None | The conservative treatment was not described and referred to only as nonoperative treatment.
Atlas, Deyo, Keller et al., 1996 | 1 | 81 | SWDL-Standard Wide Decompressive Laminectomy | 3 patients received fusion | None | None
Atlas, Deyo, Keller et al., 1996 | 2 | 67 | Conservative-many | None | None | Bed rest 27%, back exercises 39%, Traction 4%, Brace 14%, TENS 14%, Physical Therapy 23%, Spinal Manipulation 23%, Other therapies 5%, Epidural Steroids 18%, Narcotic analgesics use in past week 21%.
Atlas, Keller, Robson et al., 2000 | 1 | 67 | SWDL-Standard Wide Decompressive Laminectomy | Four year followup for Atlas, Deyo, Keller et al., 1996
Atlas, Keller, Robson et al., 2000 | 2 | 52 | Conservative-many | Four year followup for Atlas, Deyo, Keller et al., 1996
Swezey, 1996 | 1 | 12 | Exercise/stretching and flexibility | None | None | Ergonomics and flexion exercises plus analgesic and nonsteroidal anti-inflammatory drugs.
Swezey, 1996 | 2 | 11 | Physical Therapy/massage, ultrasound, heat, ice, traction | None | None | Outpatient pelvic traction using static traction on a split-traction table given once or twice weekly for 20 minutes at 50% of body weight. Ergonomics and flexion exercises plus analgesic and nonsteroidal anti-inflammatory drugs.
Swezey, 1996 | 3 | 13 | Epidural Steroid Injections | None | None | Epidural corticosteroid injections when other measures were not providing sufficient relief from neurogenic claudication.Maximum of 3 injections at no less than 1-2 week intervals. Ergonomics and flexion exercises plus analgesic and nonsteroidal anti-inflammatory drugs.
Swezey, 1996 | 4 | 11 | Standard Wide Decompressive Laminectomy | None | None | None
Nagler and Bodack, 1993 | 1 | 41 | Conservative-various types | None | None | Analgesics, electrical stimulation, ice, heat, hydrotherapy, ultrasound, muscle relaxation techniques, stretching and strengthening exercises, and treadmill training.
Nagler and Bodack, 1993 | 2 | 39 | Standard Wide Decompressive Laminectomy | None | None | None
Herno, Airaksinen, Saari et al., 1996 | 1 | 54 | Conservative-not described | None | None | Conservative therapy was not described.Patients were considered nonoperative.
Herno, Airaksinen, Saari et al., 1996 | Data from surgical patients used for comparison were obtained from a larger previously published study.
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 1 | 29 | Rigid Brace | None | None | Lumbo-sacral corset
Fitzgerald and Newman, 1976 | 2 | 14 | Mixed Decompression Techniques | Postero-lateral grafts over the transverse processes and adjoining outer parts of the facets and pedicles. | None | None
Rosenberg, 1976 | 1 | 11 | Partial laminectomy or hemilaminectomy | None | None | None
Rosenberg, 1976 | 2 | 15 | Standard Wide Decompressive Laminectomy | None | None | None
Rosenberg, 1976 | 3 | 170 | Conservative-not described | None | None | Patients received analgesics, anti-inflammatory medication, bracing, bed rest, exercise, traction and different thermal modalities with unpredictable ability to relief pain.Symptomatic therapy was adequate in 90% of patients.

Evidence Table 10. Patient Characteristics Information for Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized controlled Trials of Patients Receiving Conservative Treatments
First Author and Year of Publication | Patient Group | N | Treatment | Males | Females | Dropouts | | | Age years | | | | Duration of Condition months | | | | Levels Involved | | | PriorSurgery
First Author and Year of Publication | Patient Group | N | Treatment | Males | Females | Total | Deaths | Lost to Followup | Mean | SD | Youngest | Oldest | Mean | SD | Minimum | Maximum | Single | Multiple | Mean | PriorSurgery
Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 1 | 16 | Epidural Saline | 12 | 4 | 0 | 0 | 0 | 70 | 8 | | | 2.63 | 2 | | | 0 | 0 | 0
Fukusaki, Kobayashi, Hara et al., 1998 | 2 | 18 | Epidural Anesthetics | 13 | 5 | 0 | 0 | 0 | 69 | 9 | | | 2.73 | 2.27 | | | 0 | 0 | 0
Fukusaki, Kobayashi, Hara et al., 1998 | 3 | 19 | Epidural Anesthetics and Steroids | 13 | 6 | 0 | 0 | 0 | 72 | 7 | | | 3.13 | 2.63 | | | 0 | 0 | 0
Eskola, Pohjolainen, Alaranta et al., 1992 | 1 | 20 | Calcitonin Injections | 10 | 10 | 0 | 0 | 0 | 56.3 | | 26 | 74 | 68.4 | | 24 | 120 | 0 | 0 | 0 | 0
Eskola, Pohjolainen, Alaranta et al., 1992 | 2 | 19 | Calcitonin Injections | 10 | 9 | 0 | 0 | 0 | 55.7 | | 38 | 71 | 75.4 | | 24 | 144 | 0 | 0 | 0 | 0
Cuckler, Bernini, Wiesel et al., 1985 | 1 | 20 | Epidural Anesthetics and Steroids | 10 | 10 | 0 | | | 48.5 | 1.3 | | | 36.6 | 12.5
Cuckler, Bernini, Wiesel et al., 1985 | 2 | 17 | Epidural Anesthetics | 10 | 7 | 0 | | | 49.5 | 2.8 | | | 29.4 | 14.3
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 1 | 29 | Exercise/flexion | 12 | 14 | 3 | 0 | 3 | 44.5 | 14.5 | | | 46.8 | 70.8 | | | 0 | 0 | 0
Sinaki, Lutness, Ilstrup et al., 1989 | 2 | 19 | Exercise/extension | 6 | 12 | 1 | 1 | | 44.3 | 15.7 | | | 48 | 55.2 | | | 0 | 0 | 0
Trials Examining Surgical Patients with Central Lumbar Stenosis
Randomized controlled Trial
Grob, Humke, and Dvorak, 1995 | 1 | 15 | Partial laminectomy or hemilaminectomy | 6 | 9 | 0 | | | 66 | | 48 | 72 | 16 | | 6 | 37 | | | | 0
Grob, Humke, and Dvorak, 1995 | 2 | 15 | Partial laminectomy with fusion and instrumentation for single level | 10 | 5 | 0 | | | 71 | | 56 | 87 | 16 | | 6 | 37 | 15 | 0 | 1 | 0
Grob, Humke, and Dvorak, 1995 | 3 | 15 | Partial laminectomy with fusion and instrumentation for multiple levels | 5 | 10 | 0 | | | 71 | | 58 | 79 | 16 | | 6 | 37 | | 15 | | 0
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 1 | 35 | Mixed Decompression Techniques - no post-surgery stenosis | 16 | 19 | | | | 52.9 | | | | 40 | | | | | | | 0
Herno, Saari, Suomalainen et al., 1999 | 2 | 57 | Mixed Decompression Techniques - post-surgery stenosis | 28 | 29 | | | | 51.4 | | | | 2.4 | | | | | | | 0
Herno, Partanen, Talaslahti et al., 1999 | 1 | 41 | Standard Wide Decompressive Laminectomy post surgery stenosis | 25 | 16 | | | | 55.1 | | | | | | | | | | 1.7
Herno, Partanen, Talaslahti et al., 1999 | 2 | 15 | Standard Wide Decompressive Laminectomy no post surgery stenosis | 6 | 9 | | | | 52 | | | | | | | | | | 1.6
Hanakita, Suwa, and MIzuno, 1999 | 1 | 59 | Standard Wide Decompressive Laminectomy SWDL | | | | | | | | | 64
Hanakita, Suwa, and MIzuno, 1999 | 2 | 61 | Standard Wide Decompressive Laminectomy | | | | | | | | 65
Hanakita, Suwa, and MIzuno, 1999 | 3 | 16 | Partial laminectomy or hemilaminectomy | | | | | | | | | 64
Hanakita, Suwa, and MIzuno, 1999 | 4 | 20 | SWDL with Fusion Arthrodesis | | | | | | | | | 64
Thomas, Rea, Pikul et al., 1997 | 1 | 12 | Standard Wide Decompressive Laminectomy | | | | | | 68 | | 40 | 86 | | | | | | | | 0
Thomas, Rea, Pikul et al., 1997 | 2 | 14 | Laminotomy | | | | | | 68 | | 40 | 86 | | | | | | | | 0
Yone, Sakou, Kawauchi et al., 1996 | 1 | 10 | SWDL with Fusion and Instrumentation | 4 | 6 | | | | 68 | | 60 | 89 | | | | | 3 | 7 | 1.7
Yone, Sakou, Kawauchi et al., 1996 | 2 | 17 | Laminotomy | 12 | 5 | | | | 68 | | 60 | 78 | | | | | 5 | 12 | 2.2
Ray, 1982 | 1 | 48 | Standard Wide Decompressive Laminectomy | 30 | 18 | | | | 54.3 | | | | 173 | | | | 25 | 23 | 1.67
Ray, 1982 | 2 | 17 | Partial laminectomy or hemilaminectomy | 12 | 5 | | | | 45.5 | | | | 83 | | | | 9 | 8 | 1.65
Surin, Hedelin, and Smith, 1982 | 1 | 15 | Standard Wide Decompressive Laminectomy - marked stenosis | 13 | 9 | 0 | 0 | 0 | 64 | | 47 | 76 | | | | | 4 | 18
Surin, Hedelin, and Smith, 1982 | 2 | 7 | Standard Wide Decompressive Laminectomy - moderate stenosis | 13 | 9 | | | | 64 | | 47 | 76 | | | | | 4 | 18
Tajima, Fukazawa, and Ishio, 1980 | 1 | 13 | Mixed Decompression Techniques | 11 | 2 | | | | 46.9 | | 35 | 55 | | | | | 6 | 7 | 1.5
Tajima, Fukazawa, and Ishio, 1980 | 2 | 14 | Mixed Decompression Techniques - disk lesion | 12 | 2 | | | | 49.3 | | 35 | 55 | | | | | 9 | 5 | 1.4
Prospective Trials
Kleeman, Hiscoe, and Berg, 2000 | 1 | 54 | Partial Laminectomy | 30 | 24 | 6 | 0 | 6 | 71 | | 51 | 86 | | | | | 18 | 36 | 2.02 | 0
Weiner, Wlaker, Brower et al., 1999 | 1 | 30 | Partila Laminectomy | 14 | 16 | 0 | 0 | 0 | 68 | | 41 | 81 | 24 | | 3 | 96 | 9 | 21 | 2.07
diPierro, Helm, Shaffrey et al., 1996 | 1 | 35 | Hemilaminectomy and fusion | 11 | 18 | 6 | 0 | 6 | 64 | | 33 | 80 | | | | | 0 | 29 | 2.93 | 9
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 1 | 65 | Mixed Decompression Techniques | 22 | 43 | 4 | | 4 | 78 | | | | | | | | 15 | 50 | 2.5 | 20
Matsui, Kanamori, Ishihara et al., 1997 | 1 | 27 | SWDL with Fusion Arthrodesis | 20 | 7 | | | | 53.3 | | 37 | 69 | | | | | 0 | 27 | 3.2
Airaksinen, Herno, Turunen et al., 1997 | 1 | 497 | Standard Wide Decompressive Laminectomy | 255 | 183 | 59 | 33 | 26 | 53 | 10 | | | 84 | | | | | | 1.5 | 99
Mullin, Rea, Irsik et al., 1996 | 1 | 72 | Standard Wide Decompressive Laminectomy | 16 | 8 | 48 | | | 63.1 | 11.8 | 31 | 78
Ishac, Alhayek, Fournier et al., 1996 | 1 | 34 | Standard Wide Decompressive Laminectomy | 21 | 13 | 0 | | | 83 | | 80 | 87 | | | 6 | | 1 | 33 | 3
Jonsson and Stromqvist, 1994 | 1 | 43 | Partial laminectomy or hemilaminectomy | | | 3 | 1 | 2 | | | 71 | 84 | 48 | | | | 12 | 31 | 2.3 | 9
Caputy and Luessenhop, 1992 | 1 | 100 | Standard Wide Decompressive Laminectomy | 46 | 54 | | | | 67 | | 43 | 84 | 6 | | 1 | 144 | 21 | 79 | | 4
Dhar and Porter, 1992 | 1 | 36 | Standard Wide Decompressive Laminectomy
Chahal, Mundkur, Sancheti et al., 1982 | 1 | 32 | Standard Wide Decompressive Laminectomy | 22 | 10 | | | | 42.8 | | 21 | 70 | 51 | | 3 | 240 | 13 | 19 | 1.75
Rosomoff, 1981 | 1 | 50 | Standard Wide Decompressive Laminectomy | 20 | 30 | | | | | | 25 | 75 | | | 6 | 120 | 10 | 40 | 2.2 | 36
Getty, 1980 | 1 | 35 | Standard Wide Decompressive Laminectomy | 16 | 15 | 7 | 0 | 4 | 58 | | 30 | 75 | 69.6 | | | | | | 2.5
Reale, Deifini, Gambacona et al., 1978 | 1 | 37 | Standard Wide Decompressive Laminectomy - congenital stenosis | 27 | 10 | 4 | 0 | 4 | 52.5 | | 30 | 75
Verbiest, 1977 | 1 | 116 | Standard Wide Decompressive Laminectomy - congenital stenosis | | | 24 | 1 | 24 | | | 22 | 85
Case-series
Young, Veerapen, and O'Laoire, 1988 | 1 | 32 | Decompressive Surgery | 17 | 15 | | | | | | | | | | | | | | | 2
Kurihara, Tanaka, Tsumura et al., 1988 | 1 | 12 | Standard Wide Decompressive Laminectomy - hyperostotic stenosis | 6 | 6 | | | | 56 | | 42 | 72
Hall, Bartleson, Onofrio et al., 1985 | 1 | 68 | Standard Wide Decompressive Laminectomy | 53 | 15 | 6 | 3 | 3 | 63 | | 32 | 83 | 32 | | 1 | 120 | 3 | 65 | 3 | 0
Weinstein, Scafuri, and McNeill, 1983 | 1 | 24 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | | | | 3
Weir and De Leo, 1981 | 1 | 81 | Standard Wide Decompressive Laminectomy | 57 | 24 | | | | 53.3 | | 30 | 80
Johnsson, Willner, and Pettersson, 1981 | 1 | 27 | Standard Wide Decompressive Laminectomy | 22 | 5 | 0 | 0 | 0 | 61.3 | 9 | 48 | 80 | 25 | 22 | 1 | 84 | 4 | 23 | 2.4
Verbiest, 1979 | 1 | 11 | SWDL with Fusion Arthrodesis - congenital lumbar stenosis | 3 | 8 | | | | 19.3 | 10.5 | 11 | 42 | | | | | 7 | 4 | 1.45
Salibi, 1976 | 1 | 19 | Standard wide laminectomy 16 patients and unilateral laminectomy 3 patients | 17 | 3 | 1 | | | 60 | | 36 | 76 | | | | | 3 | 17 | | 2
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized controlled Trial
Lee and deBari, 1986 | 1 | 12 | SWDL with Fusion Arthrodesis | | | | | | 45.7 | | 28 | 65 | | | | | | 12
Lee and deBari, 1986 | 2 | 12 | SWDL with Fusion and Instrumentation | | | | | | 45.7 | | 28 | 65 | | | | | | 12
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 1 | 20 | Partial laminectomy or hemilaminectomy | | | 5 | | | 46 | | 41 | 52 | 132 | | 108 | 156 | | | | 0
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 2 | 32 | Partial laminectomy or hemilaminectomy - with disk herniation | | | 6 | | | 46 | | 41 | 52 | 132 | | 108 | 156 | | | | 0
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 3 | 21 | Partial laminectomy or hemilaminectomy - Lateral and Central Stenosis | | | 3 | | | 46 | | 41 | 52 | 132 | | 108 | 156 | | | | 0
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 4 | 21 | Partial laminectomy or hemilaminectomy - Lateral and Central Stenosis and disk herniation | | | | | | 46 | | 41 | 52 | 132 | | 108 | 156 | | | | 0
Mikhael, Ciric, Tarkington et al., 1981 | 1 | 35 | Standard Wide Decompressive Laminectomy | | | | | | 51 | | | | 48 | | 6 | 120
Mikhael, Ciric, Tarkington et al., 1981 | 2 | 50 | Control/Placebo/None | | | | | | 51
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 1 | 66 | Laminotomy | 24 | 33 | 9 | 3 | 6 | 56 | | 36 | 74 | 65 | | 6 | 180 | 51 | 6 | 1.1
Baba, Uchida, Maezawa et al., 1996 | 1 | 31 | Laminotomy | 19 | 12 | | | | 49.1 | | 37 | 76 | | | | | 31 | | 1
Aryanpur and Ducker, 1990 | 1 | 32 | Laminotomy | 8 | 24 | | | | 66 | | 31 | 83 | | | | | 9 | 23 | 2 | 0
Case-series
Choudhury and Taylor, 1977 | 1 | 28 | Standard Wide Decompressive Laminectomy | 19 | 9 | | | | | | 17 | 61
Epstein, Epstein, Rosenthal et al., 1972 | 1 | 15 | Foraminotomy/nerve root decompression | 8 | 7 | | | | | | 17 | 51
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Controlled Trial
Yone and Sakou, 1999 | 1 | 14 | Laminotomy - patients with instability | 10 | 4 | | | | 63 | | 45 | 79 | | | | | 6 | 8 | 1.93
Yone and Sakou, 1999 | 2 | 19 | Laminotomy with Fusion and Instrumentation - patients with instability | 12 | 7 | | | | 61 | | 55 | 76 | | | | | 11 | 8 | 1.58
Yone and Sakou, 1999 | 3 | 27 | Laminotomy - patients without instability | 17 | 10 | | | | 58 | | 32 | 76 | | | | | 5 | 22 | 2.15
Epstein, 1999 | 1 | 10 | Standard Wide Decompressive Laminectomy - patients with Ossification of the Posterior Longitudinal Ligament | 5 | 5 | | | | 62.5 | 13.2 | 38 | 77 | | | | | 1 | 9 | 3.2
Epstein, 1999 | 2 | 11 | Standard Wide Decompressive Laminectomy - patients with Ossification of the Yellow Ligament | 4 | 7 | | | | 69.2 | 7.7 | 52 | 78 | | | | | 4 | 7 | 3.36
Javid and Hadar, 1998 | 1 | 86 | Standard Wide Decompressive Laminectomy - patients with central stenosis | 43 | 43 | | | | 64.7 | | 27 | 89 | 42 | | | | | | 2.5 | 0
Javid and Hadar, 1998 | 2 | 61 | Standard Wide Decompressive Laminectomy - patients with central stenosis and herniated disks | 39 | 22 | | | | 59.1 | | 23 | 82 | 79 | | | | | | 2.16 | 0
Javid and Hadar, 1998 | 3 | 23 | Standard Wide Decompressive Laminectomy - patients with lateral stenosis | 14 | 9 | | | | 53.6 | | 25 | 79 | 38 | | | | | | | 0
Kalbarczyk, Lukes, and Seiler, 1998 | 1 | 93 | Standard Wide Decompressive Laminectomy - patients without instability | | | 0 | | | 76 | | 70 | 88
Kalbarczyk, Lukes, and Seiler, 1998 | 2 | 46 | Partial laminectomy or hemilaminectomy - patients with mild instability | | | 0 | | | 76 | | 70 | 88
Kalbarczyk, Lukes, and Seiler, 1998 | 3 | 9 | Partial laminectomy and fusion - patients with high instability | | | 1 | 1 | | 76 | | 70 | 88
Pai and Kumar, 1996 | 1 | 30 | Decompressive Surgery - patients with congenital stenosis | | | | | | 36
Pai and Kumar, 1996 | 2 | 23 | Decompressive Surgery - patients with degenerative stenosis | | | | | | 52
Kawauchi, Yone, and Sakou, 1996 | 1 | 7 | Partial laminectomy and fusion - patients with slight adhesions | 24 | 12 | 0 | 0 | 0 | 60.6 | | 39 | 78 | 46 | | 2 | 132 | 7 | 0 | 1 | 0
Kawauchi, Yone, and Sakou, 1996 | 2 | 16 | Partial laminectomy and fusion- patients with moderate adhesions | 24 | 12 | 0 | 0 | 0 | 60.6 | | 39 | 78 | 46 | | 2 | 132 | 16 | 0 | 1 | 0
Kawauchi, Yone, and Sakou, 1996 | 3 | 13 | Partial laminectomy and fusion- patients with marked adhesions | 24 | 12 | 0 | 0 | 0 | 60.6 | | 39 | 78 | 46 | | 2 | 132 | 13 | 0 | 1 | 0
Cinotti, Postacchini, and Weinstein, 1994 | 1 | 25 | Standard Wide Decompressive Laminectomy - patients with diabetes | 14 | 11 | 0 | | | 68 | | 37 | 84 | 19
Cinotti, Postacchini, and Weinstein, 1994 | 2 | 25 | Standard Wide Decompressive Laminectomy - patients without diabetes | 13 | 12 | 0 | | | 71 | | 58 | 84 | 16
Little and MacDonald, 1994 | 1 | 60 | SWDL with Fusion Arthrodesis | | | | | | 50.6
Little and MacDonald, 1994 | 2 | 34 | SWDL with Fusion Arthrodesis | | | | | | 50.6
Simpson, Silveri, Balderston et al., 1993 | 1 | 33 | Standard Wide Decompressive Laminectomy - patients with diabetes | | | 9 | | | 63 | | 32 | 84
Simpson, Silveri, Balderston et al., 1993 | 2 | 24 | Standard Wide Decompressive Laminectomy - patients without diabetes | | | 2 | | | 63 | | 32 | 84
Jonsson and Stromqvist, 1993a | 1 | 20 | Partial laminectomy or hemilaminectomy - patients with central stenosis | | | 1 | 1 | 0 | | | | | | | | | | | | 20
Jonsson and Stromqvist, 1993a | 2 | 19 | Partial laminectomy or hemilaminectomy - patients with lateral stenosis | | | 1 | 1 | | | | | | | | | | | | | 19
Nasca, 1989 | 1 | 15 | Decompressive Surgery -patients with lateral lumbar stenosis | 9 | 6 | | | | 47
Nasca, 1989 | 2 | 29 | Decompressive Surgery - patients with central or combined lumbar stenosis | | | | | | | | | | | | | | 23 | 6
Nasca, 1989 | 3 | 16 | Decompressive Surgery with fusion and instrumentation - patients with central or combined lumbar stenosis | 9 | 7 | | | | 56 | | | | | | | | 7 | 9
Nasca, 1989 | 4 | 21 | Decompressive Surgery - patients with postsurgical stenosis
Nasca, 1989 | 5 | 22 | Decompressive Surgery with fusion and instrumentation - patients with instability | 10 | 12 | | | | 55
Nasca, 1989 | 6 | 11 | Decompressive Surgery with fusion and instrumentation - patients with degenerative stenosis and scoliosis | 0 | 11 | | | | 63
Nather and Thomas, 1985 | 1 | 11 | Decompressive surgery with or without fusion - patients with degenerative lumbar stenosis
Nather and Thomas, 1985 | 2 | 14 | Decompressive surgery with or without fusion - patients with combined degenerative and congenital lumbar stenosis
Paine, 1976 | 1 | 95 | Standard Wide Decompressive Laminectomy - patients with degenerative stenosis | | | | | | | | | | | | | | 39 | 56 | | 10
Paine, 1976 | 2 | 48 | Standard Wide Decompressive Laminectomy- patients with degenerative stenosis and disk herniation
Shenkin and Hash, 1976 | 1 | 49 | Standard Wide Decompressive Laminectomy - patients with no prior surgery | 27 | 22 | 3 | | 3 | 59.4 | | 45 | 84 | | | | | | | | 0
Shenkin and Hash, 1976 | 2 | 21 | Standard Wide Decompressive Laminectomy - patients with prior surgery for herniated disk | 11 | 10 | 0 | | | 55.7 | | 33 | 75 | | | | | | | | 21
Tile, McNeil, Zarins et al., 1976 | 1 | 26 | Mixed Decompression Techniques - patients with lumbar stenosis
Tile, McNeil, Zarins et al., 1976 | 2 | 18 | Standard Wide Decompressive Laminectomy - patients with congenital stenosis
Retrospective Trial with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 1 | 34 | Partial laminectomy or hemilaminectomy | 15 | 19 | 0 | | | 64 | | 29 | 88 | 53 | | 24 | | 0 | 34 | 3.5 | 60
Silvers, Lewis, and Asch, 1993 | 1 | 248 | Standard Wide Decompressive Laminectomy | 97 | 147 | 4 | 4 | 0 | 65 | 0.6 | 30 | 87 | 21.6 | 3.3 | 0 | 480 | 108 | 140 | 1.82 | 47
Katz, Lipson, Larson et al., 1991 | 1 | 88 | Mixed Decompression Techniques | 26 | 62 | 18 | 8 | 10 | 69.3 | | 55 | 89 | 19 | | | | 16 | 72 | 2.4 | 0
Ganz, 1990 | 1 | 36 | Standard Wide Decompressive Laminectomy | 29 | 4 | 3 | 1 | 1 | 57 | 14.7 | 21 | 84 | | | | | | | 2.5
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 1 | 70 | Decompressive Surgery with fusion and instrumentation | | | | | | 46 | 13.1 | | | | | | | 0
Guigui, Benoist, Delecourt et al., 1998 | 1 | 50 | Decompressive surgery | 22 | 28 | | | | 60 | | 31 | 85 | | | | | 14 | 36 | 2.26
Scholz, Firsching, and Lanksch, 1998 | 1 | 72 | Decompressive Surgery | 32 | 40 | | | | 59.7 | | | | 72
Tsai, Yang, and Bray, 1998 | 1 | 62 | Laminotomy | 31 | 19 | 12 | | | 66 | | 35 | 85 | 79 | | 1 | 480 | 13 | 37 | 1.88 | 0
Mackay and Wheelwright, 1998 | 1 | 50 | Partial laminectomy or hemilaminectomy | 24 | 26 | 2 | 2 | | 61 | | 36 | 81 | 33.6 | | 6 | 240 | 23 | 27 | 1.6
Whitecloud, Castro Jr, Brinker et al., 1998 | 1 | 35 | SWDL with Fusion and Instrumentation | 19 | 16 | | | | 45.3 | 11.2 | 26 | 76 | | | | | 13 | 22 | 1.8 | 29
Spetzger, Bertalanffy, Reinges et al., 1997 | 1 | 29 | Laminotomy | 14 | 15 | 4 | | 4 | 62 | | 34 | 83 | 42 | | 3 | 180 | 22 | 7 | 1.28
Katz, Lipson, Chang et al., 1996 | 1 | 88 | Standard Wide Decompressive Laminectomy | | | 33 | 20 | 13 | 69.3 | | 55 | 88 | | | | | 16 | 72 | 2.38
Lehto and Honkanen, 1995 | 1 | 96 | Decompressive Surgery | 46 | 50 | 31 | 7 | 24 | 59 | | 26 | 87 | 2.7 | | 2 | 16 | 59 | 37 | 1.48 | 41
Stucki, Liang, Fossel et al., 1995 | 1 | 203 | Decompressive Surgery | 46 | 84 | 100 | | | 68 | 9.1
Tuite, Stern, Doran et al., 1994 | 1 | 119 | Standard Wide Decompressive Laminectomy | 63 | 56 | | | | 61.8 | 11 | 46 | 80 | | | 6 | 60 | | | 2.5 | 0
McCullen, Bernini, Bernstein et al., 1994 | 1 | 193 | Decompressive Surgery | 42 | 76 | 75 | | 75 | 69 | | 46 | 91 | 39 | | 11 | 480 | 9 | 109 | 2.81 | 23
Simmons and Simmons, 1992 | 1 | 40 | SWDL with Fusion and Instrumentation | 15 | 25 | 0 | | | 61.5 | | 38 | 77
Mauersberger and Nietgen, 1989 | 1 | 92 | Decompressive surgery with or without fusion | | | 26 | 4 | 9 | | | | | | | 1 | 360 | 49 | 43
Johnsson, Redlund-Johnell, Uden et al., 1989 | 1 | 61 | Standard Wide Decompressive Laminectomy | 40 | 21 | | 1 | | 65 | | 38 | 80 | 27 | 30 | 1 | 180
Brodsky, Hendricks, Khalil et al., 1989 | 1 | 34 | Fusion | | | 2
Jalovaara, Lahde, Iikko et al., 1989 | 1 | 31 | Standard Wide Decompressive Laminectomy | 19 | 12 | 0 | 0 | 0 | 52 | | 37 | 79 | 72 | | 12 | 120 | 14 | 17 | 1.8 | 0
Fast, Robin, and Floman, 1985 | 1 | 19 | Standard Wide Decompressive Laminectomy | 9 | 10 | | | | 67 | | 50 | 80 | | | 1 | 240 | 0
Boccanera, Pellicioni, and Laus, 1984 | 1 | 25 | Standard Wide Decompressive Laminectomy | 18 | 7 | | | | 61 | | 49 | 73 | | | | | | | | 6
Hood and Weigl, 1983 | 1 | 21 | Standard Wide Decompressive Laminectomy | 15 | 6 | 1 | 1 | | | | 50 | 75 | | | 60 | 360 | 0 | 20 | 3.4
Scafuri and Weinstein, 1981 | 1 | 27 | Standard Wide Decompressive Laminectomy | 12 | 15 | 2 | | | 57.1 | | 26 | 75 | 116 | | 2 | 456 | 8 | 17 | 3.12
Echeverria and Lockwood, 1979 | 1 | 35 | Standard Wide Decompressive Laminectomy | 27 | 8 | 15 | | 8 | 57.5 | | 28 | 82 | 36 | | 12 | 240 | | | | 10
Scapinelli, 1978 | 1 | 23 | Standard Wide Decompressive Laminectomy | | | 0 | 0 | 0 | | | 25 | 60
Vestad and Naca, 1977 | 1 | 80 | Standard Wide Decompressive Laminectomy | | | | | | 39.6 | | 15 | 65
McKinley and Davis, 1976 | 1 | 32 | Standard Wide Decompressive Laminectomy | 15 | 17 | 14 | | | 51 | | 17 | 75 | 49 | | | | 32 | | 1
Teng and Papatheodorou, 1963 | 1 | 29 | SWDL-Standard Wide Decompressive Laminectomy | 22 | 8 | | | | | | 37 | 72 | | | 0 | 240 | 2 | | 2.7
Epstein, Epstein, and Lavine, 1962 | 1 | 29 | Mixed Decompression Techniques | 15 | 14
Epstein, 1960 | 1 | 14 | Standard Wide Decompressive Laminectomy | 8 | 6 | | | | | | 29 | 66 | | | 1 | 480
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trial
Fischgrund, Mackay, Herkowitz et al., 1997 | 1 | 40 | SWDL with Fusion and Instrumentation | 7 | 28 | 5 | | 5 | 69 | | 53 | 86 | | | | | 35 | | 1 | 0
Fischgrund, Mackay, Herkowitz et al., 1997 | 2 | 35 | SWDL with Fusion Arthrodesis | 6 | 27 | 2 | | 2 | 66 | | 52 | 80 | | | | | 35 | | 1 | 0
Thomsen, Christensen, Eiskjaer et al., 1997 | 1 | 20 | Partial laminectomy with fusion and instrumentation | | | | | | 46 | | 20 | 67
Thomsen, Christensen, Eiskjaer et al., 1997 | 2 | 21 | Partial laminectomy and fusion | | | | | | 43.5 | | 20 | 66
Bridwell, Sedgewick, O'Brien et al., 1993 | 1 | 9 | Partial laminectomy or hemilaminectomy | 2 | 7 | 0 | | | 72.3 | | | | | | | | 9 | | 1 | 0
Bridwell, Sedgewick, O'Brien et al., 1993 | 2 | 10 | Partial laminectomy and fusion | 4 | 6 | 0 | | | 65.6 | | | | | | | | 10 | | 1 | 0
Bridwell, Sedgewick, O'Brien et al., 1993 | 3 | 24 | Partial laminectomy with fusion and instrumentation | 4 | 24 | 0 | | | 64.2 | | | | | | | | 23 | 1 | 1.04 | 0
Herkowitz and Kurz, 1991 | 1 | 25 | SWDL-Standard Wide Decompressive Laminectomy | 9 | 16 | 0 | | | 65 | | 53 | 83 | | | | | 25 | | 1
Herkowitz and Kurz, 1991 | 2 | 25 | SWDL with Fusion Arthrodesis | 5 | 20 | 0 | | | 63.5 | | 52 | 84 | | | | | 25 | | 1
Controlled Trials
Plotz and Benini, 1998 | 1 | 17 | Decompressive Surgery without fusion | 2 | 15 | | | | 64 | | 45 | 85
Plotz and Benini, 1998 | 2 | 18 | Decompressive Surgery with fusion and Translaminar Screw Fixation | 8 | 10 | | | | 67 | | 57 | 83
Plotz and Benini, 1998 | 3 | 71 | Decompressive Surgery with fusion and AO Internal Fixator | 2 | 15 | | | | 67 | | 45 | 83
Yuan, Garfin, Dickman et al., 1994 | 1 | 2177 | Fusion and Pedical Screw Fixation | 817 | 1360 | | | | 57.8 | | | | | | | | 1868 | 309 | 1.1 | 738
Yuan, Garfin, Dickman et al., 1994 | 2 | 456 | Fusion | 140 | 316 | | | | 61.3 | | | | | | | | 415 | 41 | 1.1 | 92
Satomi, Hirabayashi, Toyama et al., 1992 | 1 | 27 | Fusion and instrumentation | | | 0 | | | 51.1 | | 36 | 65 | 46
Satomi, Hirabayashi, Toyama et al., 1992 | 2 | 14 | Mixed Decompression Techniques | | | 0 | | | 68.6 | | 60 | 81 | 104
Lombardi, Wiltse, Reynolds et al., 1985 | 1 | 20 | SWDL-Standard Wide Decompressive Laminectomy | | | | | | 65 | | 49 | 81
Lombardi, Wiltse, Reynolds et al., 1985 | 2 | 21 | SWDL with Fusion Arthrodesis | | | | | | 65 | | 49 | 81
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 1 | 23 | Fusion only | 2 | 16 | 5 | | 2 | 52.8 | 7.4 | 42 | 68 | | | | | 23 | | 1
Rechtine, Sutterlin, Wood et al., 1996 | 1 | 18 | SWDL with Fusion and Instrumentation | 4 | 14 | 0 | | | 55 | 13.4 | 33 | 74 | | | | | 10 | 8 | 1.67 | 14
Retrospective Trial with Consecutive Patients
Stambough, 1999 | 1 | 35 | SWDL with Fusion and Instrumentation | | | | | | 52.2 | | 18 | 85
Nishizawa and Fujimura, 1997 | 1 | 58 | Fusion and instrumentation | 13 | 45 | 0 | | | 53 | | 28 | 68 | | | | | 56 | 2 | 1.03
Moller, Wittenberg, Nolte et al., 1992 | 1 | 37 | Fusion | | | | | | 42.8 | | 21 | 62 | | | | | 37 | | 1
Marchesi, Thalgott, and Aebi, 1991 | 1 | 30 | SWDL with Fusion and Instrumentation | 18 | 12 | | | | 45.8 | | 13 | 71
Takahashi, Kitahara, Yamagata et al., 1990 | 1 | 39 | Fusion | 5 | 34 | 4 | 3 | 1 | 51 | | 34 | 74 | | | | | 29 | 10 | 1.3
Knox, Harvell, Nelson et al., 1989 | 1 | 39 | SWDL with Fusion and Instrumentation | 15 | 24 | 15 | | 3 | 64 | | 53 | 80 | 24 | | 3 | 80 | 20 | 4 | 1.16 | 3
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 1 | 49 | Partial laminectomy with fusion and instrumentation | 12 | 29 | 13 | 8 | 5 | 66.7 | | 52 | 79 | | | | | | | 1.27 | 0
McCulloch, 1998 | 1 | 21 | Partial laminectomy and fusion | 6 | 15 | 2 | 1 | 1 | 65 | | 51 | 79 | | | | | 14 | 7 | 1.33
Epstein, 1998b | 1 | 28 | SWDL with Fusion and Instrumentation | 15 | 13 | | | | 64 | | 38 | 82 | | | | | 0 | 28 | 4
Mochida, Toh, Suzuki et al., 1997 | 1 | 10 | Partial laminectomy with fusion and instrumentation | 4 | 6 | | | | 56.5 | 6.8 | 48 | 66 | | | | | 10 | 0 | 1
Epstein, 1998a | 1 | 290 | Mixed Decompression Techniques | 94 | 196 | | | | 67 | | 38 | 82 | | | | | | | 3.2
Grob, Humke, and Dvorak, 1996 | 1 | 18 | SWDL with Fusion and Instrumentation | 5 | 13 | 2 | 1 | 1 | 54 | | 35 | 77 | | | 24 | 60 | 18 | 0 | 1
Herron and Trippi, 1989 | 1 | 24 | Standard Wide Decompressive Laminectomy | 5 | 19 | | | | 67 | | 52 | 87 | 15 | | 3 | 72 | 14 | 10 | 1.46 | 1
Chang and McAfee, 1989 | 1 | 17 | SWDL with Fusion and Instrumentation | 5 | 12 | | | | 59.4 | | 44 | 73
Inoue, Watanabe, Goto et al., 1988 | 1 | 36 | Fusion | 6 | 30 | | | | 48.1 | | 34 | 60
Simmons and Capicotto, 1988 | 1 | 15 | SWDL with Fusion and Instrumentation | | | | | | 64 | | 56 | 70
Hanley, 1986 | 1 | 20 | SWDL with Fusion and Instrumentation | 2 | 18 | | | | 58.2 | | 39 | 75 | | | | | 20 | | 1 | 0
Kaneda and Kazama, 1986 | 1 | 54 | SWDL with Fusion and Instrumentation | 21 | 33 | | | | 53 | | 40 | 75 | | | | | 29 | 25 | 1.5
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 1 | 50 | Standard Wide Decompressive Laminectomy | 12 | 38 | 9 | 1 | 3 | 66 | | 47 | 87 | | | | | 49 | 1 | 1.04 | 8
Dall and Rowe, 1985 | 1 | 26 | SWDL-Standard Wide Decompressive Laminectomy | 4 | 13 | 9 | 4 | 5 | 60.5 | | 47 | 73 | | | 1 | 300 | 12 | 5 | 1.4 | 4
Epstein, Epstein, Carras et al., 1983 | 1 | 60 | Mixed Decompression Techniques | 20 | 40 | | | | 65 | | 44 | 90 | 48 | | 2 | 600 | 20 | 40 | | 4
Richardson and Brown, 1980 | 1 | 21 | SWDL with Fusion Arthrodesis | 18 | 3 | 0
Cauchoix, Benoist, and Chassaing, 1976 | 1 | 26 | SWDL-Standard Wide Decompressive Laminectomy | 8 | 18 | | | | | | 50 | 84 | | | | | 7 | 19 | 1.96
Epstein, Epstein, Lavine et al., 1976 | 1 | 20 | Mixed Decompression Techniques | 3 | 17 | 5 | | | | | 45 | 84 | | | 18 | 240
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
Controlled Trial
Rompe, Eysel, Zollner et al., 1999 | 1 | 39 | Partial laminectomy or hemilaminectomy - patients with central lumbar stenosis | 19 | 20 | 14 | | | 63 | 8.1 | | | 21 | 6.6 | | | | | 1.5 | 0
Rompe, Eysel, Zollner et al., 1999 | 2 | 51 | SWDL-Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | 27 | 24 | 25 | | | 59 | 7.9 | | | 20 | 5 | | | | | 1.5 | 0
Rompe, Eysel, Zollner et al., 1999 | 3 | 27 | SWDL with Fusion and Instrumentation - patients with degenerative spondylolisthesis | 14 | 13 | 6 | | | 64 | 8.8 | | | 30 | 6 | | | | | 1.6 | 0
Katz, Lipson, Lew et al., 1997 | 1 | 194 | Standard Wide Decompressive Laminectomy | 91 | 103 | | | | 70 | 8.1 | | | 30 | 28 | | | | | 2.6 | 0
Katz, Lipson, Lew et al., 1997 | 2 | 37 | SWDL with Fusion Arthrodesis | 10 | 27 | | | | 64 | 9.2 | | | 27 | 30 | | | | | 2 | 0
Katz, Lipson, Lew et al., 1997 | 3 | 41 | SWDL with Fusion and Instrumentation | 9 | 32 | | | | 66 | 8.7 | | | 33 | 29 | | | | | 1.8 | 0
Sato and Kikuchi, 1997 | 1 | 28 | Laminotomy - 2 level stenosis | 19 | 9 | | | | 64 | | | | 25.2 | | | | 28 | 0 | 1
Sato and Kikuchi, 1997 | 2 | 53 | Laminotomy - 1 level stenosis | 28 | 25 | | | | 64 | | | | 25.2 | | | | 53 | 0 | 1
Rompe, Eysel, Hopf et al., 1995 | 1 | 24 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis | 13 | 11 | 0 | 0 | 0 | 58.9 | | 45 | 79 | 56.4 | | 9 | 180 | 19 | 5 | 1.7 | 0
Rompe, Eysel, Hopf et al., 1995 | 2 | 24 | Standard Wide Decompressive Laminectomy - patients with lumbar stenosis | 12 | 12 | 0 | 0 | 0 | 65.6 | | 46 | 86 | 56.4 | | 9 | 180 | 15 | 9 | 1.3 | 0
Rompe, Eysel, Hopf et al., 1995 | 3 | 12 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis and spondylolisthesis | 6 | 6 | 0 | 0 | 0 | 65.1 | | 50 | 74 | 56.4 | | 9 | 180 | | | 2.1 | 0
Sanderson and Wood, 1993 | 1 | 19 | Partial laminectomy or hemilaminectomy - patients with Degenerative Spondylolisthesis | 5 | 14 | | | | 72.2 | | 65 | 81 | 96 | | 12 | 192 | 19 | 0 | 1
Sanderson and Wood, 1993 | 2 | 12 | SWDL-Standard Wide Decompressive Laminectomy - patients with lumbar spinal stenosis | 8 | 4 | | | | 72.2 | | 65 | 81 | 96 | | 12 | 192 | 9 | 3 | 1.3
Robertson, Grobler, Novotny et al., 1993 | 1 | 22 | SWDL-Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | | | | | | 69.7 | 8.2 | 56 | 90 | | | | | 22 | | 1
Robertson, Grobler, Novotny et al., 1993 | 2 | 11 | SWDL-Standard Wide Decompressive Laminectomy - patients with degenerative spondylolisthesis | | | | | | 69.7 | 8.2 | 56 | 90 | | | | | 11 | | 1
Postacchini, Cinotti, Perugia et al., 1993 | 1 | 26 | Laminotomy - patients with congenital or degenerative stenosis, combined, or degenerative spondylolisthesis | | | | | | 57 | | 43 | 79 | | | | | 12 | 14 | 1.7
Postacchini, Cinotti, Perugia et al., 1993 | 2 | 41 | Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | | | | | | 57 | | 43 | 79 | | | | | 19 | 22 | 1.7
Hirabayashi, Kumano, and Kuroki, 1991 | 1 | 32 | SWDL with Fusion and Instrumentation - patients with degenerative spondylolisthesis | | | | | | 53 | | 19 | 76 | | | | | 30 | 2 | 1.1
Hirabayashi, Kumano, and Kuroki, 1991 | 2 | 21 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis | | | | | | 53 | | 19 | 76 | | | | | 10 | 11 | 1.8
Herkowitz and Garfin, 1989 | 1 | 58 | Standard Wide Decompressive Laminectomy - patients with degenerative stenosis
Herkowitz and Garfin, 1989 | 2 | 41 | Standard Wide Decompressive Laminectomy - patients with degenerative spondylolisthesis
Prospective Trial
Jonsson, Annertz, Sjoberg et al., 1997a | 1 | 105 | Partial laminectomy or hemilaminectomy - patients with Central Spinal Stenosis and Degenerative Spondylolisthesis | 60 | 45 | 17 | 15 | 2 | 65 | | 37 | 83 | 57 | | 1 | 480 | 21 | 84 | 2.2
Postacchini and Conotti, 1992 | 1 | 88 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined, with or without Spondylolisthesis | 24 | 16 | 48 | | | 54 | | 38 | 71
Retrospective Trial with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 1 | 80 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined stenosis, or degenerative or isthmic spondylolisthesis | 30 | 18 | 32 | | | 65 | | 40 | 75 | | | | | 20 | 28 | 2
Postacchini, Cinotti, Gumina et al., 1993 | 1 | 64 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined, with or without spondylolisthesis | 38 | 26
Case-series
Guigui, Barre, Benoist et al., 1999 | 1 | 28 | SWDL-Standard Wide Decompressive Laminectomy | 8 | 15 | 5 | | 5 | 53 | | 31 | 79 | | | | | 7 | 16 | 2.2
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 1 | 40 | Conservative - various treatments | 13 | 27 | 6 | 1 | 5 | 72 | | 53 | 87 | | | | | 13 | 27 | 2.1 | 0
Simotas, Dorey, Hansraj et al., 2000 | 2 | 9 | Surgery - not described | 2 | 7 | 0 | 0 | 0 | 67 | | 58 | 80 | | | | | 0 | 9 | 2.6
Mariconda, Zanforlino, Celestino et al., 2000 | 1 | 20 | Standard Wide Decompressive Laminectomy | 8 | 12 | 0 | | | 61 | | 41 | 83 | 42 | | | | 6 | 14 | 2 | 0
Mariconda, Zanforlino, Celestino et al., 2000 | 2 | 17 | Untreated | 6 | 11 | 0 | | | 61 | | 41 | 83 | 42 | | | | 6 | 11 | 1.7 | 0
Johnsson, Uden, and Rosen, 1991 | 1 | 20 | Conservative-not described | 15 | 5 | 1 | 0 | | 60 | 9 | 42 | 80 | 22 | 24 | 4 | 96 | 0 | 0 | 0 | 0
Johnsson, Uden, and Rosen, 1991 | 2 | 30 | Standard Wide Decompressive Laminectomy - patients with moderate stenosis | | | | | | 62 | 9 | 45 | 78 | 33 | 35 | 2 | 180 | | | | 0
Johnsson, Uden, and Rosen, 1991 | 3 | 14 | Standard Wide Decompressive Laminectomy - patients with severe stenosis | | | | | | 69 | 8 | 55 | 80 | 26 | 20 | 4 | 72 | | | | 0
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen T, Weber H, Nordal HJ et al., 2000 | 1 | 19 | SWDL-Standard Wide Decompressive Laminectomy | 11 | 8 | 2 | 2 | 0 | | | 21 | 71 | | | | | | | | 0
Amundsen T, Weber H, Nordal HJ et al., 2000 | 2 | 50 | Conservative - various | 27 | 23 | 19 | 9 | 0 | | | 16 | 71 | | | | | | | | 0
Amundsen T, Weber H, Nordal HJ et al., 2000 | 3 | 13 | SWDL-Standard Wide Decompressive Laminectomy | 9 | 4 | 2 | 2 | 0 | | | 21 | 71 | | | | | | | | 0
Amundsen T, Weber H, Nordal HJ et al., 2000 | 4 | 18 | Conservative - various | 7 | 11 | 10 | 1 | 0 | | | 21 | 71 | | | | | | | | 0
Hurri, Slatis, Soini et al., 1998 | 1 | 57 | SWDL-Standard Wide Decompressive Laminectomy | | | 0 | 0 | 0 | 50 | 11 | | | | | | | | | | 12
Hurri, Slatis, Soini et al., 1998 | 2 | 18 | Conservative-not described | | | 0 | 0 | 0 | 47 | 10 | | | | | | | | | | 4
Atlas, Deyo, Keller et al., 1996 | 1 | 81 | SWDL-Standard Wide Decompressive Laminectomy | 24 | 57 | 9 | | 9 | 67.6 | | 30 | 87 | | | | | | | | 0
Atlas, Deyo, Keller et al., 1996 | 2 | 67 | Conservative-many | 27 | 40 | 9 | | 9 | 65.3 | | 22 | 89 | | | | | | | | 0
Atlas, Keller, Robson et al., 2000 | 1 | 67 | SWDL-Standard Wide Decompressive Laminectomy | Four year followup to Atlas, Deyo, Keller et al., 1996
Atlas, Keller, Robson et al., 2000 | 2 | 52 | Conservative-many | Four year followup to Atlas, Deyo, Keller et al., 1996
Swezey, 1996 | 1 | 12 | Exercise/stretching and flexibility | | | 0 | 0 | | 76 | | 61 | 90 | 96 | | 6 | 276
Swezey, 1996 | 2 | 11 | Physical Therapy/massage, ultrasound, heat, ice, traction | | | 0 | 0 | | 76 | | 61 | 90 | 96 | | 6 | 276
Swezey, 1996 | 3 | 13 | Epidural Steroid Injections | | | 0 | 0 | | 76 | | 61 | 90 | 96 | | 6 | 276
Swezey, 1996 | 4 | 11 | Standard Wide Decompressive Laminectomy | 7 | 4 | 0 | 0 | | 76 | | 61 | 90 | 96 | | 6 | 276
Nagler and Bodack, 1993 | 1 | 41 | Conservative-various | 17 | 24 | | | | 56.4 | | 26 | 82
Nagler and Bodack, 1993 | 2 | 39 | Standard Wide Decompressive Laminectomy | 17 | 22 | | | | 57.4 | | 28 | 78
Herno, Airaksinen, Saari et al., 1996 | 1 | 54 | Conservative-not described | 33 | 21 | | | | 54 | 9 | 30 | 73 | 52 | 18 | 1 | 480
Herno, Airaksinen, Saari et al., 1996 | Data from surgical patients used for comparison were obtained from a larger previously published study.
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 1 | 29 | Rigid Brace | | | | | | 61 | | 43 | 74
Fitzgerald and Newman, 1976 | 2 | 14 | Mixed Decompression Techniques | | | | | | 61 | | 43 | 74
Rosenberg, 1976 | 1 | 11 | Partial laminectomy or hemilaminectomy | | | | | | 61 | | 44 | 89
Rosenberg, 1976 | 2 | 15 | Standard Wide Decompressive Laminectomy | | | | | | 61 | | 44 | 89
Rosenberg, 1976 | 3 | 170 | Conservative-not described | | | | | | 61 | | 44 | 89

Evidence Table 11. Patient Signs and Symptoms for Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized controlled Trials of Patients Receiving Conservative Treatments
First Author and Year of Publication | Patient Group | N | Treatment | Back Pain | | | Leg Pain | | | Back and Leg Pain | | | Leg Weakness | | | Neurogenic Claudication | | | Sensory Dysfunction | | | Relief of Pain by Flexion | Incontinence | Extent of Stenosis
Total | Bilateral | Unilateral | Total | Bilateral | Unilateral | Total | Bilateral | Unilateral | Total | Bilateral | Unilateral | Total | Bilateral | Unilateral | Total | Bilateral | Unilateral | Mild | Moderate | Severe
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis type of stenosis unspecified or includes both types of stenosis
Fukusaki, Kobayashi, Hara et al., 1998 | 1 | 16 | Epidural Saline | | | | 16 | | | | | | | | | 16
Fukusaki, Kobayashi, Hara et al., 1998 | 2 | 18 | Epidural Anesthetics | | | | 18 | | | | | | | | | 18
Fukusaki, Kobayashi, Hara et al., 1998 | 3 | 19 | Epidural Anesthetics and Steroids | | | | 19 | | | | | | | | | 19
Eskola, Pohjolainen, Alaranta et al., 1992 | 1 | 20 | Calcitonin Injections | | | | | | | 20 | | | | | | | | | | | | | | | 20
Eskola, Pohjolainen, Alaranta et al., 1992 | 2 | 19 | Calcitonin Injections | | | | | | | 19 | | | | | | | | | | | | | | | 19
Cuckler, Bernini, Wiesel et al., 1985 | 1 | 20 | Epidural Anesthetics and Steroids
Cuckler, Bernini, Wiesel et al., 1985 | 2 | 17 | Epidural Anesthetics
Patients with Degenerative Spondylolisthesis
Sinaki, Lutness, Ilstrup et al., 1989 | 1 | 29 | Exercise/flexion | 29
Sinaki, Lutness, Ilstrup et al., 1989 | 2 | 19 | Exercise/extension | 19
Trials Examining Surgical Patients with Central Lumbar Stenosis
Randomized controlled Trial
Grob, Humke, and Dvorak, 1995 | 1 | 15 | Partial laminectomy or hemilaminectomy
Grob, Humke, and Dvorak, 1995 | 2 | 15 | Partial laminectomy with fusion and instrumentation for single level
Grob, Humke, and Dvorak, 1995 | 3 | 15 | Partial laminectomy with fusion and instrumentation for multiple levels
Controlled Trials
Herno, Saari, Suomalainen et al., 1999 | 1 | 35 | Mixed Decompression Techniques - no post-surgery stenosis | | | | | | | | | | | | | | | | 1 | | | 28 | 7
Herno, Saari, Suomalainen et al., 1999 | 2 | 57 | Mixed Decompression Techniques - post-surgery stenosis | | | | | | | | | | | | | | | | 2 | | | 51 | 8
Herno, Partanen, Talaslahti et al., 1999 | 1 | 41 | Standard Wide Decompressive Laminectomy post surgery stenosis
Herno, Partanen, Talaslahti et al., 1999 | 2 | 15 | Standard Wide Decompressive Laminectomy no post surgery stenosis
Hanakita, Suwa, and MIzuno, 1999 | 1 | 59 | Standard Wide Decompressive Laminectomy SWDL
Hanakita, Suwa, and MIzuno, 1999 | 2 | 61 | Standard Wide Decompressive Laminectomy
Hanakita, Suwa, and MIzuno, 1999 | 3 | 16 | Partial laminectomy or hemilaminectomy
Hanakita, Suwa, and MIzuno, 1999 | 4 | 20 | SWDL with Fusion Arthrodesis
Thomas, Rea, Pikul et al., 1997 | 1 | 12 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | 10
Thomas, Rea, Pikul et al., 1997 | 2 | 14 | Laminotomy | | | | | | | | | | | | | 13
Yone, Sakou, Kawauchi et al., 1996 | 1 | 10 | SWDL with Fusion and Instrumentation
Yone, Sakou, Kawauchi et al., 1996 | 2 | 17 | Laminotomy
Ray, 1982 | 1 | 48 | Standard Wide Decompressive Laminectomy
Ray, 1982 | 2 | 17 | Partial laminectomy or hemilaminectomy
Surin, Hedelin, and Smith, 1982 | 1 | 15 | Standard Wide Decompressive Laminectomy - marked stenosis | | | | | | | | | | | | | 12 | | | 3 | | | | | 0 | 0 | 15
Surin, Hedelin, and Smith, 1982 | 2 | 7 | Standard Wide Decompressive Laminectomy - moderate stenosis | | | | | | | | | | | | | 2 | | | 3 | | | | | 0 | 7 | 0
Tajima, Fukazawa, and Ishio, 1980 | 1 | 13 | Mixed Decompression Techniques | 13 | | | 6 | | | | | | 4 | | | 8 | | | 7
Tajima, Fukazawa, and Ishio, 1980 | 2 | 14 | Mixed Decompression Techniques - disk lesion | 11 | | | 10 | | | | | | 11 | | | 6
Prospective Trials
Kleeman, Hiscoe, and Berg, 2000 | 1 | 54 | Partial Laminectomy | 46 | | | 51 | | | | | | 37 | | | 54 | | | 32
Weiner, Wlaker, Brower et al., 1999 | 1 | 30 | Partial Laminectomy | | | | | | | | | | | | | 30
diPierro, Helm, Shaffrey et al., 1996 | 1 | 35 | Hemilaminectomy and fusion | 29 | | | | 3 | 19 | | | | 22 | | | | 10 | 6 | 26
Retrospective Trial with Consecutive Patients
Vitaz, Raque, Shields et al., 1999 | 1 | 65 | Mixed Decompression Techniques | 58 | | | 63 | | | 43 | | | 32 | | | 44 | | | 36 | | | | 3
Matsui, Kanamori, Ishihara et al., 1997 | 1 | 27 | SWDL with Fusion Arthrodesis | | | | | | | | | | | | | 27
Airaksinen, Herno, Turunen et al., 1997 | 1 | 497 | Standard Wide Decompressive Laminectomy | 4 | | | 254 | | | | | | | | | 101 | | | | | | | | 83 | 218 | 137
Mullin, Rea, Irsik et al., 1996 | 1 | 72 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | | | | 18
Ishac, Alhayek, Fournier et al., 1996 | 1 | 34 | Standard Wide Decompressive Laminectomy | 10 | | | 34 | | | | | | | | | 16
Jonsson and Stromqvist, 1994 | 1 | 43 | Partial laminectomy or hemilaminectomy
Caputy and Luessenhop, 1992 | 1 | 100 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | 47
Dhar and Porter, 1992 | 1 | 36 | Standard Wide Decompressive Laminectomy
Chahal, Mundkur, Sancheti et al., 1982 | 1 | 32 | Standard Wide Decompressive Laminectomy | 32 | | | | | | | 12 | 13 | 5 | | | 14 | | | 12 | | | | 2 | 7 | 20 | 4
Rosomoff, 1981 | 1 | 50 | Standard Wide Decompressive Laminectomy | 3 | | | 5 | | 30 | | 12 | | 27 | | | | | | | | 28 | | 13 | 2 | 32 | 16
Getty, 1980 | 1 | 35 | Standard Wide Decompressive Laminectomy | 2 | | | | | 1 | | 18 | 10 | | | 3 | 12 | | | 18 | | | | 2
Reale, Deifini, Gambacona et al., 1978 | 1 | 37 | Standard Wide Decompressive Laminectomy - congenital stenosis | | | | | | | | | | 17 | | | | | | 18 | | | | 7
Verbiest, 1977 | 1 | 116 | Standard Wide Decompressive Laminectomy - congenital stenosis | 82 | | | | | | | | | | | | 87
Case-series
Young, Veerapen, and O'Laoire, 1988 | 1 | 32 | Decompressive Surgery | 23 | | | | 18 | 14 | | | | 11 | | | 23 | | | 18
Kurihara, Tanaka, Tsumura et al., 1988 | 1 | 12 | Standard Wide Decompressive Laminectomy - hyperostotic stenosis | | | | 5 | | | | | | 12 | | | 7 | | | 12
Hall, Bartleson, Onofrio et al., 1985 | 1 | 68 | Standard Wide Decompressive Laminectomy | 44 | | | 63 | | | | | | 29 | | | 64 | | | 43 | | | 56
Weinstein, Scafuri, and McNeill, 1983 | 1 | 24 | Standard Wide Decompressive Laminectomy | | | | | | | 24
Weir and De Leo, 1981 | 1 | 81 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | 12 | | | | | | | | | | 12
Johnsson, Willner, and Pettersson, 1981 | 1 | 27 | Standard Wide Decompressive Laminectomy | 27 | | | 27 | | | 10 | | | | | | 22 | | | | | | | | 5 | 15 | 7
Verbiest, 1979 | 1 | 11 | SWDL with Fusion Arthrodesis - congenital lumbar stenosis | 10 | | | 8 | | | | | | 8 | | | 8 | | | 5 | | | | | | | 11
Salibi, 1976 | 1 | 19 | Standard wide laminectomy 16 patients and unilateral laminectomy 3 patients | | | | | | | | | | | | | 18 | | | | | | | | | | 17
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
Randomized controlled Trial
Lee and deBari, 1986 | 1 | 12 | SWDL with Fusion Arthrodesis
Lee and deBari, 1986 | 2 | 12 | SWDL with Fusion and Instrumentation
Controlled Trials
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 1 | 20 | Partial laminectomy or hemilaminectomy | | | | 20 | | | | | | 7 | | | | | | 5
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 2 | 32 | Partial laminectomy or hemilaminectomy - with disk herniation | | | | 32 | | | | | | 12 | | | | | | 17 | | | | 4
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 3 | 21 | Partial laminectomy or hemilaminectomy - Lateral and Central Stenosis | | | | 21 | | | | | | 11 | | | | | | 12
Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982 | 4 | 21 | Partial laminectomy or hemilaminectomy - Lateral and Central Stenosis and disk herniation | | | | 21 | | | | | | 10 | | | | | | 8 | | | | 1
Mikhael, Ciric, Tarkington et al., 1981 | 1 | 35 | Standard Wide Decompressive Laminectomy | | | | | 18 | 17 | | | | 21 | | | 35 | | | 4 | | | 35 | 4
| 2 | 50 | Control/Placebo/None
Retrospective Trial with Consecutive Patients
Sanderson and Getty, 1996 | 1 | 66 | Laminotomy | | | | 57 | | | | | | 6 | | | 5 | | | 19
Baba, Uchida, Maezawa et al., 1996 | 1 | 31 | Laminotomy | 26 | | | 20 | | | | | | 16 | | | 17 | | | 17
Aryanpur and Ducker, 1990 | 1 | 32 | Laminotomy
Case-series
Choudhury and Taylor, 1977 | 1 | 28 | Standard Wide Decompressive Laminectomy | 28 | | | 28 | 2 | 22 | | | | 13 | | | | | | 21 | | | | 3
Epstein, Epstein, Rosenthal et al., 1972 | 1 | 15 | Foraminotomy/nerve root decompression | 9 | | | 15 | 3 | 12 | | | | 8 | | | | | | 6
Trials Examining Surgical Patients with Centralor Lateral Lumbar Stenosis type of stenosis unspecified or includes bothtypes of stenosis
Controlled Trial
Yone and Sakou, 1999 | 1 | 14 | Laminotomy - patients with instability
Yone and Sakou, 1999 | 2 | 19 | Laminotomy with Fusion and Instrumentation - patients with instability
Yone and Sakou, 1999 | 3 | 27 | Laminotomy - patients without instability
Epstein, 1999 | 1 | 10 | Standard Wide Decompressive Laminectomy - patients with Ossification of the Posterior Longitudinal Ligament
Epstein, 1999 | 2 | 11 | Standard Wide Decompressive Laminectomy - patients with Ossification of the Yellow Ligament
Javid and Hadar, 1998 | 1 | 86 | Standard Wide Decompressive Laminectomy - patients with central stenosis | 83 | | | 84 | | | | | | 31 | | | 65 | | | 44
Javid and Hadar, 1998 | 2 | 61 | Standard Wide Decompressive Laminectomy - patients with central stenosis and herniated disks | 61 | | | 60 | | | | | | 25 | | | 35 | | | 33
Javid and Hadar, 1998 | 3 | 23 | Standard Wide Decompressive Laminectomy - patients with lateral stenosis | 23 | | | 22 | | | | | | 12 | | | 13 | | | 15
Kalbarczyk, Lukes, and Seiler, 1998 | 1 | 93 | Standard Wide Decompressive Laminectomy - patients without instability
Kalbarczyk, Lukes, and Seiler, 1998 | 2 | 46 | Partial laminectomy or hemilaminectomy- patients with mild instability
Kalbarczyk, Lukes, and Seiler, 1998 | 3 | 9 | Partial laminectomy and fusion - patients with high instability
Pai and Kumar, 1996 | 1 | 30 | Decompressive Surgery - patients with congenital stenosis | 26 | | | 18 | | | | | | 9 | | | 24 | | | 10 | | | | 0
Pai and Kumar, 1996 | 2 | 23 | Decompressive Surgery - patients with degenerative stenosis | 23 | | | 11 | | | | | | 10 | | | 12 | | | 18 | | | | 2
Kawauchi, Yone, and Sakou, 1996 | 1 | 7 | Partial laminectomy and fusion - patients with slight adhesions | | | | | | | | | | | | | | | | | | | | | 1 | 5 | 1
Kawauchi, Yone, and Sakou, 1996 | 2 | 16 | Partial laminectomy and fusion- patients with moderate adhesions | | | | | | | | | | | | | | | | | | | | | 1 | 7 | 8
Kawauchi, Yone, and Sakou, 1996 | 3 | 13 | Partial laminectomy and fusion- patients with marked adhesions | | | | | | | | | | | | | | | | | | | | | 2 | 7 | 4
Cinotti, Postacchini, and Weinstein, 1994 | 1 | 25 | Standard Wide Decompressive Laminectomy - patients with diabetes | | | | | | | | | | 11 | | | 21 | | | | | | 21
Cinotti, Postacchini, and Weinstein, 1994 | 2 | 25 | Standard Wide Decompressive Laminectomy - patients without diabetes | | | | | | | | | | 10 | | | 19 | | | | | | 25
Little and MacDonald, 1994 | 1 | 60 | SWDL with Fusion Arthrodesis
Little and MacDonald, 1994 | 2 | 34 | SWDL with Fusion Arthrodesis
Simpson, Silveri, Balderston et al., 1993 | 1 | 33 | Standard Wide Decompressive Laminectomy - patients with diabetes | | | | 21 | | | | | | 12 | | | 33 | | | 13
Simpson, Silveri, Balderston et al., 1993 | 2 | 24 | Standard Wide Decompressive Laminectomy - patients without diabetes | | | | | | | 14 | | | 10 | | | 24 | | | 12
Jonsson and Stromqvist, 1993a | 1 | 20 | Partial laminectomy or hemilaminectomy - patients with central stenosis | | | | | | | 20
Jonsson and Stromqvist, 1993a | 2 | 19 | Partial laminectomy or hemilaminectomy - patients with lateral stenosis | | | | | | | 19
Nasca, 1989 | 1 | 15 | Decompressive Surgery -patients with lateral lumbar stenosis
Nasca, 1989 | 2 | 29 | Decompressive Surgery - patients with central or combined lumbar stenosis
Nasca, 1989 | 3 | 16 | Decompressive Surgery with fusion and instrumentation - patients with central or combined lumbar stenosis
Nasca, 1989 | 4 | 21 | Decompressive Surgery - patients with postsurgical stenosis
Nasca, 1989 | 5 | 22 | Decompressive Surgery with fusion and instrumentation - patients with instability | | | | | | | | | | | | | | | | | | | | 2
Nasca, 1989 | 6 | 11 | Decompressive Surgery with fusion and instrumentation - patients with degenerative stenosis and scoliosis
Nather and Thomas, 1985 | 1 | 11 | Decompressive surgery with or without fusion - patients with degenerative lumbar stenosis
Nather and Thomas, 1985 | 2 | 14 | Decompressive surgery with or without fusion - patients with combined degenerative and congenital lumbar stenosis
Paine, 1976 | 1 | 95 | Standard Wide Decompressive Laminectomy - patients with degenerative stenosis
Paine, 1976 | 2 | 48 | Standard Wide Decompressive Laminectomy- patients with degenerative stenosis and disk herniation
Shenkin and Hash, 1976 | 1 | 49 | Standard Wide Decompressive Laminectomy - patients with no prior surgery | 7 | | | | 2 | 10 | | 9 | 21 | | | | | | | | | | | | 49
| 2 | 21 | Standard Wide Decompressive Laminectomy - patients with prior surgery for herniated disk | 3 | | | | 1 | 14 | | 1 | 2 | | | | | | | | | | | | 21
Tile, McNeil, Zarins et al., 1976 | 1 | 26 | Mixed Decompression Techniques - patients with lumbar stenosis
Tile, McNeil, Zarins et al., 1976 | 2 | 18 | Standard Wide Decompressive Laminectomy - patients with congenital stenosis
Retrospective Trial with Consecutive Patients
Crock, Shiraishi, and Crock, 1995 | 1 | 34 | Partial laminectomy or hemilaminectomy | 34 | | | 34 | 28 | 6 | | | | 21 | | 912 | 23 | | | 11 | | | | 4
Silvers, Lewis, and Asch, 1993 | 1 | 248 | Standard Wide Decompressive Laminectomy | 244 | | | 228 | | | 218 | | | 83 | | | 213 | | | 24
Katz, Lipson, Larson et al., 1991 | 1 | 88 | Mixed Decompression Techniques | | | | | | | | | | 37 | | | 25 | | | 28 | | | 88
Ganz, 1990 | 1 | 36 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | 15 | | | | | | 23
Case-series
Norcross-Nechay, Mathew, Simmons et al., 1999 | 1 | 70 | Decompressive Surgery with fusion and instrumentation | 70 | | | | | 29 | | | | | | | 70
Guigui, Benoist, Delecourt et al., 1998 | 1 | 50 | Decompressive surgery | | | | 50 | | | | | | 39 | | | | | | | | | | | | 40 | 10
Scholz, Firsching, and Lanksch, 1998 | 1 | 72 | Decompressive Surgery | | | | | | | 68 | | | | | | 25 | | | 57
Tsai, Yang, and Bray, 1998 | 1 | 62 | Laminotomy | 49 | 45 | 4 | 48 | 23 | 25 | | | | 10 | | | 13 | | | 18
Mackay and Wheelwright, 1998 | 1 | 50 | Partial laminectomy or hemilaminectomy | 50 | | | 36 | | | | | | 16 | | | | | | 47
Whitecloud, Castro Jr, Brinker et al., 1998 | 1 | 35 | SWDL with Fusion and Instrumentation | 35
Spetzger, Bertalanffy, Reinges et al., 1997 | 1 | 29 | Laminotomy | 26 | | | | | | | | | | | | 27 | | | 15 | | | | 2
Katz, Lipson, Chang et al., 1996 | 1 | 88 | Standard Wide Decompressive Laminectomy
Lehto and Honkanen, 1995 | 1 | 96 | Decompressive Surgery | 91 | | | | | | 71 | | | 84 | | | 75
Stucki, Liang, Fossel et al., 1995 | 1 | 203 | Decompressive Surgery | | | | 69 | | | 98 | | | 111 | | | | | | 98
Tuite, Stern, Doran et al., 1994 | 1 | 119 | Standard Wide Decompressive Laminectomy | 92 | | | 112 | | | | | | 56 | | | | | | 60 | | | | 2
McCullen, Bernini, Bernstein et al., 1994 | 1 | 193 | Decompressive Surgery | | | | | | | | | | 26 | | | | | | 12
Simmons and Simmons, 1992 | 1 | 40 | SWDL with Fusion and Instrumentation | 35 | | | 34 | | | | | | | | | 40
Mauersberger and Nietgen, 1989 | 1 | 92 | Decompressive surgery with or without fusion
Johnsson, Redlund-Johnell, Uden et al., 1989 | 1 | 61 | Standard Wide Decompressive Laminectomy
Brodsky, Hendricks, Khalil et al., 1989 | 1 | 34 | Fusion
Jalovaara, Lahde, Iikko et al., 1989 | 1 | 31 | Standard Wide Decompressive Laminectomy | 22 | | | 31 | | | | | | | | | 18 | | | | | | | | 0 | 6 | 25
Fast, Robin, and Floman, 1985 | 1 | 19 | Standard Wide Decompressive Laminectomy | 19 | | | 19 | | | | | | | | | 14 | | | | | | 7
Boccanera, Pellicioni, and Laus, 1984 | 1 | 25 | Standard Wide Decompressive Laminectomy | | | | | | | 23 | 14 | 9 | 8 | | 71 | 15 | | | 13 | 9 | 4
Hood and Weigl, 1983 | 1 | 21 | Standard Wide Decompressive Laminectomy | 20 | 18 | 2 | 20 | 4 | 16 | | | | 20 | | | 20
Scafuri and Weinstein, 1981 | 1 | 27 | Standard Wide Decompressive Laminectomy | 27 | | | 20 | | | | | | 2 | | | 8 | | | 19 | | | | 2
Echeverria and Lockwood, 1979 | 1 | 35 | Standard Wide Decompressive Laminectomy
Scapinelli, 1978 | 1 | 23 | Standard Wide Decompressive Laminectomy
Vestad and Naca, 1977 | 1 | 80 | Standard Wide Decompressive Laminectomy
McKinley and Davis, 1976 | 1 | 32 | Standard Wide Decompressive Laminectomy | 28 | | | 28 | 10 | 18 | | | | 17 | | | 22 | | | 18
Teng and Papatheodorou, 1963 | 1 | 29 | SWDL-Standard Wide Decompressive Laminectomy | 27 | | | 26 | | | | | | 16 | | | | | | 26
Epstein, Epstein, and Lavine, 1962 | 1 | 29 | Mixed Decompression Techniques | | | | | | | | | | | | | | | | | | | | 1
Epstein, 1960 | 1 | 14 | Standard Wide Decompressive Laminectomy | 14 | | | | | | | | | 14 | | | | | | 11 | | | | 4
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
Randomized controlled Trial
Fischgrund, Mackay, Herkowitz et al., 1997 | 1 | 40 | SWDL with Fusion and Instrumentation | 38 | | | 40
Fischgrund, Mackay, Herkowitz et al., 1997 | 2 | 35 | SWDL with Fusion Arthrodesis | 33 | | | 35
Thomsen, Christensen, Eiskjaer et al., 1997 | 1 | 20 | Partial laminectomy with fusion and instrumentation
Thomsen, Christensen, Eiskjaer et al., 1997 | 2 | 21 | Partial laminectomy and fusion
Bridwell, Sedgewick, O'Brien et al., 1993 | 1 | 9 | Partial laminectomy or hemilaminectomy | | | | | | | | | | | | | 9
Bridwell, Sedgewick, O'Brien et al., 1993 | 2 | 10 | Partial laminectomy and fusion | | | | | | | | | | | | | 10
Bridwell, Sedgewick, O'Brien et al., 1993 | 3 | 24 | Partial laminectomy with fusion and instrumentation | | | | | | | | | | | | | 24
Herkowitz and Kurz, 1991 | 1 | 25 | SWDL-Standard Wide Decompressive Laminectomy
Herkowitz and Kurz, 1991 | 2 | 25 | SWDL with Fusion Arthrodesis
Controlled Trials
Plotz and Benini, 1998 | 1 | 17 | Decompressive Surgery without fusion
Plotz and Benini, 1998 | 2 | 18 | Decompressive Surgery with fusion and Translaminar Screw Fixation
Plotz and Benini, 1998 | 3 | 71 | Decompressive Surgery with fusion and AO Internal Fixator
Yuan, Garfin, Dickman et al., 1994 | 1 | 2177 | Fusion and Pedical Screw Fixation | 2121 | | | 2125
| 2 | 456 | Fusion | 449 | | | 451
Satomi, Hirabayashi, Toyama et al., 1992 | 1 | 27 | Fusion and instrumentation | 27 | | | 24 | | | | | | | | | 6 | | | | | | | 8 | 9 | 8 | 10
Satomi, Hirabayashi, Toyama et al., 1992 | 2 | 14 | Mixed Decompression Techniques | 10 | | | 14 | | | | | | | | | 9 | | | | | | | 3 | 2 | 3 | 9
Lombardi, Wiltse, Reynolds et al., 1985 | 1 | 20 | SWDL-Standard Wide Decompressive Laminectomy
Lombardi, Wiltse, Reynolds et al., 1985 | 2 | 21 | SWDL with Fusion Arthrodesis
Prospective Trials
Nakai, Yoshizawa, and Kobayashi, 1999 | 1 | 23 | Fusion only
Rechtine, Sutterlin, Wood et al., 1996 | 1 | 18 | SWDL with Fusion and Instrumentation | | | | | | | | | | | | | | | | | | | | | 11 | 7 | 0
Retrospective Trial with Consecutive Patients
Stambough, 1999 | 1 | 35 | SWDL with Fusion and Instrumentation
Nishizawa and Fujimura, 1997 | 1 | 58 | Fusion and instrumentation | | | | | | | | | | | | | | | | | | | | | 19 | 15 | 24
Moller, Wittenberg, Nolte et al., 1992 | 1 | 37 | Fusion | | | | | | | | | | | | | | | | | | | | | 23 | 14 | 0
Marchesi, Thalgott, and Aebi, 1991 | 1 | 30 | SWDL with Fusion and Instrumentation | | | | | | | | | | | | | 9 | | | | | | | | 9 | 16 | 4
Takahashi, Kitahara, Yamagata et al., 1990 | 1 | 39 | Fusion | | | | | | | | | | | | | 32
Knox, Harvell, Nelson et al., 1989 | 1 | 39 | SWDL with Fusion and Instrumentation | 21 | | | 22 | | | | | | 17 | | | 22
Case-series
Booth, Bridwell, Eisenberg et al., 1999 | 1 | 49 | Partial laminectomy with fusion and instrumentation | | | | | | | | | | | | | 49
McCulloch, 1998 | 1 | 21 | Partial laminectomy and fusion | | | | 21
Epstein, 1998b | 1 | 28 | SWDL with Fusion and Instrumentation
Mochida, Toh, Suzuki et al., 1997 | 1 | 10 | Partial laminectomy with fusion and instrumentation
Epstein, 1998a | 1 | 290 | Mixed Decompression Techniques
Grob, Humke, and Dvorak, 1996 | 1 | 18 | SWDL with Fusion and Instrumentation | 18 | | | | | | | | | | | | 5
Herron and Trippi, 1989 | 1 | 24 | Standard Wide Decompressive Laminectomy | | | | 24 | 11 | 13 | 24 | | | 13 | | 1 | 8 | | | 12 | 2 | 10
Chang and McAfee, 1989 | 1 | 17 | SWDL with Fusion and Instrumentation | 17
Inoue, Watanabe, Goto et al., 1988 | 1 | 36 | Fusion | 36 | | | 36 | | | | | | | | | 24 | | | 36
Simmons and Capicotto, 1988 | 1 | 15 | SWDL with Fusion and Instrumentation
Hanley, 1986 | 1 | 20 | SWDL with Fusion and Instrumentation | 20 | | | 20
Kaneda and Kazama, 1986 | 1 | 54 | SWDL with Fusion and Instrumentation | 47 | | | 36 | | | | | | 45 | | | 34 | | | 39
Alexander Jr, Kelly Jr, Davis Jr et al., 1985 | 1 | 50 | Standard Wide Decompressive Laminectomy | | | | 43 | 15 | 28
Dall and Rowe, 1985 | 1 | 26 | SWDL-Standard Wide Decompressive Laminectomy | 15
Epstein, Epstein, Carras et al., 1983 | 1 | 60 | Mixed Decompression Techniques | | | | | | | 11 | | | | | 16 | 49 | | | 32
Richardson and Brown, 1980 | 1 | 21 | SWDL with Fusion Arthrodesis
Cauchoix, Benoist, and Chassaing, 1976 | 1 | 26 | SWDL-Standard Wide Decompressive Laminectomy | 21 | | | 12 | | | | | | 6 | | | 14 | | | 4 | | | | 1
Epstein, Epstein, Lavine et al., 1976 | 1 | 20 | Mixed Decompression Techniques | 20 | | | | | | | | | | | | 7 | | | 9 | | | 7 | 5
Trials Examining Surgical Patients with LumbarStenosis and/or Degenerative Spondylolisthesis
Controlled Trial
Rompe, Eysel, Zollner et al., 1999 | 1 | 39 | Partial laminectomy or hemilaminectomy - patients with central lumbar stenosis | | | | | | | 39 | | | 23 | | | | | | 16
Rompe, Eysel, Zollner et al., 1999 | 2 | 51 | SWDL-Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis | | | | | | | 51 | | | 24 | | | | | | 18
Rompe, Eysel, Zollner et al., 1999 | 3 | 27 | SWDL with Fusion and Instrumentation - patients with degenerative spondylolisthesis | | | | | | | 27 | | | 11 | | | | | | 14
Katz, Lipson, Lew et al., 1997 | 1 | 194 | Standard Wide Decompressive Laminectomy | | | | | | | | | | 54 | | | | | | 45
Katz, Lipson, Lew et al., 1997 | 2 | 37 | SWDL with Fusion Arthrodesis | | | | | | | | | | 15 | | | | | | 11
Katz, Lipson, Lew et al., 1997 | 3 | 41 | SWDL with Fusion and Instrumentation | | | | | | | | | | 16 | | | | | | 9
Sato and Kikuchi, 1997 | 1 | 28 | Laminotomy - 2 level stenosis | | | | | | | | | | | | | 28 | | | | | | | | 0 | 0 | 28
Sato and Kikuchi, 1997 | 2 | 53 | Laminotomy - 1 level stenosis | | | | | | | | | | | | | 53 | | | | | | | | 0 | 53 | 0
Rompe, Eysel, Hopf et al., 1995 | 1 | 24 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis | 24 | | | | | | | | | 9 | | | 10 | | | 17 | | | | | | 24
Rompe, Eysel, Hopf et al., 1995 | 2 | 24 | Standard Wide Decompressive Laminectomy - patients with lumbar stenosis | 24 | | | | | | | | | 15 | | | 8 | | | 6 | | | | | | | 24
Rompe, Eysel, Hopf et al., 1995 | 3 | 12 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis and spondylolisthesis | 12 | | | | | | | | | 5 | | | 8 | | | 6 | | | | | | | 12
Sanderson and Wood, 1993 | 1 | 19 | Partial laminectomy or hemilaminectomy - patients with Degenerative Spondylolisthesis | | | | | 8 | 11 | | | | | | | 10 | | | | | | | | | 12 | 7
Sanderson and Wood, 1993 | 2 | 12 | SWDL-Standard Wide Decompressive Laminectomy - patients with lumbar spinal stenosis | | | | | 6 | 6 | | | | | | | 6
Robertson, Grobler, Novotny et al., 1993 | 1 | 22 | SWDL-Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis
Robertson, Grobler, Novotny et al., 1993 | 2 | 11 | SWDL-Standard Wide Decompressive Laminectomy - patients with degenerative spondylolisthesis
Postacchini, Cinotti, Perugia et al., 1993 | 1 | 26 | Laminotomy - patients with congenital or degenerative stenosis, combined, or degenerative spondylolisthesis
Postacchini, Cinotti, Perugia et al., 1993 | 2 | 41 | Standard Wide Decompressive Laminectomy - patients with central lumbar stenosis
Hirabayashi, Kumano, and Kuroki, 1991 | 1 | 32 | SWDL with Fusion and Instrumentation - patients with degenerative spondylolisthesis
Hirabayashi, Kumano, and Kuroki, 1991 | 2 | 21 | SWDL with Fusion and Instrumentation - patients with lumbar stenosis
Herkowitz and Garfin, 1989 | 1 | 58 | Standard Wide Decompressive Laminectomy - patients with degenerative stenosis
Herkowitz and Garfin, 1989 | 2 | 41 | Standard Wide Decompressive Laminectomy - patients with degenerative spondylolisthesis
Prospective Trials
Jonsson, Annertz, Sjoberg et al., 1997a | 1 | 105 | Partial laminectomy or hemilaminectomy - patients with Central Spinal Stenosis and Degenerative Spondylolisthesis | 91 | | | 105 | | | | | | | | | 69 | | | | | | | | | | 101
Postacchini and Conotti, 1992 | 1 | 88 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined, with or without Spondylolisthesis
Retrospective Trial with Consecutive Patients
Chen, Baba, Kamitani et al., 1994 | 1 | 80 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined stenosis, or degenerative or isthmic spondylolisthesis | | | | | | | | | | | | | | | | | | | | | 16 | 26 | 6
Postacchini, Cinotti, Gumina et al., 1993 | 1 | 64 | Mixed Decompression Techniques - patients with Developmental, degenerative, or combined, with or without spondylolisthesis
Case-series
Guigui, Barre, Benoist et al., 1999 | 1 | 28 | SWDL-Standard Wide Decompressive Laminectomy
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
Patients with Central Lumbar Stenosis
Simotas, Dorey, Hansraj et al., 2000 | 1 | 40 | Conservative - various treatments | | | | | | | | | | | | | | | | | | | | | 6 | 19 | 15
Simotas, Dorey, Hansraj et al., 2000 | 2 | 9 | Surgery - not described | | | | | | | | | | | | | | | | | | | | | 0 | 2 | 7
Mariconda, Zanforlino, Celestino et al., 2000 | 1 | 20 | Standard Wide Decompressive Laminectomy | 18 | | | 17 | | | | | | 10 | | | 18 | | | 12
Mariconda, Zanforlino, Celestino et al., 2000 | 2 | 17 | Untreated | 16 | | | 14 | | | | | | 8 | | | 16 | | | 10
Johnsson, Uden, and Rosen, 1991 | 1 | 20 | Conservative-not described | | | | 2 | | | | | | | | | 16 | | | | | | | | | 19 | 1
Johnsson, Uden, and Rosen, 1991 | 2 | 30 | Standard Wide Decompressive Laminectomy - patients with moderate stenosis | | | | 5 | | | | | | | | | 23 | | | | | | | | | 30
Johnsson, Uden, and Rosen, 1991 | 3 | 14 | Standard Wide Decompressive Laminectomy - patients with severe stenosis | | | | 2 | | | | | | | | | 12 | | | | | | | | | | 14
Patients with Central or Lateral Lumbar Stenosis Unspecified
Amundsen T, Weber H, Nordal HJ et al., 2000 | 1 | 19 | Standard Wide Decompressive Laminectomy | | | | 19 | | | | | | | | | | | | | | | | | 2 | 12 | 5
Amundsen T, Weber H, Nordal HJ et al., 2000 | 2 | 50 | Conservative - various treatments | | | | 50 | | | | | | | | | | | | | | | | | 8 | 25 | 17
Amundsen T, Weber H, Nordal HJ et al., 2000 | 3 | 13 | Standard Wide Decompressive Laminectomy | | | | 13 | | | | | | | | | | | | | | | | | 4 | 7 | 2
Amundsen T, Weber H, Nordal HJ et al., 2000 | 4 | 18 | Conservative - various treatments | | | | 18 | | | | | | | | | | | | | | | | | 6 | 5 | 7
Hurri, Slatis, Soini et al., 1998 | 1 | 57 | SWDL-Standard Wide Decompressive Laminectomy | 56 | | | 47 | | | | | | | | | | | | 38 | | | | | | 31 | 26
Hurri, Slatis, Soini et al., 1998 | 2 | 18 | Conservative-not described | 18 | | | 13 | | | | | | | | | | | | 8 | | | | | | 12 | 6
Atlas, Deyo, Keller et al., 1996 | 1 | 81 | SWDL-Standard Wide Decompressive Laminectomy | 62 | | | 66 | | | | | | 18 | | | 56 | | | 12
Atlas, Deyo, Keller et al., 1996 | 2 | 67 | Conservative-many | 38 | | | 34 | | | | | | 16 | | | 34 | | | 15
Swezey, 1996 | 1 | 12 | Exercise/stretching and flexibility | | | | | | | | | | | | | | 12
Swezey, 1996 | 2 | 11 | Physical Therapy/massage, ultrasound, heat, ice, traction | | | | | | | | | | | | | | 11
Swezey, 1996 | 3 | 13 | Epidural Steroid Injections | | | | | | | | | | | | | | 13
Swezey, 1996 | 4 | 11 | Standard Wide Decompressive Laminectomy | | | | | | | | | | | | | | 11 | | | | | | | | 7 | 4
Nagler and Bodack, 1993 | 1 | 41 | Conservative-various
Nagler and Bodack, 1993 | 2 | 39 | Standard Wide Decompressive Laminectomy
Herno, Airaksinen, Saari et al., 1996 | 1 | 54 | Conservative-not described | | | | 37 | | | | | | | | | 13 | | | | | | | | | 50 | 4
Herno, Airaksinen, Saari et al., 1996 | Data from surgical patients used for comparison were obtained from a larger previously published study.
Patients with Degenerative Spondylolisthesis
Fitzgerald and Newman, 1976 | 1 | 29 | Rigid Brace | 29
Fitzgerald and Newman, 1976 | 2 | 14 | Mixed Decompression Techniques | 10 | | | 5 | | | | | | | | | 4
Rosenberg, 1976 | 1 | 11 | Partial laminectomy or hemilaminectomy
Rosenberg, 1976 | 2 | 15 | Standard Wide Decompressive Laminectomy
Rosenberg, 1976 | 3 | 170 | Conservative-not described

Evidence Table 12. Ability to Work Outcomes from Clinical Trials of Patients with Lumbar Spinal Stenosis

Randomized Controlled Trials of Patients Receiving Conservative Treatments
Randomized Controlled Trials of Patients Receiving Conservative Treatments
  Patient Condition: | Spondylolisthesis
  Authors and Year: | Sinaki, Lutness, Ilstrup et al., 1989
  Reporting: | Patient-reported
  Method: | 2 Levels. Working, or Limited or unable to work.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 29 | Degenerative Spondylolisthesis | Exercise/flexion | 28 | 3 | 3 | | 18
| | | | 26 | 36 | | | 20
2 | 19 | Degenerative Spondylolisthesis | Exercise/extension | 19 | 3 | 3 | | 6
| | | | 18 | 34.8 | | | 7

Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Airaksinen, Herno, Turunen et al., 1997
  Reporting: | Patient-reported
  Method: | Reported before and after surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 497 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 438 | 0 | | | 85
| | | | 438 | 52 | | | 121

Trials Examining Surgical Patients with Lateral Lumbar Stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982
  Reporting: | Patient-reported
  Method: | 3 levels. Ex: Same, Gd: Lighter, Pr: None
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 20 | Lateral Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 36 | | 120 | 13 | 6 | 7 | | 2
2 | 32 | Lateral Lumbar Stenosis with disk herination | Partial laminectomy or hemilaminectomy | 26 | 36 | | 120 | 25 | 18 | 7 | | 1
3 | 21 | Lateral and Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 18 | 36 | | 120 | 16 | 11 | 5 | | 2
4 | 21 | Lateral and Central Lumbar or Stenosis with disk herniation | Partial laminectomy hemilaminectomy | 18 | 36 | | 120 | 18 | 16 | 2
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Sanderson and Getty, 1996
  Reporting: | Patient-reported
  Method: | 3 levels based on patients opinion on ability to work. Excellent: heavy work, Good: light work, Poor: unable to work.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 0 | 0 | 0 | 46 | 18 | 24 | | 15
| | | | 57 | 12 | 12 | 12 | 50 | 11 | 39 | | 7
| | | | 57 | 101 | 60 | 132 | 51 | 10 | 41 | | 6
  Study Design: | Case-series
  Authors and Year: | Choudhury and Taylor, 1977
  Reporting: | Patient-reported
  Method: | 3 Levels: Full Capacity, Reduced capacity, Incapacitated.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 28 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 28 | | 2 | 24 | 28

Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type of stenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Javid and Hadar, 1998
  Reporting: | Patient-reported
  Method: | Percentage of patients working who had been working prior to surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 57.2 | 12 | 132 | 56
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy | | 56.6 | 12 | 132 | 74
3 | 23 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 86.6 | 12 | 132 | 43
  Study Design: | Case-series
  Authors and Year: | Vestad and Naca, 1977
  Reporting: | Patient-reported
  Method: | 3 Levels: Incapable of working, partial capacity, full capacity.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 80 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 80 | 0 | | | 20
| | | | 80 | 56.4 | | | 40

Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Prospective Trial
  Authors and Year: | Rechtine, Sutterlin, Wood et al., 1996
  Reporting: | Patient-reported
  Method: | Number of patients working before surgery who returned to work.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 18 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 14 | 38 | 24 | | 3
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Knox, Harvell, Nelson et al., 1989
  Reporting: | Patient-reported
  Method: | Number of patients returned to work
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 12 | 21.3 | 4 | 55 | 9
  Study Design: | Case-series
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
  Reporting: | Patient-reported
  Method: | 5 levels of work/school-related activity: 100%, 75%, 50%, 25%, 0%.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 34 | 0 | | | | 7 | 7 | 11 | 5 | 4
| | | | 32 | 24 | | | | 10 | 11 | 8 | 2 | 1
| | | | 32 | 78 | 60 | 129 | | 10 | 7 | 8 | 3 | 4
  Authors and Year: | Grob, Humke, and Dvorak, 1996
  Reporting: | Patient-reported
  Method: | Number of patients eligible to work who returned to work.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 18 | Degenerative/spondylolytic Spondylolisthesis | SWDL with Fusion and Instrumentation | 8 | 0 | | | 0
| | | | 8 | 31 | 24 | 77 | 5

Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Patient Condition: | Central lumbar stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Johnsson, Uden, and Rosen, 1991
  Reporting: | Patient-reported
  Method: | Complete information was only available for the untreated nonsurgery group.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | Number Working | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Number Working | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | Conservative-not described | 14 | 31 | 7 | 51 | 2

Evidence Table 13. Back Pain Outcomes Related to Treatment of Lumbar Spinal Stenosis

Randomized Controlled Trials of Patients Receiving Conservative Treatments
Randomized Controlled Trials of Patients Receiving Conservative Treatments
  Patient Condition: | Spondylolisthesis
  Authors and Year: | Sinaki, Lutness, Ilstrup et al., 1989
  Reporting: | Patient-reported
  Method: | 2 Levels: Good: None or mild pain, and Poor: Moderate or severe pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Degenerative Spondylolisthesis | Exercise/flexion | | 26 | 0 | | | | | | 0 | | 26
| | | | 26 | 3 | | | | | | 19 | | 7
| | | | 26 | 36 | | | | | | 21 | | 5
2 | 19 | Degenerative Spondylolisthesis | Exercise/extension | | 18 | 0 | | | | | | 6 | | 12
| | | | 18 | 3 | | | | | | 6 | | 12
| | | | 18 | 34.8 | | | | | | 6 | | 12

Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Grob, Humke, and Dvorak, 1995
  Reporting: | Patient-reported
  Method: | Visual analog scale of 0 to 10. Values are not reported separately for back and leg but as a combined Pain score.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | | 15 | 0 | 0 | 0 | 7.8
| | | | 15 | 28 | 24 | 32 | 1.8
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation | | 15 | 0 | 0 | 0 | 7.8
| | | | 15 | 28 | 24 | 32 | 2
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation | | 15 | 0 | 0 | 0 | 8.8
| | | | 15 | 28 | 24 | 32 | 3
  Study Design: | Controlled Trial
  Authors and Year: | Hanakita, Suwa, and MIzuno, 1999
  Reporting: | Patient-reported
  Method: | 3 levels. Gd: Improved, Fr: Unchanged, Pr: Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 59 | Central Lumbar Stenosis - younger than 64 years | SWDL-Standard Wide Decompressive Laminectomy | | 36 | | 12 | 96 | | | | 24 | 10 | 2
2 | 61 | Central Lumbar Stenosis - older than 64 years | SWDL-Standard Wide Decompressive Laminectomy | | 29 | | 12 | 96 | | | | 17 | 8 | 4
3 | 16 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | | 12 | | 12 | 96 | | | | 9 | 3 | 0
4 | 20 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | | 11 | | 12 | 96 | | | | 9 | 2 | 0
  Study Design: | Prospective Trial
  Authors and Year: | diPierro, Helm, Shaffrey et al., 1996
  Reporting: | Patient-reported
  Method: | Score from 0 (no pain) - 10 (severe pain). Also reported number of patients with no pain at followup.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Central Lumbar Stenosis | Partial laminectomy and fusion | | 29 | 0 | 0 | 0 | 9.2
| | | | 29 | 30 | | | 3.31 | | | 14 | 15
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Vitaz, Raque, Shields et al., 1999
  Reporting: | Patient-reported
  Method: | 3 levels. No change, Improved, and Resolved
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 65 | Central Lumbar Stenosis | Mixed Decompression Techniques | | 58 | 19.6 | 1 | 63 | | | | 38 | 10 | 6
  Authors and Year: | Matsui, Kanamori, Ishihara et al., 1997
  Reporting: | Patient-reported
  Method: | Japanese Orthopaedic Association evaluation system. Scored from 0 (frequent severe pain) to 3 (no pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | | 27 | 0 | 0 | 0 | 1.4 | 0.5
| | | | 27 | 67 | | | 2.5 | 0.6
  Study Design: | Case-series
  Authors and Year: | Johnsson, Willner, and Pettersson, 1981
  Reporting: | Patient-reported
  Method: | Number of patients with back and leg pain
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 27 | 22 | 3 | 79 | 16 | 12

Trials Examining Surgical Patients with LateralLumbar Stenosis
  Study Design: | Case-series
  Authors and Year: | Choudhury and Taylor, 1977
  Reporting: | Patient-reported
  Method: | 3 Levels: Absent, Mild (Occasional), Recurring
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 28 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 28 | | 2 | 24

Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type of stenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Yone and Sakou, 1999
  Reporting: | Physician-reported
  Method: | JOA score
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis with instability | Laminotomy | | 14 | 0 | | | 1.4
| | | | 14 | 37 | 24 | 52 | 1.7
1 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | | 19 | 0 | | | 1.4
| | | | 19 | 43 | 24 | 60 | 2.6
3 | 27 | Mixed Stenosis without instability | Laminotomy | | 27 | 0 | | | 1.3
| | | | 27 | 33 | 24 | 54 | 2.7
  Authors and Year: | Javid and Hadar, 1998
  Reporting: | Patient-reported
  Method: | 5 levels. Ex: None, Gd: Rarely, Fr: Sometimes, Pr: most times, VPr: constant
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 72 | 57.2 | 12 | 132 | | | 12 | 13 | 27 | 12 | 8
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy | | 52 | 56.6 | 12 | 132 | | | 14 | 9 | 16 | 7 | 6
3 | 23 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 22 | 86.6 | 12 | 132 | | | 2 | 4 | 6 | 5 | 5
  Authors and Year: | Kawauchi, Yone, and Sakou, 1996
  Reporting: | Patient-reported
  Method: | Japanese Orthopedic Association for low back pain score (JOA score)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 7 | Mixed Stenosis - slight adhesion | Partial laminectomy and fusion | | 7 | 0 | | | 14.1 | 2.6 | 0 | 4 | 3 | 0 | 0
2 | 16 | Mixed Stenosis - moderate adhesion | Partial laminectomy and fusion | | 16 | 0 | | | 11.4 | 5.5 | 0 | 6 | 8 | 2 | 0
3 | 13 | Mixed Stenosis - marked adhesion | Partial laminectomy and fusion | | 13 | 0 | | | 12.8 | 4.8 | 0 | 2 | 4 | 7 | 0
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Katz, Lipson, Larson et al., 1991
  Reporting: | Patient-reported
  Method: | 6 levels. 1: Very Severe, 2: Severe, 3: Moderate, 4: Mild, 5: Very Mild, 6: None
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Mixed Stenosis | Mixed Decompression Techniques | | 70 | 50 | 34 | 82 | | | 11 | 16 | 22 | 15 | 6
  Study Design: | Case-series
  Authors and Year: | Mackay and Wheelwright, 1998
  Reporting: | Patient-reported
  Method: | Yes or no, pre and post
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | | 50 | | | | | | | 0 | | 50
| | | | 50 | 32 | 12 | 49 | | | | 40 | | 10
  Authors and Year: | Tsai, Yang, and Bray, 1998
  Reporting: | Patient-reported
  Method: | Analog scale 0-20
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 62 | Mixed Stenosis | Laminotomy | | 62 | 27 | 15 | 48 | 14.4 | 5.8
| | | | 62 | 27 | 15 | 48 | 4.9 | 6.5
  Authors and Year: | Whitecloud, Castro, Brinker et al., 1998
  Reporting: | Patient-reported
  Method: | Analog Scale, 0-10
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Mixed Stenosis | SWDL with Fusion and Instrumentation | | 35 | 0 | | | 7.2 | 1.5
| | | | 35 | 20 | 6 | 49 | 5.5 | 2.6
  Authors and Year: | Katz, Lipson, Chang et al., 1996
  Reporting: | Patient-reported
  Method: | 3 Levels: Severe or very severe, Moderate or mild, Very Mild or none.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 55 | | 84 | 120 | | | 18 | 27 | 10
  Authors and Year: | McCullen, Bernini, Bernstein et al., 1994
  Reporting: | Patient-reported
  Method: | 5 levels: Patient has Back and leg pain Never, occasionally, frequently, very frequently, Constantly.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 193 | Mixed Stenosis | Decompressive Surgery | | 118 | 55 | 24 | 142 | | | 33 | 32 | 28 | 19 | 2
  Authors and Year: | Simmons and Simmons, 1992
  Reporting: | Patient-reported
  Method: | 4 levels. None, Mild (minimal disruption of lifestyle), Moderate (significant disruption of lifestyle, Severe (constant pain and problems
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Mixed Stenosis | SWDL with Fusion and Instrumentation | | 40 | 44 | 24 | 61 | | | | 32 | | 8

Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Fischgrund, Mackay, Herkowitz et al., 1997
  Reporting: | Patient-reported
  Method: | Visual analog scale from 0 (no pain) to 5 (severe pain).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | | 35 | 0 | 0 | 0 | 4
| | | | 35 | 28 | 24 | 36 | 1
2 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | | 33 | 0 | 0 | 0 | 4
| | | | 33 | 28 | 24 | 36 | 2
  Authors and Year: | Herkowitz and Kurz, 1991
  Reporting: | Patient-reported
  Method: | Scale of no pain (0) to severe pain (5).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 25 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | | 25 | 0 | 0 | 0 | 2.9
| | | | 25 | 36 | 29 | 48 | 2.5
2 | 25 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | | 25 | 0 | 0 | 0 | 3.3
| | | | 25 | 36 | 29 | 48 | 1.3
  Study Design: | Controlled Trial
  Authors and Year: | Satomi, Hirabayashi, Toyama et al., 1992
  Reporting: | Patient-reported
  Method: | JOA score 0 (severe pain)-3 (no pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Degenerative Spondylolisthesis | Fusion and instrumentation | | 27 | 0 | 0 | 0 | 1.2 | | | | 5 | 22
| | | | 27 | 36 | | | 2.3 | | 19 | 8
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | | 14 | 0 | 0 | 0 | 1.9 | | 2 | 8 | 4
| | | | 14 | 36 | | | 2.8 | | 11 | 3
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Stambough, 1999
  Reporting: | Patient-reported
  Method: | Visual analog scale of 0 (no pain) to 10 (severe pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | | 35 | 0 | 0 | 0 | 6
| | | | 35 | 45.2 | 24 | 105 | 1
  Authors and Year: | Nishizawa and Fujimura, 1997
  Reporting:
  Method: | JOA score: 0 (severe pain) to 3 (no pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 58 | Degenerative Spondylolisthesis | Fusion and instrumentation | | 58 | 0 | 0 | 0 | 1.1
| | | | 58 | 63 | 28 | 128 | 2.7
  Authors and Year: | Knox, Harvell, Nelson et al., 1989
  Reporting: | Patient-reported
  Method: | Scale of 0 (none) to 10 (severe)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | | 24 | 0 | 0 | 0 | 7.4
| | | | 24 | 21.3 | 4 | 55 | 3.2 | | | 19 | | 2
  Study Design: | Case-series
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
  Reporting: | Patient-reported
  Method: | Analog Scale, 0-9. 5 levels of experience back or leg pain: Never, Rarely, Sometimes, Often, Very Often.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | | 36 | 0 | 0 | 0 | 7.35 | 2.36 | 3 | 3 | 5 | 7 | 18
| | | | 35 | 24 | | | 3.32 | 2.25 | 10 | 12 | 10 | 2 | 1
| | | | 36 | 78 | 60 | 129 | 3.25 | 3.32 | 9 | 11 | 9 | 3 | 4
  Authors and Year: | Grob, Humke, and Dvorak, 1996
  Reporting: | Patient-reported
  Method: | VAS 0-10 scale
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 18 | Degenerative/spondylolytic Spondylolisthesis | SWDL with Fusion and Instrumentation | | 16 | 0 | 0 | 0 | 7.6
| | | | 16 | 31 | 24 | 77 | 1.5
  Authors and Year: | Inoue, Watanabe, Goto et al., 1988
  Reporting:
  Method: | 4-level score on JOA scale
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Degenerative Spondylolisthesis | Fusion | | 36 | 0 | | | 1
| | | | 36 | 127 | 12 | 324 | 2.7
  Authors and Year: | Dall and Rowe, 1985
  Reporting: | Patient-reported
  Method: | 2 levels: Yes or No, pre- and post.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | | 17 | 0 | | | 15
| | | | 17 | 0 | 8 | 32 | 15

Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Rompe, Eysel, Zollner et al., 1999
  Reporting: | Patient-reported
  Method: | Pain severity from 1 (no pain) to 5 (very severe). Also the Turner Score- Good to Excellent: back and leg pain absent, minimal.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | | 39 | 0 | 0 | 0 | 3.8 | 0.7
| | | | 25 | 88.8 | | | 2.5 | 0.8 | | 9 | 6 | 10
2 | 51 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 51 | 0 | 0 | 0 | 3.5 | 0.8
| | | | 26 | 96 | | | 2.7 | 0.7 | | 8 | 9 | 9
3 | 27 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | | 27 | 0 | 0 | 0 | 3.6 | 0.8
| | | | 21 | 88.8 | | | 2.4 | 0.9 | | 5 | 10 | 6
  Authors and Year: | Sato and Kikuchi et al., 1997
  Reporting: | Patient-reported
  Method: | pretreatment-op JOA Score (extrapolate from graph)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 28 | Spondylosis and Degenerative Spondylolisthesis | Laminotomy - 2 level stenosis | | 28 | 0 | 0 | 0 | 13
| | | | 28 | 0 | | | 3.6 | 0.9
| | | | | 6 | | | 2.6
| | | | | 24 | | | 2.7
| | | | 28 | 55.2 | 12 | 96 | 21.6
2 | 53 | Spondylosis and Degenerative Spondylolisthesis | Laminotomy - 1 level stenosis | | 53 | 0 | 0 | 0 | 15
| | | | 37 | 0 | | | 4 | 0.7
| | | | | 6 | | | 2.1
| | | | | 24 | | | 2.3
| | | | 53 | 55.2 | 12 | 96 | 24
  Authors and Year: | Rompe, Eysel, Hopf et al., 1995
  Reporting: | Patient-reported
  Method: | Pain rating 0-4
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 24 | Mixed Stenosis | SWDL with Fusion and Instrumentation | | 24 | 0 | | | 2.83
| | | | 24 | 21.6 | 12 | 48 | 1.2
2 | 24 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 24 | 0 | | | 3.1
| | | | 24 | 25.9 | 12 | 50 | 0.7
3 | 12 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion and Instrumentation | | 12 | 0 | | | 2.9
| | | | 12 | 25.9 | 12 | 50 | 1
  Study Design: | Prospective Trial
  Authors and Year: | Jonsson, Annertz, Sjoberg et al., 1997a
  Reporting: | Patient-reported
  Method: | Number of patients with back pain
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | | 86 | 12 | | | | | | 44 | | 42
| | | | 86 | 24 | | | | | | 40 | | 46
| | | | 86 | 60 | | | | | | 40 | | 46

Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Study Design: | Controlled Trial
  Authors and Year: | Simotas, Dorey, Hansraj, et al., 2000
  Reporting: | Patient-reported
  Method: | 3 levels. Good: None or mild pain, Fair: Moderate pain, Poor: Very severe or severe pain
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Central Lumbar Stenosis | Conservative-various treatments | | 40 | 33 | 16 | 55 | | | | 16 | 17 | 7
2 | 9 | Central Lumbar Stenosis | Surgery - not described | | 9 | 33 | 16 | 55 | | | | 7 | 1 | 1
  Authors and Year: | Mariconda, Zanforlino, Celestino et al., 2000
  Reporting: | Patient-reported
  Method: | 0, 1, 2, 3 scale: 0- continuous severe pain, 1- occasional severe pain, 2- occasional mild pain, 3- none
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 20 | 0 | | | 1.1 | 1
| | | | 20 | 12 | | | 2 | 1
| | | | 20 | 24 | | | 1.5 | 1.3
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | | 17 | 0 | | | 1.2 | 1.1
| | | | 17 | 12 | | | 1.6 | 1
| | | | 17 | 24 | | | 1.1 | 1.1
  Authors and Year: | Johnsson, Uden, and Rosen, 1991
  Reporting: | Patient-reported
  Method: | 3 levels passed on a 0-100 visual analog scale. Good: 0-37.5, Fair: 37.6-62.5, Poor: 62.6-100. These groups were considered Mild,
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | Conservative-not described | | 19 | 31 | 7 | 51 | | | | 4 | 14 | 1
2 | 30 | Central Lumbar Stenosis - moderate stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 30 | 50 | 5 | 109 | | | | 13 | 14 | 3
3 | 14 | Central Lumbar Stenosis - severe stenosis | SWDL-Standard Wide Decompressive Laminectomy | | 14 | 58 | 3 | 120 | | | | 6 | 6 | 2

Evidence Table 14. Back Pain Relief Outcomes Related to Treatment of Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Grob, Humke, and Dvorak, 1995
  Reporting: | Patient-reported
  Method: | Based on increase or decrease in pain postsurgery and on difference in VAS score.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 28 | 24 | 32 | 6
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation | 15 | 28 | 24 | 32 | 5.8
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation | 15 | 28 | 24 | 32 | 5.8
  Study Design: | Prospective Trial
  Authors and Year: | Kleeman, Hiscoe, and Berg, 2000
  Reporting: | Patient-reported
  Method: | 4 levels: Resolved, Better, Same, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 46 | 30 | 13 | 51 | | | 33 | 17 | 1 | 0
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 45 | 48 | 31 | 69 | | | 18 | 20 | 6 | 1
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Ishac, Alhayek, Fournier et al., 1996
  Reporting: | Physician-reported
  Method: | Reported relief of symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 10 | 0.2 | 0 | 0 | | | | 3 | | 7
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 10 | 12 | 12 | 12 | | | | 4 | | 6
  Study Design: | Case-series
  Authors and Year: | Verbiest, 1979
  Reporting: | Patient-reported
  Method: | 2 Levels: Cured or Residual Symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 11 | Congenital Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 11 | 123 | 36 | 204 | | | 6 | | 2
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Baba, Uchida, Maezawa et al., 1996
  Reporting: | Physician-reported
  Method: | Reported number of patients with back pain before and after surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 31 | Lateral Lumbar Stenosis | Laminotomy | 26 | 38 | 12 | 88 | | | | 13 | | 13
Trials Examining Surgical Patients with Centralor Lateral Lumbar Stenosis (type of stenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Yone and Sakou, 1999
  Reporting: | Physician-reported
  Method: | Percent change in JOA score
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 37 | 24 | 52 | 19
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 43 | 24 | 60 | 75
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 33 | 24 | 54 | 82
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Silvers, Lewis, and Asch, 1993
  Reporting: | Patient-reported
  Method: | 4 levels: Excellent, Good, Fair, Poor. Excellent and Good were combined as a successful outcome.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 248 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 244 | 8.4 | 1 | 82 | | | | 227 | | 17
1 | 248 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 128 | 56.4 | 4 | 174 | | | | 82 | | 46
  Authors and Year: | Ganz, 1990
  Reporting: | Physician-reported
  Method: | 4 levels. 0- No improvement, 1-Some improvement, 2-Almost normal, 3-No symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 33 | 36 | 12 | 72 | 2 | 0.93
  Study Design: | Case-series
  Authors and Year: | Norcross-Nechay, Mathew, Simmons et al., 1999
  Reporting: | Patient-reported
  Method: | Number of patients reporting complete pain relief
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 70 | Mixed Stenosis | Decompressive Surgery with fusion and instrumentation | 70 | 11.8 | | | 44
  Authors and Year: | Spetzger, Bertalanffy, Reinges et al., 1997
  Reporting: | Patient-reported
  Method: | 3 Levels: No pain, Improved pain, Unimproved pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Mixed Stenosis | Laminotomy | 25 | 18 | 6 | 26 | | | 7 | 13 | | 5
  Authors and Year: | McCullen, Bernini, Bernstein et al., 1994
  Reporting: | Patient-reported
  Method: | 5 Levels: Is the back and/or leg pain Gone, Much better, Better, Worse, Much Worse?
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 193 | Mixed Stenosis | Decompressive Surgery | 118 | | | | | | 37 | 32 | 28 | 19 | 2
1 | 193 | Mixed Stenosis | Decompressive Surgery | 118 | 55 | 24 | 142 | | | 37 | 22 | 14 | 29 | 16
  Authors and Year: | Fast, Robin, and Floman, 1985
  Reporting: | Physician-reported
  Method: | Stated that back pain was milder after surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 19 | 23 | 12 | 36
  Authors and Year: | Hood and Weigl, 1983
  Reporting: | Patient-reported
  Method: | 2 levels: complete or partial relief
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 21 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | | 18 | 60 | | | 16 | 4
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Plotz and Benini, 1998
  Reporting: | Patient-reported
  Method: | 3 Levels: Improved, Unchanged, Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 17 | Degenerative Spondylolisthesis | Decompressive Surgery without fusion | 6 | 45 | 9 | 120 | | | 2 | | | 1 | 1
2 | 18 | Degenerative Spondylolisthesis | Decompressive Surgery with fusion and Translaminar Screw Fixation | 14 | 54 | 12 | 100 | | | 6 | | | 1 | 1
3 | 71 | Degenerative Spondylolisthesis | Decompressive Surgery with fusion and AO Internal Fixator | 64 | 28 | 9 | 100 | | | 32 | | | 2 | 5
  Authors and Year: | Yuan, Garfin, Dickman et al., 1994
  Reporting: | Physician-reported
  Method: | 3 levels. Improved, No change, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 2177 | Degenerative Spondylolisthesis | Fusion and Pedical Screw Fixation | 2121 | 12 | 1 | 51 | | | | 1941 | 165 | 15
2 | 456 | Degenerative Spondylolisthesis | Fusion | 449 | 12 | 1 | 51 | | | | 391 | 58 | 2
  Study Design: | Prospective Trial
  Authors and Year: | Rechtine, Sutterlin, Wood et al., 1996
  Reporting: | Patient-reported
  Method: | 5-point scale used to determine improvement. Severe, Moderate-to-severe, Moderate, Mild, None.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 18 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 18 | 24 | 24 | 24 | | | | 16 | 1 | 1
  Study Design: | Case-series
  Authors and Year: | Herron and Trippi, 1989
  Reporting: | Patient-reported
  Method: | Average % relief, number of patients with complete relief.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 24 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 34 | 18 | 71 | 84
  Authors and Year: | Alexander Jr, Kelly Jr, Davis Jr et al., 1985
  Reporting: | Patient-reported
  Method: | 3 Levels: Pain Free = Excellent, Much Less Pain = Good, No Improvement = Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 36 | 6 | 131 | | | 26 | 11 | | 4
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Rompe, Eysel, Zollner et al., 1999
  Reporting: | Patient-reported
  Method: | Patients were asked to estimate the percentage decrease in pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 25 | 88.8 | | | 44 | 36.8
2 | 51 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 26 | 96 | | | 40.7 | 34.2
3 | 27 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 21 | 88.8 | | | 46.2 | 32
  Authors and Year: | Postacchini, Cinotti, Perugia et al., 1993
  Reporting: | Patient-reported
  Method: | Improvement based on a 0-100 scale with 0 meaning greatest disability.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Congenital or Degenerative Stenosis, Combined, or Deg. Spondylolisthesis | Laminotomy | 26 | 44.4 | 26 | 64 | 63
2 | 41 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 44.4 | 26 | 64 | 42
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Study Design: | Controlled Trial
  Authors and Year: | Atlas, Deyo, Keller et al., 1996
  Reporting: | Patient-reported
  Method: | 3 levels. Gd: Better, Fr: Same, Pr: Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 12 | | | | | | 56 | 13 | 3
2 | 67 | Mixed Stenosis | Conservative-many | 58 | 12 | | | | | | 24 | 22 | 12
  Authors and Year: | Atlas, Keller, Robson, et al. 2000
  Reporting:
  Method: | See Atlas, Deyo, Keller, et al. 1996
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 67 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 67 | 48 | | | | | | 42 | 18 | 7
2 | 52 | Mixed Stenosis | Conservative-not described | 52 | 48 | | | | | | 20 | 18 | 14

Evidence Table 15. Disability and Dependency Outcomes Related to Treatment of Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Herno, Partanen, Talaslahti et al., 1999
  Reporting: | Patient-reported
  Method: | Oswestry questionnaire for low back pain disability.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 41 | Central Lumbar Stenosis - post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 133 | 113 | 157 | 31.2
2 | 15 | Central Lumbar Stenosis - no post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | 15 | 122 | 113 | 157 | 28.7
  Authors and Year: | Herno, Saari, Suomalainen et al., 1999
  Reporting: | Patient-reported
  Method: | Oswestry disability questionnaire
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Central Lumbar Stenosis - no postsurgery stenosis | Mixed Decompression Techniques | 35 | 47 | | | 28.4
2 | 57 | Central Lumbar Stenosis - post surgery stenosis | Mixed Decompression Techniques | 57 | 47 | | | 26.4
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Airaksinen, Herno, Turunen et al., 1997
  Reporting: | Patient-reported
  Method: | 2 levels and mean. Based on an Oswestry Low Back Pain Disability Score. 0-40 was good to excellent and 41-100 was poor to very
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 497 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 438 | 52 | | | 34 | 18 | 273 | | | 165
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type of stenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Little and MacDonald, 1994
  Reporting: | Patient-reported
  Method: | Oswestry Low Back Pain Questionnaire was used to calculate a percentage change in the disability index.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 60 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 60 | 6 | 5 | 10 | 32.7 | 51.4
1 | 60 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 40 | 24 | 18 | 36 | 37.7 | 42.9
2 | 34 | Lateral Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 34 | 6 | 5 | 10 | 38.8 | 39.8
2 | 34 | Lateral Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 13 | 24 | 18 | 36 | 32.6 | 37.5
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Case-series
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
  Reporting: | Patient-reported
  Method: | 3 Levels: Limited a lot, Limited a little, not limited.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 34 | 0 | | | | | 10 | | 5 | 19
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 31 | 24 | | | | | 13 | | 10 | 8
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 33 | 78 | 60 | 129 | | | 12 | | 12 | 9
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Study Design: | Controlled Trial
  Authors and Year: | Hurri, Slatis, Soini et al., 1998
  Reporting: | Patient-reported
  Method: | Oswestry Questionnaire for disability due to low-back pain (0-100).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 57 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 57 | 144 | | | 34.1
2 | 18 | Mixed Stenosis | Conservative-not described | 18 | 144 | | | 28.9
  Authors and Year: | Atlas, Deyo, Keller et al., 1996
  Reporting: | Patient-reported
  Method: | Score based on the Roland score for back disability. Lower score mean less disability.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 81 | 0 | | | 16
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 12 | | | 7.6
2 | 67 | Mixed Stenosis | Conservative-many | 67 | 0 | | | 12
2 | 67 | Mixed Stenosis | Conservative-many | 58 | 12 | | | 10.4
  Authors and Year: | Atlas, Keller, Robson, et al. 2000
  Reporting: | Patient-reported
  Method: | See Atlas, Deyo, Keller, et al. 1996
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 67 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 67 | 48 | | | 8.1
2 | | Mixed Stenosis | Conservative-not described | 52 | 48 | | | 9.6
  Authors and Year: | Herno, Airaksinen, Saari et al., 1996
  Reporting: | Patient-reported
  Method: | Oswestry score for back pain related disability
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Mixed Stenosis | Conservative-not described | 54 | | | | 37.8 | 16

Evidence Table 16. Global Success Outcomes Related to Treatment of Lumbar Spinal Stenosis

Randomized Controlled Trials of Patient Receiving Conservative Treatments
  Authors and Year: | Sinaki, Lutness, Ilstrup et al., 1989
  Reporting: | Patient-reported
  Method: | 2 Levels. "Recovered" based on only rare episodes of mild pain, able to perform job and leisure activities w/o restriction, no need for back support.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Degenerative Spondylolisthesis | Exercise/flexion | 26 | 3 | | | 15
| | | | 26 | 36 | | | 16
2 | 19 | Degenerative Spondylolisthesis | Exercise/extension | 18 | 3 | | | 1
| | | | 18 | 34.8 | | | 0
Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Grob, Humke, and Dvorak, 1995
  Reporting: | Patient-reported
  Method: | 4 levels: Very good = 75% relief, no analgesics or restrictions; Good = 50-74% relief, some analgesics & restrictions; Fair = <50% relief; Poor = pain worse than before surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 28 | 24 | 32 | | | 8 | 5 | 2
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation | 15 | 28 | 24 | 32 | | | 7 | 5 | | 3
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation | 15 | 28 | 24 | 32 | | | 4 | 6 | 3 | 2
  Study Design: | Controlled Trial
  Authors and Year: | Hanakita, Suwa, and MIzuno, 1999
  Reporting: | Patient-reported
  Method: | 4 levels. Ex: Cured, Gd: Better, Fr: Unchanged, Pr: Worse plus no comment
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 59 | Central Lumbar Stenosis - younger than 64 years | SWDL-Standard Wide Decompressive Laminectomy | 47 | | 12 | 96 | | | 18 | 18 | 4 | 7
2 | 61 | Central Lumbar Stenosis - older than 64 years | SWDL-Standard Wide Decompressive Laminectomy | 44 | | 12 | 96 | | | 15 | 14 | 2 | 13
3 | 16 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 12 | | 12 | 96 | | | 4 | 3 | 2 | 3
4 | 20 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 14 | | 12 | 96 | | | 4 | 8 | 1 | 1
  Authors and Year: | Herno, Partanen, Talaslahti et al., 1999
  Reporting: | Patient-reported
  Method: | 2 levels. Patients were asked whether their condition during the past 5 years had remained the same or improve (no-change group) or had worsened (final-change group).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 41 | Central Lumbar Stenosis - post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 133 | 113 | 157 | | | | 29 | | 12
2 | 15 | Central Lumbar Stenosis - no post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | 15 | 122 | 113 | 157 | | | | 11 | | 4
  Authors and Year: | Ray, 1982
  Reporting: | Physician-reported
  Method: | 4 levels: Nil, Minimum, Moderate, Excellent base on questionnaire addressing daily pain intensity, percentage of time in pain, activity level, and behavioral factors.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 48 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 48 | 10.1 | | | | | 12 | 25 | 7 | 4
12 | 17 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 17 | 12.6 | | | | | 5 | 4 | 6 | 2
  Authors and Year: | Surin, Hedelin, and Smith, 1982
  Reporting: | Physician-reported
  Method: | 3 levels. Ex: symptom-free, resumed all previous activities; Gd: resumed normal activities, recurrent back or leg pain; Fair and Poor combined: reduced previous activities due to pain, frankly disabled and pain not reduced.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Central Lumbar Stenosis - marked stenosis | SWDL-Standard Wide Decompressive Laminectomy | 15 | 29 | 14 | 70 | | | 3 | 9 | 3
2 | 7 | Central Lumbar Stenosis - moderate stenosis | SWDL-Standard Wide Decompressive Laminectomy | 7 | 29 | 14 | 70 | | | 5 | 2 | 0 | 0
  Authors and Year: | Tajima, Fukazawa, and Ishio, 1980
  Reporting: | Physician-reported
  Method: | 3 levels. Good: symptoms disappeared, no restrictions for daily life and work, Fair: occasional low back pain, no inconveniences in daily life, Poor: not improved or slightly aggravated.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 13 | Central Lumbar Stenosis | Mixed Decompression Techniques | 13 | 3 | | | | | | 11 | 2
2 | 14 | Central Lumbar Stenosis and disk lesion | Mixed Decompression Techniques | 14 | 3 | | | | | | 12 | 2
  Study Design: | Prospective Trial
  Authors and Year: | Kleeman, Hiscoe, and Berg, 2000
  Reporting: | Patient-reported
  Method: | 4 levels: Very satisfied, somewhat satisfied, somewhat dissatisfied, very dissatisfied
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 51 | 30 | 13 | 51 | | | 36 | 13 | 4 | 0
| | | | 48 | 48 | 31 | 69 | | | 34 | 17 | 0 | 0
  Authors and Year: | Weiner, Walker, Brower et al., 1999
  Reporting: | Patient-reported
  Method: | Neurogenic Claudication Outcome Score (max = 100 asymptomatic with full function. 5 level surgical success scale: Ex: complete relief, Gd: a good deal of relief, Fr: only a little relief, Pr: no relief, VPr: worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 30 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 30 | | | | 67 | | 13 | 13 | 3 | 1 | 0
| | | | 30 | 0 | | | 32
  Authors and Year: | diPierro, Helm, Shaffrey et al., 1996
  Reporting: | Patient-reported
  Method: | Patient satisfied or not satisfied with surgery
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Central Lumbar Stenosis | Partial laminectomy and fusion | 29 | 30 | | | | | | 20 | 9
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Matsui, Kanamori, Ishihara et al., 1997
  Reporting: | Patient-reported
  Method: | Japanese Orthopaedic Association evaluation system. Scored from 0-29. % recovery rate of pre- and post-op scores determined Excellent (>75&), Good (50-75), Fair (25-50), Poor (<25).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 27 | 0 | 0 | 0 | 11 | 3.9
| | | | 27 | 2 | 2 | 2 | 19.3
| | | | 27 | 36 | | | 23.2
| | | | 27 | 67 | | | 23.8 | 3 | 10 | 12 | 4 | 1
  Authors and Year: | Ishac, Alhayek, Fournier et al., 1996
  Reporting: | Physician-reported
  Method: | 3 levels. Good (Ex): no symptoms and resumption of former activities, Acceptable (Gd) alleviation of symptoms, normal daily activities, Poor (Pr): no change, worsening of symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 34 | 12 | | | | | 18 | 11 | | 5
  Authors and Year: | Mullin, Rea, Irsik et al., 1996
  Reporting: | Patient-reported
  Method: | 5 level functional rating. V Pr: bedridden, Pr: self-care with aid, Fr: self-care alone, Gd: most desired activities, Ex: all desired activities.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 72 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 0 | 0 | 0 | | | 3 | 4 | 8 | 6 | 2
| | | | 24 | 31 | 14 | 63 | | | 10 | 7 | 6 | 1 | 0
  Authors and Year: | Caputy and Luessenhop, 1992
  Reporting: | Patient-reported
  Method: | Patient rated success or failure of surgery
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 100 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 96 | 12 | 12 | 12 | | | | 86 | | 10
| | | | 88 | 60 | 60 | 60 | | | | 64 | | 24
| | | | 18 | 96 | 96 | 96 | | | | 12 | | 6
  Authors and Year: | Dhar and Porter, 1992
  Reporting: | Patient-reported
  Method: | 4 levels. Ex: No pain or functional limitation, Gd: Intermittent pain, no functional limitation, Fr: Intermittent pain affecting function, Pr: Constant pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 36 | 12 | 12 | 12 | | | 4 | 7 | 18 | 7
  Authors and Year: | Chahal, Mundkur, Sancheti et al., 1982
  Reporting: | Physician-reported
  Method: | 3 levels. Good, Fair, and Poor undefined.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 32 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 32 | | 6 | 30 | | | | 22 | 7 | 3
| | | | 32 | 1 | 1 | 1 | | | | 24 | 5 | 3
  Authors and Year: | Rosomoff, 1981
  Reporting: | Physician-reported
  Method: | 3 levels. Good to Excellent: pain-free or full activity with some pain, Fair: moderately restricted, Poor and Very Poor: severely restricted to totally disabled.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 50 | | 6 | 120 | | | | 25 | 12 | 13
  Authors and Year: | Getty, 1980
  Reporting: | Physician-reported
  Method: | 3 levels. Good: pain relieved, Fair: partial pain relief with recurrence after heavy work, Poor: no relief or pain increased
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 28 | 42 | 12 | 120 | | | | 15 | 8 | 5
  Authors and Year: | Reale, Deifini, Gambacona et al., 1978
  Reporting: | Patient-reported
  Method: | 3 levels/ Ex: patients goes back to work and is free or nearly free from pain, Gd: patient has gone back to work but has to rest now and again, Pr: all other conditions even if patient has improved.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 37 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 33 | 19 | | | | | 15 | 8 | | 10
  Authors and Year: | Verbiest, 1977
  Reporting: | Physician-reported
  Method: | 2 levels. Complete relief of symptoms and signs v. permanent residual or new symptoms.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 116 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 91 | 88 | 12 | 240 | | | | 62 | | 29
  Study Design: | Case-series
  Authors and Year: | Kurihara, Tanaka, Tsumura et al., 1988
  Reporting: | Physician-reported
  Method: | 2 Levels. Satisfactory or unsatisfactory, also described as good or fair. Not defined.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 12 | Hyperostotic stenosis | SWDL-Standard Wide Decompressive Laminectomy | 12 | | | | | | | 11 | 1
  Authors and Year: | Young, Veerapen, and O'Laoire, 1988
  Reporting: | Physician-reported
  Method: | 4 Levels: Good, Fair, Marginal, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 32 | Central Lumbar Stenosis | Decompressive Surgery | 32 | 39.8 | 17 | 58 | | | | 21 | 6 | 4 | 1
  Authors and Year: | Hall, Bartleson, Onofrio et al., 1985
  Reporting: | Physician-reported
  Method: | 3 levels: Very good to excellent, Lesser degrees of satisfaction, little or no use.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 68 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 62 | 48 | 35 | 65 | | | | 38 | 14 | 10
  Authors and Year: | Weinstein, Scafuri, and McNeill, 1983
  Reporting: | Physician-reported
  Method: | 4 levels. Back Analysis Form sections converted to a numerical ranking for Excellent (85-100), Good (71-84), Fair (60-70), Poor (0-60)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 24 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 23 | 13 | 50 | 78.2 | | 9 | 7 | 3 | 3
  Authors and Year: | Johnsson, Willner, and Pettersson, 1981
  Reporting: | Physician-reported
  Method: | 4 levels. Ex: no symptoms, Gd: slight residual pain, Unchanged (Fr): no relief of symptoms, Worse (Pr): increased pain. Also Improved and No Change/Worse. Individual data is presented for walking.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 27 | 22 | 3 | 79 | | | 10 | 6 | 5 | 6
  Authors and Year: | Weir and De Leo, 1981
  Reporting: | Physician-reported
  Method: | 4 levels. Cured, Better, Unchanged, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 81 | | 3 | 144 | | | 17 | 60 | 2 | 2
  Authors and Year: | Salibi, 1976
  Reporting: | Physician-reported
  Method: | 3 Levels: Good: Full return to premorbid activities; Fair: partial return; Poor: Became more comfortable, but not rehabilitated. No followup time period is reported.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 19 | | | | | | | 14 | 4 | 1
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Lee and deBari, 1986
  Reporting: | Patient-reported
  Method: | Scoring system from 0-100 to evaluate patient pain and degree of tolerable activities of daily living.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 12 | Lateral Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 12 | 0 | 0 | 0 | 21.4 | 9.23
| | | | 12 | 38 | 12 | 72 | 53.6 | 19.1
2 | 12 | Lateral Lumbar Stenosis | SWDL with Fusion and Instrumentation | 12 | 0 | 0 | 0 | 18.9 | 8.7
| | | | 12 | 38 | 12 | 72 | 50.5 | 12.4
  Study Design: | Controlled Trial
  Authors and Year: | Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982
  Reporting: | Patient-reported
  Method: | 4 levels. Ex: great improvement, Gd: slight improvement, Fr: no improvement, Pr: worsening
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Lateral Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 36 | | 120 | | | 3 | | 6 | 6
2 | 32 | Lateral Lumbar Stenosis with disk herniation | Partial laminectomy or hemilaminectomy | 26 | 36 | | 120 | | | 18 | | 5 | 2 | 1
3 | 21 | Lateral and Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 18 | 36 | | 120 | | | 11 | | 3 | 4
4 | 21 | Lateral and Central Lumbar Stenosis with disk herniation | Partial laminectomy or hemilaminectomy | 18 | 36 | | 120 | | | 16 | | 2
  Authors and Year: | Mikhael, Ciric, Tarkington et al., 1981
  Reporting: | Physician-reported
  Method: | 4 levels. Ex: Disabling low back and leg pain disappeared; Gd: Occasional slight backache or rarely paresthesia of the leg; Fr: Mild symptoms persisted or recurred; Pr: Gradually worsened.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 35 | | 12 | 40 | | | 24 | 6 | 4 | 1
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Baba, Uchida, Maezawa et al., 1996
  Reporting: | Patient-reported
  Method: | 2 levels: Excellent and Good: complete recovery or improved with minimal leg discomfort, Fair and Poor: residual radicular symptoms or symptoms and signs unchanged or worsened.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 31 | Lateral Lumbar Stenosis | Laminotomy | 31 | 38 | 12 | 88 | | | | 25 | | 6
  Authors and Year: | Sanderson and Getty, 1996
  Reporting: | Patient-reported
  Method: | 3 levels based on patient satisfaction with leg pain. Good: improved, Fair: no Change, Poor: worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 12 | 12 | 12 | | | | 47 | 10
| | | | 57 | 101 | 60 | 132 | | | | 50 | 5 | 2
  Authors and Year: | Aryanpur and Ducker, 1990
  Reporting: | Patient-reported
  Method: | 3 levels. Good: complete relief of symptoms, No change, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 32 | Lateral Lumbar Stenosis | Laminotomy | 32 | 24 | 12 | | | | | 29 | 2 | 1
  Study Design: | Case-series
  Authors and Year: | Choudhury and Taylor, 1977
  Reporting: | Patient-reported
  Method: | 4 Levels: Excellent: Pain free, unrestricted activity. Good: Occasional pain, but normal activities. Fair: Improved capacity, but not full activity. Poor: No Improvement.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 28 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 28 | | | | | | 24 | 2 | 2 | 0
  Authors and Year: | Epstein, Epstein, Rosenthal et al., 1972
  Reporting: | Patient-reported
  Method: | 3 Levels: Excellent: Regained and maintained normal activity; Good: Minimal residual discomfort and disability. Able to return to work; Fair: Improved, but still had significant functional impairment.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Lateral Lumbar Stenosis | Foraminotomy/nerve root decompression | 15 | | 6 | 60 | | | 11 | 3 | 1
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type ofstenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Epstein, 1999
  Reporting: | Physician-reported
  Method: | Odom's Criteria, 4 Levels, Excellent, Good, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 10 | Ossification of the Posterior Longitudinal Ligament | SWDL-Standard Wide Decompressive Laminectomy | 10 | 44.4 | 6 | 132 | | | 5 | 2 | 2 | 1
2 | 11 | Ossification of the Yellow Ligament | SWDL-Standard Wide Decompressive Laminectomy | 11 | 84 | 12 | 132 | | | 5 | 4 | 2
  Authors and Year: | Yone and Sakou, 1999
  Reporting: | Physician-reported
  Method: | 4 Levels, Excellent, Good, Fair, Poor, based on percent improvement. Presumable this is % improvement in overall JOE score, but this is not explicitly stated.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis with instability | Laminectomy | 14 | 37 | 24 | 52 | | | 2 | 4 | 1 | 7
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 43 | 24 | 60 | | | 10 | 6 | 3 | 0
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 33 | 24 | 54 | | | 13 | 9 | 5 | 0
  Authors and Year: | Javid and Hadar, 1998
  Reporting: | Patient-reported
  Method: | 2 levels. Good: Successful; Poor: Unsuccessful.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 85 | 1.5 | | | | | | 75 | | 10
| | | | 82 | 6 | | | | | | 71 | | 11
| | | | 83 | 12 | | | | | | 58 | | 25
| | | | 72 | 57.2 | 12 | 132 | | | | 51 | | 21
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy | 61 | 1.5 | | | | | | 49 | | 12
| | | | 59 | 6 | | | | | | 46 | | 13
| | | | 57 | 12 | | | | | | 44 | | 13
| | | | 52 | 56.6 | 12 | 132 | | | | 35 | | 17
3 | 23 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 21 | 1.5 | | | | | | 12 | | 9
| | | | 22 | 6 | | | | | | 14 | | 8
| | | | 23 | 12 | | | | | | 15 | | 8
| | | | 22 | 86.6 | 12 | 132 | | | | 14 | | 8
  Authors and Year: | Kalbarczyk, Lukes, and Seiler, 1998
  Reporting: | Patient-reported
  Method: | 6-level scale. 1=Pain Free, 2= mild pain, 3=Fair pain, 4=slight pain relief, 5=unchanged, 6=worsened. No one got a 6.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 93 | Mixed Stenosis - without instability | SWDL-Standard Wide Decompressive Laminectomy | 93 | | 2 | 3 | | | 44 | 35 | 7 | 6 | 1
2 | 46 | Mixed Stenosis - mild instability | Partial laminectomy or hemilaminectomy | 46 | | 2 | 3 | | | 22 | 12 | 7 | 3 | 2
3 | 9 | Mixed Stenosis - high instability | Partial laminectomy and fusion | 8 | | 2 | 3 | | | 6 | 1 | 0 | 1 | 0
  Authors and Year: | Kawauchi, Yone, and Sakou, 1996
  Reporting: | Patient-reported
  Method: | Stauffer's criteria (relief of back and leg pain, return to employment, restriction of physical activities, use of analgesic) [Good/Fair/Poor]
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 7 | Mixed Stenosis - slight adhesion | Partial laminectomy and fusion | 7 | 33 | 24 | 61 | | | | 4 | 3
2 | 16 | Mixed Stenosis - moderate | Partial laminectomy and fusion | 16 | 33 | 24 | 16 | | | | 6 | 8 | 2
  Authors and Year: | Pai and Kumar, 1996
  Reporting: | Patient-reported
  Method: | 4-Level rating, Excellent, Good, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 30 | Congenital Stenosis | Decompressive Surgery | 30 | 42 | 24 | 60 | | | 2 | 19 | 9 | 0
| | | | 26 | 78 | | | | | 3 | 18 | 5 | 0
2 | 23 | Mixed Stenosis | Decompressive Surgery | 23 | 42 | 24 | 60 | | | 2 | 15 | 4 | 2
| | | | 20 | 78 | | | | | 0 | 15 | 4 | 1
  Authors and Year: | Cinotti, Postacchini, and Weinstein, 1994
  Reporting: | Patient-reported
  Method: | 4 levels. Excellent: no leg pain, full normal activities. Good: some leg pain, normal activities. Fair: moderate pain, mild restriction of activities. Poor: little or no improvement, seriously restricted activities.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 25 | Mixed Stenosis - diabetes | SWDL-Standard Wide Decompressive Laminectomy | 25 | 41 | 24 | 88 | | | 4 | 14 | 5 | 2
2 | 4 | Mixed Stenosis - no diabetes | SWDL-Standard Wide Decompressive Laminectomy | 25 | 41 | 24 | 88 | | | 5 | 15 | 3 | 2
  Authors and Year: | Simpson, Silveri, Balderston et al., 1993
  Reporting: | Physician-reported
  Method: | 4 levels. Based on patient symptoms, clinical results were rated as Excellent: no recurrence, no low-back dysfunction; Good: occasional pain; Fair: persistent symptoms with some limitations; Poor: condition same or worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 33 | Mixed Stenosis - diabetes | SWDL-Standard Wide Decompressive Laminectomy | 24 | 60 | 24 | 108 | | | 3 | 7 | 12 | 2
2 | 24 | Mixed Stenosis - no diabetes | SWDL-Standard Wide Decompressive Laminectomy | 22 | 84 | 66 | 120 | | | 14 | 6 | 1 | 1
  Authors and Year: | Nasca, 1989
  Reporting: | Physician-reported
  Method: | 3 levels: Good Fair Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Lateral Lumbar Stenosis | Decompressive Surgery | 15 | | 24 | 108 | | | | 10 | 5 | 0
2 | 29 | Central-mixed Stenosis | Decompressive Surgery | 29 | | 24 | 108 | | | | 26 | 3 | 0
3 | 16 | Central-mixed Stenosis | Decompressive Surgery with fusion and instrumentation | 16 | | 24 | 108 | | | | 11 | 3 | 2
4 | 21 | Post-surgical stenosis | Decompressive Surgery | 21 | | 24 | 84 | | | | 13 | 5 | 3
5 | 22 | Mixed Stenosis with instability | Decompressive Surgery with fusion and instrumentation | 22 | | 24 | 84 | | | | 15 | 4 | 3
6 | 11 | Degenerative Stenosis and scoliosis | Decompressive Surgery with fusion and instrumentation | 11 | | 24 | 84 | | | | 7 | 4 | 0
  Authors and Year: | Nather and Thomas, 1985
  Reporting:
  Method: | Patient reports 4 levels: Excellent, partial, same, worse. Doctor reports 4 levels: Excellent, Good, Fair, Poor. Both are stratified by diagnosis.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 11 | Mixed Stenosis | Decompressive surgery with or without fusion | 14 11 | 27.6 27.6 | 10 10 | 84 84 | | | 5 7 | 0 2 | 5 1 | 2 1 | 2
2 | 14 | Mixed Stenosis and Congenital combined | Decompressive surgery with or without fusion | 14 11 | 27.6 27.6 | 10 10 | 84 84 | | | 5 7 | 5 0 | 0 4 | 4 0 | 0
  Authors and Year: | Paine, 1976
  Reporting: | Patient-reported
  Method: | 4 Levels. Excellent: Returned to normal activities with little or no discomfort. Good: Minimal restrictions, occasional pain. Fair: Lighter or part-time employment, occasional debilitating pain. Poor: No work, limited activities.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 95 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 95 | | | | | | 46 | 30 | 11 | 8
2 | 48 | Degenerative stenosis with disk herniation | SWDL-Standard Wide Decompressive Laminectomy | 48 | | | | | | 31 | 6 | 5 | 6
  Authors and Year: | Shenkin and Hash, 1976
  Reporting: | Physician-reported
  Method: | 3 level. Excellent: all pain has been relieved and resumed normal activity; Good: normal activities are resumed but has occasional complaints; Poor: all other results even though patient may have improved.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 49 | Mixed Stenosis - no prior surgery | SWDL-Standard Wide Decompressive Laminectomy | 46 | 30 | | | | | 38 | 5 | | 3
2 | 21 | Mixed Stenosis - prior surgery for herniated disk | SWDL-Standard Wide Decompressive Laminectomy | 21 | | 24 | 72 | | | 13 | 5 | | 3
  Authors and Year: | Tile, McNeil, Zarins et al., 1976
  Reporting: | Physician-reported
  Method: | 4 levels. Excellent, Good, Fair, Poor not defined.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Mixed Stenosis | Mixed Decompression Techniques | 26 | 60 | 24 | 240 | | | 9 | 15 | 1 | 1
2 | 18 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 18 | 60 | 24 | 240 | | | 8 | 7 | 1 | 2
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Crock, Shiraishi, and Crock, 1995
  Reporting: | Physician-reported
  Method: | 4 levels. Ex: complete relief of symptoms, Gd: pain improved, walking increased, Fr: Symptoms unchanged, Pr: deterioration in any on the of the three major symptoms (pain, bladder dysfunction, walking).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 34 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | 34 | 38 | 14 | 72 | | | 14 | 16 | 4 | 0
  Authors and Year: | Silvers, Lewis, and Asch, 1993
  Reporting: | Patient-reported
  Method: | Patient satisfaction with surgery was scored as: yes, yes with some limitation, and no. Success was the sum of the first 2 scores.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 248 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 128 | 56.4 | 4 | 174 | | | | 96 | | 32
  Authors and Year: | Katz, Lipson, Larson et al., 1991
  Reporting: | Patient-reported
  Method: | 4 levels. 1: very satisfied, 2: Somewhat satisfied, 3: Somewhat dissatisfied, 4: Very dissatisfied
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Mixed Stenosis | Mixed Decompression Techniques | 69 | 50 | 34 | 82 | | | 33 | 15 | 8 | 13
  Authors and Year: | Ganz, 1990
  Reporting: | Physician-reported
  Method: | Combined back and leg pain scores. Good: 4 to 6; Poor 0 to 3.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 33 | 36 | 12 | 72 | | | | 27 | | 6
  Study Design: | Case-series
  Authors and Year: | Guigui, Benoist, Delecourt et al., 1998
  Reporting: | Physician-reported
  Method: | Provided pre- and postoperative mean scores from a questionnaire.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Mixed Stenosis | Decompressive Surgery | 50 50 | 3 | 1 | 10 | 7.6 16
  Authors and Year: | Mackay and Wheelwright, 1998
  Reporting: | Physician-reported
  Method: | 5 Levels: Excellent: pain free; Good: pain improved; Fair: pain improved but occasional medication; Marginal: pain improved but requires frequent medication; Poor: pain unimproved or worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | 50 | 32 | 12 | 49 | | | 16 | 14 | 14 | 2 | 4
  Authors and Year: | Scholz, Firsching, and Lanksch, 1998
  Reporting: | Patient-reported
  Method: | Two measures: One had 4 levels: A, no pain or complaints. B, improved. C, Unimproved. D, deteriorated. The other had 3 levels: Excellent or good, Indifferent, Not Satisfied.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 72 | Mixed Stenosis | Decompressive Surgery | 72 72 47 | 30 30 96 | 18 18 | 42 42 | | | 9 | 53 35 | 11 | 8 7 | 21
  Authors and Year: | Tsai, Yang, and Bray, 1998
  Reporting:
  Method: | Doctors rated Excellent, Good, Fair Poor. Patients rated Very satisfied, somewhat sat., Somewhat dissatisfied and Very dissatisfied.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 62 | Mixed Stenosis | Laminotomy | 62 62 | 27 27 | 15 15 | 48 48 | | | 30 18 | 10 16 | 2 8 | 8 8
  Authors and Year: | Spetzger, Bertalanffy, Reinges et al., 1997
  Reporting: | Patient-reported
  Method: | 4 Levels: Excellent: Complete relief; Good: mild pain, normal activity and relief of claudication; Fair: Some improvement; Poor: Unchanged or worsened.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Mixed Stenosis | Laminotomy | 25 | 18 | 6 | 26 | | | 7 | 15 | 3 | 0
  Authors and Year: | Katz, Lipson, Chang et al., 1996
  Reporting: | Patient-reported
  Method: | Two 4-level scales: Very satisfied, Somewhat satisfied, Somewhat dissatisfied, Very dissatisfied or Would patient have the operation again? Definitely, Probably, probably not, definitely not.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 55 55 | | 84 84 | 120 120 | | | 37 30 | 6 12 | 1 6 | 9 7
  Authors and Year: | Lehto and Honkanen, 1995
  Reporting: | Patient-reported
  Method: | 4 Levels, Excellent, Good, Satisfactory, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 96 | Mixed Stenosis | Decompressive Surgery | 65 | 66 | 36 | 132 | | | 9 | 28 | 14 | 14
  Authors and Year: | Stucki, Liang, Fossel et al., 1995
  Reporting: | Patient-reported
  Method: | 4-Level Likert scale: Very satisfied, 1 point. Somewhat satisfied, 2 patients, Somewhat dissatisfied, 3pts. Very dissatisfied, 4 points.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 230 | Mixed Stenosis | Decompressive Surgery | 130 | 6 | | | 2 | 0.85
  Authors and Year: | McCullen, Bernini, Bernstein et al., 1994
  Reporting:
  Method: | Patient reports 5 Levels: Very Satisfied, Satisfied, Somewhat Satisfied, Somewhat dissatisfied, Very Dissatisfied. Physician reports 3 Levels: Good, Fair, Poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 193 | Mixed Stenosis | Decompressive Surgery | 118 118 | 55 55 | 24 24 | 142 142 | | | 56 | 18 59 | 18 32 | 17 27 | 9
  Authors and Year: | Brodsky, Hendricks, Khalil et al., 1989
  Reporting: | Patient-reported
  Method: | 2 Levels: Good to Excellent or Fair to Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 34 | Mixed Stenosis | Fusion | 34 | 55.2 | 6 | 390 | | | | 30 | 4
  Authors and Year: | Jalovaara, Lahde, Iikko et al., 1989
  Reporting: | Patient-reported
  Method: | 4 levels, Good (Ex): none or slight pain, Fair (Gd): residual symptoms, Unchanged (Fr): no relief of symptoms, Worse (Pr): increased pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 31 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 31 | 44.4 | 10 | 84 | | | 9 | 14 | 5 | 3
  Authors and Year: | Johnsson, Redlund-Johnell, Uden et al., 1989
  Reporting: | Patient-reported
  Method: | 2 Levels: Good, or poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 61 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 61 | 51 | 12 | 156 | | | | 36 | | 25
  Authors and Year: | Mauersberger and Nietgen, 1989
  Reporting: | Patient-reported
  Method: | 3 Levels: Improved, unimproved, worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 92 | Mixed Stenosis | Decompressive surgery with or without fusion | 66 | | 12 | 84 | | | | 53 | | 7 | 6
  Authors and Year: | Boccanera, Pellicioni, and Laus, 1984
  Reporting: | Physician-reported
  Method: | 3 levels- Good, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 25 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 25 | 36 | 24 | 72 | | | | 8 | 11 | 6
  Authors and Year: | Hood and Weigl, 1983
  Reporting: | Physician-reported
  Method: | 3 levels: Good, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 21 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | | 18 | 60 | | | | 19 | 1 | 0
  Authors and Year: | Scafuri and Weinstein, 1981
  Reporting: | Physician-reported
  Method: | 100 point scale based on pain, function, and physical findings. Excellent: 85-100; Good: 71-84; Fair: 60-70; Poor: less than 60.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 25 25 | 0 15.6 | 0 6 | 0 43 | 47.4 78.2 | | 9 | 7 | 3 | 3
  Authors and Year: | Echeverria and Lockwood, 1979
  Reporting: | Both Patient and
  Method: | 4 Levels: Excellent, complete resolution; Good, Some disability and reduced activity; Fair, slight improvement; Poor, No improvement or worsened.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 35 | 45.6 | 12 | 168 | | | 5 | 10 | 2 | 3
  Authors and Year: | Scapinelli, 1978
  Reporting: | Physician-reported
  Method: | 3 Levels. Excellent: complete relief of pain and neurological features of lower limbs. Good: improvement of symptoms. Poor: no benefit.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 23 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 23 | 2 | | | | | 17 | 4 | | 2
  Authors and Year: | Vestad and Naca, 1977
  Reporting: | Patient-reported
  Method: | 3 Levels: Excellent, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 80 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 80 | 56.4 | | | | | 40 | | 20 | 20
  Authors and Year: | McKinley and Davis, 1976
  Reporting: | Patient-reported
  Method: | 2 Levels: Successful or Not.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 32 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 18 | | 14 | 44 | | | | 16 | | 2
  Authors and Year: | Teng and Papatheodorou, 1963
  Reporting: | Patient-reported
  Method: | 4 Levels: Asymptomatic, Improved Slightly Improved, Unimproved.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 29 | | 12 | 66 | | | 18 | 8 | 3 | 2
  Authors and Year: | Epstein, Epstein, and Lavine, 1962
  Reporting: | Patient-reported
  Method: | 4 Levels: Excellent, Good, Fair, Poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Mixed Stenosis | Mixed Decompression Techniques | 29 | | 12 | 42 | | | 13 | 10 | 2 | 4
  Authors and Year: | Epstein, 1960
  Reporting: | Patient-reported
  Method: | 4 Levels: Excellent, Good, Modest (Fair) and Failure (Poor)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 14 | | 6 | 84 | | | 4 | 4 | 3 | 3
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Plotz and Benini, 1998
  Reporting: | Physician-reported
  Method: | 5 Levels: Excellent: Pain at least 90% reduced; Good: Pain at least 70% Reduced; Fair: Pain at least 50% reduced requiring mild analgesics; Poor: Pain at least 50% reduced requiring strong analgesics or opiates; Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 17 | Degenerative Spondylolisthesis | Decompressive Surgery without fusion | 17 | | | | | | 2 | 1 | 2 | 1 | 11
| | | | 15 | 54 | 12 | 100 | | | 4 | 5 | 3 | 0 | 3
  Authors and Year: | Satomi, Hirabayashi, Toyama et al., 1992
  Reporting: | Patient-reported
  Method: | JOA score from −6 to 15.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Degenerative Spondylolisthesis | Fusion and instrumentation | 27 | 0 | 0 | 0 | 7.9
| | | | 27 | 36 | | | 13.4 | | 15 | 10 | 2
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 14 | 0 | 0 | 0 | 7.1
| | | | 14 | 36 | | | 11.5 | | 5 | 5 | 3 | 1
  Authors and Year: | Lombardi, Wiltse, Reynolds et al., 1985
  Reporting: | Physician-reported
  Method: | 5 Levels: Excellent, Good, Fair, Poor, Failure
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 32.4 | 24 | 84 | | | 6 | 10 | 1 | 3 | 0
2 | 21 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 21 | 32.4 | 24 | 84 | | | 11 | 8 | 0 | 1 | 1
  Study Design: | Prospective Trial
  Authors and Year: | Nakai, Yoshizawa, and Kobayashi, 1999
  Reporting: | Patient-reported
  Method: | Patient reported pain and requirement for medication.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 23 | Degenerative Spondylolisthesis | Fusion only | 18 | 94 | 60 | 144 | | | 8 | 5
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Fischgrund, Mackay, Herkowitz et al., 1997
  Reporting: | Physician-reported
  Method: | 4 levels. Excellent (unrestricted and pain free), good (unrestricted and improved), fair (restricted and some pain), poor (no postsurgical improvement and still in pain).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
| | | | 35 | 28 | 24 | 36 | | | 20 | 7 | 4 | 4
2 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis)
| | | | 35 | 28 | 24 | 36 | | | 16 | 12 | 1 | 4
  Authors and Year: | Herkowitz and Kurz, 1991
  Reporting: | Physician-reported
  Method: | 4 levels. Excellent: unrestricted activity, complete relief of pain, Good: occasional discomfort, major improvement, unrestricted, Fair: intermittent discomfort, improvement, restrictions, Poor: major discomfort, no improvement.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 25 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy
| | | | 25 | 36 | 29 | 48 | | | 11 | 13 | 1
2 | 25 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis)
| | | | 25 | 36 | 29 | 48 | | | 2 | 9 | 12 | 2
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Nishizawa and Fujimura, 1997
  Reporting: | Patient-reported
  Method: | JOA score: maximum 15
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 58 | Degenerative Spondylolisthesis | Fusion and instrumentation
| | | | 58 | 0 | 0 | 0 | 7.3
| | | | 58 | 63 | 28 | 128 | 13.3 | | | 53 | | 5
  Authors and Year: | Moller, Wittenberg, Nolte et al., 1992
  Reporting: | Patient-reported
  Method: | 4 levels based on a questionnaire with 0-100 points accumulated for back pain, leg pain, Laseque sign, pain-free walking distance, use of analgesics, and need of braces or crutches. Ex 0-15, Gd 16-34, Acceptable 35-49, Fr 50-65, Pr >65.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 37 | Degenerative Spondylolisthesis | Fusion
| | | | 37 | 46.8 | 12 | 78 | | | 19 | 11 | 3 | 2 | 2
  Authors and Year: | Marchesi, Thalgott, and Aebi, 1991
  Reporting: | Patient-reported
  Method: | 3 levels. Good: 75% back and leg pain relief, Fair: 25-75% back and leg pain relief, Poor: 25% back and leg pain relief.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 30 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
| | | | 30 | 41 | 20 | 50 | | | | 16 | 10 | 4
  Authors and Year: | Takahashi, Kitahara, Yamagata et al., 1990
  Reporting: | Patient-reported
  Method: | Total score from the Japanese Orthopaedic Association, maximum 29 points, Satisfactory was 25 points or more
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | Fusion
| | | | 19 | 0 | 0 | 0 | 13.2
| | | | 19 | 151 | 6 | 360 | 24.4 | | | 25 | | 10
  Authors and Year: | Knox, Harvell, Nelson et al., 1989
  Reporting: | Patient-reported
  Method: | 4 levels of satisfaction. Very satisfied (no symptoms), Satisfied (much better), Somewhat satisfied (somewhat better), Unsatisfied (same or worse)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
| | | | 24 | 21.3 | 4 | 55 | | | 9 | 9 | 5 | 1
  Study Design: | Case-series
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
  Reporting: | Physician-reported
  Method: | 3 Levels of Patient satisfaction.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 36 | 78 | 60 | 129 | | | 30 | 10 | 0 | 3 | 3
  Authors and Year: | Epstein, 1998a
  Reporting: | Physician-reported
  Method: | 4-Level Scale: Excellent, Good, Fair, Poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 290 | Mixed Stenosis Mixed | Decompression Techniques | 290 | 120 | 12 | 324 | | | 200 | 38 | 35 | 17
  Authors and Year: | Epstein, 1998b
  Reporting: | Physician-reported
  Method: | 4-Level scale: Excellent, Good, Fair, Poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 28 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 28 | 38 | 9 | 67 | | | 20 | 4 | 3 | 1
  Authors and Year: | McCulloch, 1998
  Reporting:
  Method: | Patient reported satisfaction yes/no, Physician reported success Yes/No
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 23 | Degenerative Spondylolisthesis | Partial laminectomy and fusion | 21 | 38 | 24 | 56 | | | | 16 | | 5
  Authors and Year: | Mochida, Toh, Suzuki et al., 1997
  Reporting: | Physician-reported
  Method: | JOA score, which was neither referenced nor defined. At least 12 out of 15 points was considered a satisfactory response.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 10 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 10 | 30 | 24 | 38 | 13.3 | 0.9
  Authors and Year: | Chang and McAfee, 1989
  Reporting: | Physician-reported
  Method: | Excellent, Good, fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 17 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 17 | 15.3 | 12 | 18 | | | 13 | 2 | 2 | 0
  Authors and Year: | Herron and Trippi, 1989
  Reporting: | Physician-reported
  Method: | 3 levels: Good, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 24 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 34 | 18 | 71 | | | 20 | 3 | 1
  Authors and Year: | Hanley, 1986
  Reporting: | Physician-reported
  Method: | 4 Levels: Excellent, Good, Fair, Poor
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 20 | 31.6 | 24 | 46 | | | 13 | 4 | 2 | 1
  Authors and Year: | Kaneda and Kazama, 1986
  Reporting: | Physician-reported
  Method: | 4-level outcome based on a 12-point scale
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 54 54 | 0 30 | 12 | 66 | | | 34 | 12 | 19 6 | 35 2
  Authors and Year: | Dall and Rowe, 1985
  Reporting: | Patient-reported
  Method: | 2 Levels: Better or Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 17 | 20 | 8 | 32
  Authors and Year: | Epstein, Epstein, Carras et al., 1983
  Reporting: | Physician-reported
  Method: | 3 levels. Excellent: full/minimal restrictions, Good: moderate restriction, Poor: no improvement to worsening.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 60 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 60 | 16 | 1 | 90 | | | | 41 | 12 | 7
  Authors and Year: | Richardson and Brown, 1980
  Reporting: | Physician-reported
  Method: | 5 levels. Ex: no pain with full activity, Satisfactory (Gd): minimal pain not incapacitated, Fr: residual pain but improved, Pr: not working, minor improvement, Failure: no improvement or not working.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 21 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 21 | 1 | | | | | 13 | 6 | 0 | 2
  Authors and Year: | Cauchoix, Benoist, and Chassaing, 1976
  Reporting: | Patient-reported
  Method: | 4 Levels: Free from pain (Excellent), Slight and temporary sciatica (Good), Not Improved (Poor), Recurrence of pain after increasing of slipping (Very Poor). Terms in parentheses are by ECRI and did not appear in the published study.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 26 | | | | | | 15 | 7 | | 1 | 3
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Rompe, Eysel, Zollner et al., 1999
  Reporting: | Patient-reported
  Method: | 3 levels. Patients were asked if they were Satisfied, Moderately satisfied, or Unsatisfied.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 25 | 88.8 | | | | | | 8 | 7 | 10
2 | 51 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 26 | 96 | | | | | | 8 | 8 | 10
3 | 27 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 21 | 88.8 | | | | | | 5 | 9 | 7
  Authors and Year: | Katz, Lipson, Lew et al., 1997
  Reporting: | Patient-reported
  Method: | 2 levels. Satisfied of Not Satisfied. Based on questions regarding improvement in pain, relief of sensory dysfunction, ability to do recreational activities, satisfaction with overall results.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 194 | 6 | | | | | | 144 | | 50
| | | | 194 | 24 | | | | | | 140 | | 54
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 37 | 6 | | | | | | 28 | | 9
| | | | 41 | 24 | | | | | | 31 | | 6
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 6 | | | | | | 26 | | 15
| | | | 41 | 24 | | | | | | 28 | | 13
  Authors and Year: | Rompe, Eysel, Hopf et al., 1995
  Reporting: | Patient-reported
  Method: | 3 levels: Good-to-excellent, Fair, Poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 24 | Mixed Stenosis | SWDL with Fusion and Instrumentation | 20 | 21.6 | 12 | 48 | | | | 16 | 5 | 1
2 | 24 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 25.9 | 12 | 50 | | | | 18 | 5 | 1
3 | 12 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion and Instrumentation | 12 | 25.6 | 12 | 50 | | | | 9 | 3 | 0
  Authors and Year: | Postacchini, Cinotti, Perugia et al., 1993
  Reporting: | Patient-reported
  Method: | 4 levels. Ex 81-100, Gd 61-80, Fr41-60, Pr0-40. Score is passed on points for subjective opinion of back and leg pain, physician rating of nerve-root tension, motor deficit, analgesics, ability to work, ADL, and walking ability.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Congenital or Degenerative Stenosis, Combined, or Deg. Spondylolisthesis | Laminotomy | 26 | 44.4 | 26 | 64 | | | 8 | 13 | 3 | 2
2 | 41 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 44.4 | 26 | 64 | | | 15 | 17 | 4 | 5
  Authors and Year: | Sanderson and Wood, 1993
  Reporting: | Patient-reported
  Method: | 3 levels. Ex: no leg pain, Gd: less leg pain and could walk further, Pr: continued leg pain and no improvement in walking.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 19 | Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 19 | 42 | 24 | 84 | | | 13 | 3 | | 3
2 | 12 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 12 | 42 | 24 | 84 | | | 7 | 2 | | 3
  Authors and Year: | Hirabayashi, Kumano, and Kuroki, 1991
  Reporting: | Patient-reported
  Method: | 4 levels but reported as 2. Excellent and Good: no postoperative complaints or improved with some complaints, Fair and Poor: no improvement or worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 32 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 32 | 33 | 15 | 54 | | | | 27 | | 5
2 | 31 | Mixed Stenosis | SWDL with Fusion and Instrumentation | 21 | 33 | 15 | 54 | | | | 14 | | 7
  Authors and Year: | Herkowitz and Garfin, 1989
  Reporting: | Physician-reported
  Method: | 2 levels: Good to excellent or poor.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 58 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 58 | | 25 | 84 | | | | 50 | | 8
2 | 41 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | | 25 | 84 | | | | 32 | | 9
  Study Design: | Prospective Trial
  Authors and Year: | Jonsson, Annertz, Sjoberg et al., 1997a
  Reporting: | Patient-reported
  Method: | 4 levels. Ex: pain-free, Fair (Gd): improved but residual pain, Unchanged (Fr), Worse (Pr)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 86 | 4 | | | | | 54 | 18 | 10 | 4
| | | | 86 | 12 | | | | | 52 | 9 | 23 | 2
| | | | 86 | 24 | | | | | 58 | 10 | 19 | 1
| | | | 86 | 60 | | | | | 45 | 9 | 18 | 13
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Postacchini, Cinotti, Gumina et al., 1993
  Reporting: | Physician-reported
  Method: | 2 levels, Ex & Gd, Fr & Pr. Determined from subjective pain score (0-50) each for back and leg pain, and examiner assessment of range of motion, nerve root tension, muscle strength, medication, work, walking, and ADL.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 64 | Developmental, degenerative, or combined, with or without spondylolisthesis | Mixed Decompression Techniques | 64 | 6 | | | | | | 54 | | 10
| | | | 64 | 96 | 48 | 252 | | | | 43 | | 21
  Study Design: | Case-series
  Authors and Year: | Guigui, Barre, Benoist et al., 1999
  Reporting: | Physician-reported
  Method: | 2 levels, improved v. not improved. Clinical evaluation based on the Beaujon Scoring System using claudication, radiculalgia, low back pain, motor and sensory deficit, medication, and quality of life, was used to determine level of improvement.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 28 | Stenosis and/or Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 23 | 3 | | | | | | 18 | | 5
| | | | 23 | 96 | | | | | | 12 | | 11
Trials Examining Surgical Patients and PatientsReceiving Conservative Treatment
  Patient Condition: | Central lumbar stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Simotas, Dorey, Hansraj, et al., 2000
  Reporting: | Patient-reported
  Method: | Patients were asked how satisfied they were with the overall results of treatment. 4 levels. Ex: very satisfied, Gd: somewhat satisfied, Fr: somewhat dissatisfied, Pr: very dissatisfied.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Central Lumbar Stenosis | Conservative-various treatments | 40 | 33 | 15 | 55 | | | 16 | 16 | 5 | 3
2 | 9 | Central Lumbar Stenosis | Surgery - not described | 9 | 33 | 16 | 55 | | | 3 | 3 | 3 | 0
  Authors and Year: | Mariconda, Zanforlino, Celestino et al., 2000
  Reporting: | Patient-reported
  Method: | 0-20 score from the Beaujon Scoring System. Measures walking, leg pain at rest and exertion, low back pain, neurological deficit, medications required, and quality of life.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 0 | | | 8.1 | 2.7
| | | | 20 | 12 | | | 14.4 | 4.1
| | | | 20 | 24 | | | 13.8 | 4.4
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 0 | | | 11 | 2.4
| | | | 17 | 12 | | | 14.8 | 2.2
| | | | 17 | 24 | | | 14.2 | 3.6
  Authors and Year: | Johnsson, Uden, and Rosen, 1991
  Reporting: | Patient-reported
  Method: | 3 levels determined by a 0-100 visual analog scale. Good (improved) 56-100, Fair (unchanged) 46-55, Poor (worse) 0-45.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | Conservative-not described | 19 | 31 | 7 | 51 | | | | 6 | 11 | 2
2 | 30 | Central Lumbar Stenosis - moderate stenosis | SWDL-Standard Wide Decompressive Laminectomy | 30 | 50 | 5 | 109 | | | | 17 | 7 | 6
3 | 14 | Central Lumbar Stenosis - severe stenosis | SWDL-Standard Wide Decompressive Laminectomy | 14 | 58 | 3 | 120 | | | | 9 | 0 | 5
  Patient Condition: | Mixed lumbar stenosis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Amundsen, Weber, Nordal, et al. 2000
  Reporting: | Physician-reported
  Method: | Excellent: full or almost full resolution of pain and return to normal physical activity; Fair: partial resolution, with lesser problems clear improvement; Unchanged (Poor): no change in the clinical condition; Worse (V Poor): worsening clinical condition
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 19 | 6 | | | | | 7 | | 8 | 2 | 2
| | | | 19 | 12 | | | | | 9 | | 8 | 2 | 0
| | | | 19 | 48 | | | | | 11 | | 5 | 2 | 1
| | | | 17 | 120 | | | | | 7 | | 5 | 4 | 1
2 | 50 | Mixed Stenosis | Conservative-various | 50 | 6 | | | | | 18 | | 17 | 5 | 10
| | | | 50 | 12 | | | | | 18 | | 14 | 6 | 12
| | | | 50 | 48 | | | | | 17 | | 11 | 8 | 14
| | | | 41 | 120 | | | | | 15 | | 8 | 6 | 12
3 | 13 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 13 | 6 | | | | | 4 | | 8 | 1 | 0
| | | | 13 | 12 | | | | | 5 | | 4 | 1 | 3
| | | | 13 | 48 | | | | | 8 | | 3 | 1 | 1
| | | | 11 | 120 | | | | | 5 | | 5 | 0 | 1
4 | 18 | Mixed Stenosis | Conservative-various | 18 | 6 | | | | | 3 | 4 | 1 | 10
| | | | 18 | 12 | | | | | 3 | | 3 | 2 | 10
| | | | 17 | 120 | | | | | 3 | | 5 | 0 | 9
  Study Design: | Controlled Trial
  Authors and Year: | Hurri, Slatis, Soini et al., 1998
  Reporting: | Patient-reported
  Method: | 3 levels. Patients were asked if condition were much better and improved (Good), unchanged (Fair), worse (Poor)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 57 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 57 | 144 | | | | | | 36 | 11 | 10
2 | 18 | Mixed Stenosis | Conservative-not described | 18 | 144 | | | | | | 8 | 8 | 2
  Authors and Year: | Atlas, Deyo, Keller et al., 1996
  Reporting: | Patient-reported
  Method: | 2 levels. Gd: Satisfied, Pr: Unsatisfied
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 12 | | | | | | 50 | | 22
2 | 67 | Mixed Stenosis | Conservative-many | 58 | 12 | | | | | | 21 | | 37
  Authors and Year: | Atlas, Keller, Robson, et al. 2000
  Reporting: | Patient-reported
  Method: | See Atlas, Deyo, Keller, et al. 1996
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 67 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 67 | 48 | | | | | | 42 | | 25
2 | | Mixed Stenosis | Conservative-not described | 52 | 48 | | | | | | 22 | | 30
  Authors and Year: | Swezey, 1996
  Reporting: | Patient-reported
  Method: | 3 levels. Improved, Unchanged, Worsened since initial diagnoses.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 12 | Mixed Stenosis | Exercise/stretching and flexibility | 12 | 60 | 60 | 60 | | | | 7 | 5 | 0
2 | 11 | Mixed Stenosis | Physical Therapy/massage, ultrasound, heat, ice, traction | 11 | 60 | 60 | 60 | | | | 7 | 2 | 2
3 | 13 | Mixed Stenosis | Epidural Steroid Injections | 13 | 60 | 60 | 60 | | | | 6 | 7
4 | 11 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 11 | 60 | 60 | 60 | | | | 11 | 0 | 0
  Authors and Year: | Nagler and Bodack, 1993
  Reporting: | Patient-reported
  Method: | 5 levels. Based on the ratio of original symptoms and symptoms at one year. Ex: 76-100%, Gd: 51-75%, Fr: 26-50%, Slight: 1-25%, Same or worse: 0%. Symptoms were pain, functioning, medication, and bladder problems.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 41 | Mixed Stenosis | Conservative-various | 41 | 12 | | | | | 12 | 10 | 7 | 5 | 7
2 | 39 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 39 | 12 | | | | | 10 | 12 | 5 | 4 | 8
  Patient Condition: | Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Fitzgerald and Newman, 1976
  Reporting: | Physician-reported
  Method: | 2 levels. Patients were asked if they were better, unchanged, or worse as a result of treatment and classified as satisfactory or unsatisfactory.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 29 | Degenerative Spondylolisthesis | Rigid Brace | 29 | 70 | 6 | 216 | | | | 27 | | 2
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 14 | 70 | 6 | 216 | | | | 10 | | 4
  Authors and Year: | Rosenberg, 1976
  Reporting: | Patient-reported
  Method: | 2 levels. Patient reported satisfactory or unsatisfactory relief of pain and symptoms after therapy.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 11 | Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 11 | | 1 | 12 | | | | 6 | | 5
2 | 15 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 15 11 | | 1 24 | 12 120 | | | | 11 11 | | 4 0
3 | 170 | Degenerative Spondylolisthesis | Conservative-not described | 170 | | 0 | 312 | | | | 153 | | 17

Evidence Table 17. Leg Pain Outcomes Related to Treatment of Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Hanakita, Suwa, and MIzuno, 1999
  Reporting: | Patient-reported
  Method: | 3 levels. Gd: Improved, Fr: Unchanged, Pr: Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 59 | Central Lumbar Stenosis - younger than 64 years | SWDL-Standard Wide Decompressive Laminectomy | 40 | | 12 | 96 | | | | 26 | 11 | 3
2 | 61 | Central Lumbar Stenosis - older than 64 years | SWDL-Standard Wide Decompressive Laminectomy | 37 | | 12 | 96 | | | | 22 | 12 | 3
3 | 16 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 11 | | 12 | 96 | | | | 7 | 4 | 0
4 | 20 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 14 | | 12 | 96 | | | | 12 | 1 | 1
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Vitaz, Raque, Shields et al., 1999
  Reporting: | Patient-reported
  Method: | 3 levels. No change, Improved, and Resolved
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 65 | Central Lumbar Stenosis | Mixed Decompression Techniques | 59 | 19.6 | 1 | 63 | | | | 38 | 10 | 6
  Authors and Year: | Jonsson and Stromqvist, 1994
  Reporting: | Patient-reported
  Method: | 4 levels. Ex: pain-free, Gd: improved but residual pain, Unchanged (Fr), Worse (Pr).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 43 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 40 | 24 | | | | | 24 | 8 | | 8
  Study Design: | Case-series
  Authors and Year: | Johnsson, Willner, and Pettersson, 1981
  Reporting: | Patient-reported
  Method: | Number of patients with back and leg pain
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 27 | 22 | 3 | 79 | | | | 13 | | 14
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982
  Reporting: | Patient-reported
  Method: | 4 levels. None, Mild, Moderate, Severe
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Lateral Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 36 | | 120 | | | | 7 | 6 | 2
2 | 32 | Lateral Lumbar Stenosis with disk herniation | Partial laminectomy or hemilaminectomy | 26 | 36 | | 120 | | | | 4 | 13 | 9
3 | 21 | Lateral and Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 18 | 36 | | 120 | | | | 4 | 7 | 5 | 2
4 | 21 | Lateral and Central Lumbar Stenosis with disk herniation | Partial laminectomy or hemilaminectomy | 18 | 36 | | 120 | | | | 3 | 10 | 3 | 2
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Sanderson and Getty, 1996
  Reporting: | Patient-reported
  Method: | 3 levels. Good: No analgesia, Fair: Occasional analgesia, Poor: Continual analgesia
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 0 | 0 | 0 | | | | | 5 | 52
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 12 | 12 | 12 | | | | 45 | 7 | 5
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 101 | 60 | 132 | | | | 41 | 9 | 7
  Study Design: | Case-series
  Authors and Year: | Choudhury and Taylor, 1977
  Reporting: | Patient-reported
  Method: | 3 Levels: Absent, Mild (Occasional), Recurring
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 28 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 28 | | 2 | 24
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type of stenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Yone and Sakou, 1999
  Reporting: | Physician-reported
  Method: | JOA score
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 0 | | | 1
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 37 | 24 | 52 | 1.5
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 0 | | | 1
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 43 | 24 | 60 | 1.9
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 0 | | | 1.1
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 33 | 24 | 54 | 2.3
  Authors and Year: | Javid and Hadar, 1998
  Reporting: | Patient-reported
  Method: | 5 levels. Ex: None, Gd: Rarely, Fr: Sometimes, Pr: most times, VPr: constant
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 57.2 | 12 | 132 | | | 13 | 11 | 25 | 15 | 8
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy | 52 | 56.6 | 12 | 132 | | | 18 | 4 | 16 | 10 | 4
3 | 23 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 22 | 86.6 | 12 | 132 | | | 5 | 7 | 2 | 4 | 4
  Study Design: | Case-series
  Authors and Year: | Mackay and Wheelwright, 1998
  Reporting: | Patient-reported
  Method: | Yes or no, pre and post
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | 50 | 0 | | | | | | 14 | | 36
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | 50 | 32 | 12 | 49 | | | | 40 | | 10
  Authors and Year: | Tsai, Yang, and Bray, 1998
  Reporting: | Patient-reported
  Method: | Analog scale 0-20
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 62 | Mixed Stenosis | Laminotomy | 62 | 27 | 15 | 48 | 15.2 | 5.7
1 | 62 | Mixed Stenosis | Laminotomy | 62 | 27 | 15 | 48 | 5.8 | 7.1
  Authors and Year: | Katz, Lipson, Chang et al., 1996
  Reporting: | Patient-reported
  Method: | 3 Levels: Severe or very severe, Moderate or mild, Very Mild or none.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 55 | | 84 | 120 | | | 11 | 16 | 28
  Authors and Year: | Simmons and Simmons, 1992
  Reporting: | Patient-reported
  Method: | 4 levels. None, Mild (minimal disruption of lifestyle), Moderate (significant disruption of lifestyle, Severe (constant pain and problems with all activities).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Mixed Stenosis | SWDL with Fusion and Instrumentation | 40 | 44 | 24 | 61 | | | | 38 | | 2
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Fischgrund, Mackay, Herkowitz et al., 1997
  Reporting: | Patient-reported
  Method: | Visual analog scale from 0 (no pain) to 5 (severe pain).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 35 | 0 | 0 | 0 | 4
1 | 40 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 35 | 28 | 24 | 36 | 1
2 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 33 | 0 | 0 | 0 | 4
2 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 33 | 28 | 24 | 36 | 1
  Authors and Year: | Herkowitz and Kurz, 1991
  Reporting: | Patient-reported
  Method: | Scale of no pain (0) to severe pain (5).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 25 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 25 | 0 | 0 | 0 | 4
1 | 25 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 25 | 36 | 29 | 48 | 1.7
2 | 25 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 25 | 0 | 0 | 0 | 4.3
2 | 25 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 25 | 36 | 29 | 48 | 1
  Study Design: | Controlled Trial
  Authors and Year: | Satomi, Hirabayashi, Toyama et al., 1992
  Reporting: | Patient-reported
  Method: | JOA score 0 (severe pain)-3 (no pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Degenerative Spondylolisthesis | Fusion and instrumentation | 27 | 0 | 0 | 0 | 1.3 | | 3 | 2 | 21 | 1
1 | 27 | Degenerative Spondylolisthesis | Fusion and instrumentation | 27 | 36 | | | 2.2 | | 14 | 9 | 4
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 14 | 0 | 0 | 0 | 1 | | | 1 | 11 | 2
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 14 | 36 | | | | | 4 | 8 | 2
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Stambough, 1999
  Reporting: | Patient-reported
  Method: | Visual analog scale of 0 (no pain) to 10 (severe pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 35 | 0 | 0 | 0 | 8.5
1 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 35 | 45.2 | 24 | 105 | 0.5
  Authors and Year: | Nishizawa and Fujimura, 1997
  Reporting: | Patient-reported
  Method: | JOA score: 0 (severe pain) to 3 (no pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 58 | Degenerative Spondylolisthesis | Fusion and instrumentation | 58 | 0 | 0 | 0 | 1.3
1 | 58 | Degenerative Spondylolisthesis | Fusion and instrumentation | 58 | 63 | 28 | 128 | 2.8
  Authors and Year: | Knox, Harvell, Nelson et al., 1989
  Reporting: | Patient-reported
  Method: | Scale of 0 (none) to 10 (severe)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 24 | 0 | 0 | 0 | 6.4
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 24 | 21.3 | 4 | 55 | 3.4 | | | 20 | | 2
  Study Design: | Case-series
  Authors and Year: | Inoue, Watanabe, Goto et al., 1988
  Reporting:
  Method: | 4-Level score on JOA scale
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Degenerative Spondylolisthesis | Fusion | 36 | 0 | 0 | 0 | 1.1
1 | 36 | Degenerative Spondylolisthesis | Fusion | 36 | 127 | 12 | 324 | 2.7
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Katz, Lipson, Lew et al., 1997
  Reporting: | Patient-reported
  Method: | Scale of 1 to 5 with 1 being no pain and 5 being very severe pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 194 | 0 | | | 3.4 | 1
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 194 | 6 | | | 2.3
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 194 | 24 | | | 2.4
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 37 | 0 | | | 3.4 | 1.1
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 37 | 6 | | | 2.1
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 37 | 24 | | | 2.1
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 0 | | | 3.6 | 1
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 6 | | | 2.1
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 24 | | | 2
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Study Design: | Controlled Trial
  Authors and Year: | Simotas, Dorey, Hansraj, et al., 2000
  Reporting: | Patient-reported
  Method: | 3 levels. Good: None or mild pain, Fair: Moderate pain, Poor: Very severe or severe pain
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Central Lumbar Stenosis | Conservative-various treatments | 40 | 33 | 16 | 55 | | | | 19 | 13 | 8
2 | 9 | Central Lumbar Stenosis | Surgery - not described | 9 | 33 | 16 | 55 | | | | 6 | 2 | 1
  Authors and Year: | Mariconda, Zanforlino, Celestino et al., 2000
  Reporting: | Patient-reported
  Method: | 0, 1, 2, 3 scale: 0- continuous severe pain, 1- occasional severe pain, 2- occasional mild pain, 3- none
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 0 | | | 1.4 | 1.1
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 12 | | | 1.9 | 1.2
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 24 | | | 2 | 1
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 0 | | | 1.7 | 0.9
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 12 | | | 2.2 | 1
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 24 | | | 2.1 | 0.9

Evidence Table 18. Leg Pain Relief Outcomes Related to Treatment of Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Ishac, Alhayek, Fournier et al., 1996
  Reporting: | Physician-reported
  Method: | Reported relief of symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 34 | 0.2 | | | | | | 31 | | 3
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 34 | 12 | | | | | | 30 | | 4

  Study Design: | Prospective Trial
  Authors and Year: | Kleeman, Hiscoe, and Berg, 2000
  Reporting: | Patient-reported
  Method: | 4 levels: Resolved, Better, Same, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 51 | 30 | 13 | 51 | | | 33 | 17 | 1 | 0
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 48 | 48 | 31 | 69 | | | 34 | 12 | 1 | 1

  Study Design: | Case-series
  Authors and Year: | Young, Veerapen, and O'Laoire, 1988
  Reporting:
  Method: | 2 levels- Relieved or not. Also 3 levels- relieved of claudication, significantly improved, not improved.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 32 | Central Lumbar Stenosis | Decompressive Surgery | 32 | 39.8 | 17 | 58

  Authors and Year: | Verbiest, 1979
  Reporting: | Patient-reported
  Method: | 2 Levels: Cured or Residual Symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 11 | Congenital Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 11 | 123 | 36 | 204 | | | 6 | | 1

Trials Examining Surgical Patients with Lateral Lumbar Stenosis
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Baba, Uchida, Maezawa et al., 1996
  Reporting: | Physician-reported
  Method: | Reported number of patients with leg pain before and after surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 31 | Lateral Lumbar Stenosis | Laminotomy | 20 | 38 | 12 | 88 | | | | 17 | | 3

Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type ofstenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Yone and Sakou, 1999
  Reporting: | Physician-reported
  Method: | Percent change in JOA score
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 37 | 24 | 52 | 25
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 43 | 24 | 60 | 45
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 33 | 24 | 54 | 63

  Authors and Year: | Jonsson and Stromqvist, 1993a
  Reporting: | Physician-reported
  Method: | 4 levels. Excellent: pain-free, Fair: improved but with residual pain, Unchanged, Poor: deteriorated.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 19 | 24 | 24 | 24 | | | 7 | 7 | 4 | 1
2 | 19 | Lateral Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 18 | 24 | 24 | 24 | | | 12 | 4 | 2 | 0

  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Ganz, 1990
  Reporting: | Physician-reported
  Method: | 4 levels. 0- No improvement, 1-Some improvement, 2-Almost normal, 3-No symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 33 | 36 | 12 | 72 | 2.45 | 1

Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Plotz and Benini, 1998
  Reporting: | Patient-reported
  Method: | 3 Levels: Improved, Unchanged, Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 17 | Degenerative Spondylolisthesis | Decompressive Surgery without fusion | 6 | 45 | 9 | 120 | | | | | | 1
2 | 18 | Degenerative Spondylolisthesis | Decompressive Surgery with fusion and Translaminar Screw Fixation | 14 | 54 | 12 | 100 | | | 2 | | | 1 | 1
3 | 71 | Degenerative Spondylolisthesis | Decompressive Surgery with fusion and AO Internal Fixator | 64 | 28 | 9 | 100 | | | 32 | | | 2 | 5

  Authors and Year: | Yuan, Garfin, Dickman et al., 1994
  Reporting: | Physician-reported
  Method: | 3 levels. Improved, No change, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 2177 | Degenerative Spondylolisthesis | Fusion and Pedical Screw Fixation | 2125 | 12 | 1 | 51 | | | | 1945 | 176 | 4
2 | 456 | Degenerative Spondylolisthesis | Fusion | 451 | 12 | 1 | 51 | | | | 398 | 51 | 2

  Study Design: | Case-series
  Authors and Year: | Herron and Trippi, 1989
  Reporting: | Patient-reported
  Method: | Average % relief, number of patients with complete relief.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 24 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 34 | 18 | 71 | 92

Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Postacchini, Cinotti, Perugia et al., 1993
  Reporting: | Patient-reported
  Method: | Improvement based on a 0-100 scale with 0 meaning greatest disability.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 26 | Congenital or Degenerative Stenosis, Combined, or Deg. Spondylolisthesis | Laminotomy | 26 | 44.4 | 26 | 64 | 71
2 | 41 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 44.4 | 26 | 64 | 84

Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Amundsen, Weber, Nordal, et al. 2000
  Reporting: | Patient-reported
  Method: | 3 levels of pain were recorded: Good: No or Light pain, Fair: Moderate pain, and Poor: Severe pain
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 19 | 0 | | | | | | 0 | 5 | 14
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 19 | 3 | | | | | | 8 | 8 | 3
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 18 | 48 | | | | | | 6 | 9 | 3
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 16 | 120 | | | | | | 8 | 3 | 5
2 | 50 | Mixed Stenosis | Conservative-various | 50 | 0 | | | | | | 2 | 24 | 24
2 | 50 | Mixed Stenosis | Conservative-various | 50 | 3 | | | | | | 13 | 33 | 4
2 | 50 | Mixed Stenosis | Conservative-various | 48 | 48 | | | | | | 16 | 27 | 5
2 | 50 | Mixed Stenosis | Conservative-various | 27 | 120 | | | | | | 12 | 14 | 1
3 | 13 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 13 | 0 | | | | | | 0 | 6 | 7
3 | 13 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 13 | 3 | | | | | | 2 | 11 | 0
3 | 13 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 12 | 48 | | | | | | 5 | 7 | 0
3 | 13 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 11 | 120 | | | | | | 5 | 6 | 0
4 | 18 | Mixed Stenosis | Conservative-various | 18 | 0 | | | | | | 0 | 5 | 13
4 | 18 | Mixed Stenosis | Conservative-various | 18 | 3 | | | | | | 7 | 9 | 2
4 | 18 | Mixed Stenosis | Conservative-various | 16 | 48 | | | | | | 2 | 10 | 4
4 | 18 | Mixed Stenosis | Conservative-various | 8 | 120 | | | | | | 2 | 6 | 0

  Study Design: | Controlled Trial
  Authors and Year: | Atlas, Deyo, Keller et al., 1996
  Reporting: | Patient-reported
  Method: | 3 levels. Gd: Better, Fr: Same, Pr: Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 12 | | | | | | 57 | 11 | 4
2 | 67 | Mixed Stenosis | Conservative-many | 58 | 12 | | | | | | 26 | 25 | 7

  Authors and Year: | Atlas, Keller, Robson, et al. 2000
  Reporting:
  Method: | See Atlas, Deyo, Keller, et al. 1996
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 67 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 67 | 48 | | | | | | 51 | 14 | 2
2 | | Mixed Stenosis | Conservative-not described | 52 | 48 | | | | | | 25 | 18 | 9

Evidence Table 19. Mental Status Outcomes from Clinical Trials of Patients with Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Thomsen, Christensen, Eiskjaer et al., 1997
  Reporting: | Patient-reported
  Method: | Dallas Pain Questionnaire. 3 questions measure anxiety-depression.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation
| | | | 20 | 24 | | | 12
2 | 21 | Degenerative Spondylolisthesis | Partial laminectomy and fusion
| | | | 21 | 24 | | | 7
  Study Design: | Case-series
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
  Reporting: | Patient-reported
  Method: | 5 levels: Much Better, Better, Same, Worse, Much Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | Time in Months | | | | | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation
| | | | 36 | 78 | 60 | 129 | | | 15 | 16 | 2 | 2 | 1

Evidence Table 20. Physical Function and Activities of Daily Living Outcomes Related to Treatment of Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Centralor Lateral Lumbar Stenosis (type of stenosis unspecified or includes bothtypes of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Simpson, Silveri, Balderston et al., 1993
  Reporting: | Patient-reported
  Method: | Patient reported motor weakness as absent or present at long term followup.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 33 | Mixed Stenosis - diabetes | SWDL-Standard Wide Decompressive Laminectomy | 24 | 60 | 24 | 81
2 | 24 | Mixed Stenosis - no diabetes | SWDL-Standard Wide Decompressive Laminectomy | 22 | 84 | 66 | 120

  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Silvers, Lewis, and Asch, 1993
  Reporting: | Patient-reported
  Method: | 4 levels: Excellent, Good, Fair, Poor. Excellent and Good were combined as a successful outcome.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 248 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 128 | 56.4 | 4 | 174 | | | | 72 | | 56

  Study Design: | Case-series
  Authors and Year: | McCullen, Bernini, Bernstein et al., 1994
  Reporting: | Patient-reported
  Method: | 5 Levels: Does activity have No limits, Few Limits, Some Limits, Many Limits, Disabling.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 193 | Mixed Stenosis | Decompressive Surgery | 118 | 55 | 24 | 142 | | | 39 | 22 | 21 | 30 | 6

Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Thomsen, Christensen, Eiskjaer et al., 1997
  Reporting: | Patient-reported
  Method: | Dallas Pain Questionnaire. 10 questions measure daily activities and work-leisure activities.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 20 | 24 | | | 48
2 | 21 | Degenerative Spondylolisthesis | Partial laminectomy and fusion | 21 | 24 | | | 22

  Study Design: | Controlled Trial
  Authors and Year: | Yuan, Garfin, Dickman et al., 1994
  Reporting: | Physician-reported
  Method: | 3 levels. Improved, No change, Worse
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 2177 | Degenerative Spondylolisthesis | Fusion and Pedical Screw Fixation | 2132 | 12 | 1 | 51 | | | | 1927 | 192 | 13
2 | 456 | Degenerative Spondylolisthesis | Fusion | 451 | 12 | 1 | 51 | | | | 391 | 58 | 2

  Study Design: | Prospective Trial
  Authors and Year: | Rechtine, Sutterlin, Wood et al., 1996
  Reporting: | Patient-reported
  Method: | 5-point scale used to determine improvement. Bedridden, Rare activity, Limited activity, Moderate daily activity, Normal daily activity.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 18 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 18 | 24 | 24 | 24 | | | | 12 | 4 | 2

  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Takahashi, Kitahara, Yamagata et al., 1990
  Reporting: | Patient-reported
  Method: | 7 activities of daily living with a maximum of 14 points.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | Fusion | 19 | 0 | 0 | 0 | 6.2
1 | 39 | Degenerative Spondylolisthesis | Fusion | 19 | 151 | 6 | 360 | 11.7

  Study Design: | Case-series
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
  Reporting: | Patient-reported
  Method: | 5 Levels of activity: Bedridden, Primarily no activity, Light labor, Moderate labor, No restrictions.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 34 | 0 | | | | | 6 | 13 | 11 | 5 | 1
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 35 | 24 | | | | | 11 | 12 | 10 | 2 | 0
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 36 | 78 | 60 | 129 | | | 9 | 8 | 15 | 4 | 0

  Authors and Year: | Inoue, Watanabe, Goto et al., 1988
  Reporting: | Physician-reported
  Method: | 14 point JOA scale
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 36 | Degenerative Spondylolisthesis | Fusion | 36 | 0 | 0 | 0 | 4.9
1 | 36 | Degenerative Spondylolisthesis | Fusion | 36 | 127 | 12 | 324 | 11.7

Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Rompe, Eysel, Zollner et al., 1999
  Reporting: | Patient-reported
  Method: | 4 levels. Low Back Outcome Scale. Ex (65-75), Gd (50-64), F (30-49), P (0-29) Score based on physical activities and activities of daily living.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 25 | 88.8 | | | | | 3 | 7 | 7 | 8
2 | 51 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 26 | 96 | | | | | 3 | 5 | 8 | 10
3 | 27 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 21 | 88.8 | | | | | 3 | 2 | 9 | 7

  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Chen, Baba, Kamitani et al., 1994
  Reporting: | Physician-reported
  Method: | 4 levels, Japanese Orthopaedic Association Assessment Scoring System. Based on back pain, leg pain, walking, sensory disturbance, motor disturbance, ADL (48% of score) urinary function. Ex: improvement >80%, Gd: 65-80%, Fr: 50-65%, Pr:<50%.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 80 | Developmental, degenerative, or combined stenosis, or degenerative or isthmic spondylolisthesis | Mixed Decompression Techniques | 48 | 54 | 24 | 84 | | | 11 | 8 | 9 | 20

Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Study Design: | Controlled Trial
  Authors and Year: | Atlas, Deyo, Keller et al., 1996
  Reporting: | Patient-reported
  Method: | Score based on Short Form 36 score. The higher the score the better the physical function.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 81 | 0 | | | 27.6
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 12 | | | 54.1
2 | 67 | Mixed Stenosis | Conservative-many | 67 | 0 | | | 44.7
2 | 67 | Mixed Stenosis | Conservative-many | 58 | 12 | | | 45.7

  Authors and Year: | Herno, Airaksinen, Saari et al., 1996
  Reporting: | Physician-reported
  Method: | Patient's functional status was evaluated during the clinical examination. Good: normal or near normal activities such as walking, dressing, turning around; Poor: difficulty performing activities
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Mixed Stenosis | Conservative-not described | 54 | | | | | | | 51 | | 3

Evidence Table 21. Quality of Life Outcomes Related to Treatment of Lumbar Spinal Stenosis

Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Thomsen, Christensen, Eiskjaer et al., 1997
  Reporting: | Patient-reported
  Method: | Dallas Pain Questionnaire. 3 questions measure social concerns.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 20 | 24 | | | 13
2 | 21 | Degenerative Spondylolisthesis | Partial laminectomy and fusion | 21 | 24 | | | 8

Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Patient Condition: | Central lumbar stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Mariconda, Zanforlino, Celestino et al., 2000
  Reporting: | Patient-reported
  Method: | 0, 1, 2, 3 scale: 0- completely incapacitated, 1- very limited, 2- slightly limited, 3- normal
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 0 | | | 1.3 | 0.7
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 12 | | | 2.3 | 0.6
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 24 | | | 2.2 | 0.7
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 0 | | | 1.8 | 0.8
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 12 | | | 2.4 | 0.5
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 24 | | | 2.5 | 0.5

  Patient Condition: | Mixed lumbar stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Atlas, Deyo, Keller et al., 1996
  Reporting: | Patient-reported
  Method: | 2 levels. Number of patients reporting moderate or better improvement in quality of life
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 12 | | | | | | 58 | | 14
2 | 67 | Mixed Stenosis | Conservative-many | 58 | 12 | | | | | | 28 | | 30

  Authors and Year: | Atlas, Keller, Robson, et al. 2000
  Reporting:
  Method: | See Atlas, Deyo, Keller, et al. 1996
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Mean | SD | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 67 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 67 | 48 | | | | | | 43 | | 24
2 | 52 | Mixed Stenosis | Conservative-not described | 52 | 48 | | | | | | 25 | | 27

Evidence Table 22. Walking Capacity Outcomes Related to Treatment of Lumbar Spinal Stenosis

Randomized Controlled Trials of Patients Receiving Conservative Treatments
  Patient Condition: | Mixed lumbar stenosis
  Study Design: | Randomized Control Trial
  Authors and Year: | Fukusaki, Kobayashi, Hara et al., 1998
  Reporting: | Physician-reported
  Method: | Observation by blinded physical therapist of walking distance provoking intolerable pain. Mean and SD of distance walked and a 3-level success rating were reported. Excellent =>100M, Good=20-100M, Poor =<20M.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 16 | Mixed Stenosis | Epidural Saline | 16 | 0 | | | 10 | 8
1 | 16 | Mixed Stenosis | Epidural Saline | 16 | 0.25 | | | 23 | 19 | | | 2 | 14
1 | 16 | Mixed Stenosis | Epidural Saline | 16 | 1 | | | 18 | 13 | | 1 | | 15
1 | 16 | Mixed Stenosis | Epidural Saline | 16 | 3 | | | 11 | 8 | | 1 | | 15
2 | 18 | Mixed Stenosis | Epidural Anesthetics | 18 | 0 | | | 11 | 9
2 | 18 | Mixed Stenosis | Epidural Anesthetics | 18 | 0.25 | | | 92 | 66 | 2 | 8 | | 8
2 | 18 | Mixed Stenosis | Epidural Anesthetics | 18 | 1 | | | 28 | 24 | | 3 | | 15
2 | 18 | Mixed Stenosis | Epidural Anesthetics | 18 | 3 | | | 13 | 7 | | 1 | | 17
3 | 19 | Mixed Stenosis | Epidural Anesthetics and Steroids | 19 | 0 | | | 9 | 7
3 | 19 | Mixed Stenosis | Epidural Anesthetics and Steroids | 19 | 0.25 | | | 87 | 58 | 2 | 10 | | 7
3 | 19 | Mixed Stenosis | Epidural Anesthetics and Steroids | 19 | 1 | | | 26 | 23 | 0 | 3 | | 16
3 | 19 | Mixed Stenosis | Epidural Anesthetics and Steroids | 19 | 3 | | | 10 | 8 | 0 | 1 | | 18
Trials Examining Surgical Patients with Central Lumbar Stenosis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Grob, Humke, and Dvorak, 1995
  Reporting: | Patient-reported
  Method: | Average distance in meters that the patient could walk without pain.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 0 | 0 | 0 | 1400
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 15 | 28 | 24 | 32 | 6600
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation | 15 | 0 | 0 | 0 | 400
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation | 15 | 28 | 24 | 36 | 4600
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation | 15 | 0 | 0 | 0 | 200
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation | 15 | 28 | 24 | 32 | 3800
  Study Design: | Controlled Trial
  Authors and Year: | Hanakita, Suwa, and MIzuno, 1999
  Reporting: | Patient-reported
  Method: | 3 levels. Gd: Improved, Fr: Unchanged, Pr: Worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 59 | Central Lumbar Stenosis - younger than 64 years | SWDL-Standard Wide Decompressive Laminectomy | 24 | | 12 | 96 | | | | 20 | 4 | 0
2 | 61 | Central Lumbar Stenosis - older than 64 years | SWDL-Standard Wide Decompressive Laminectomy | 33 | | 12 | 96 | | | | 23 | 9 | 1
3 | 16 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 5 | | 12 | 96 | | | | 5 | 0 | 0
4 | 20 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 6 | | 12 | 96 | | | | 6 | 0 | 0
  Authors and Year: | Herno, Partanen, Talaslahti et al., 1999
  Reporting: | Physician-reported
  Method: | The walking capacity was evaluated on a treadmill with a speed of 3600 m/h and a maximum time of 15 minutes (900m).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 41 | Central Lumbar Stenosis - post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 133 | 113 | 157 | 470
2 | 15 | Central Lumbar Stenosis - no post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | 15 | 122 | 113 | 157 | 515
  Authors and Year: | Herno, Saari, Suomalainen et al., 1999
  Reporting: | Physician-reported
  Method: | The walking capacity was evaluated on a treadmill with a speed of 3600 m/h and a maximum time of 15 minutes (900m).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 35 | Central Lumbar Stenosis - no postsurgery stenosis | Mixed Decompression Techniques | 35 | 47 | | | 706
2 | 57 | Central Lumbar Stenosis - post surgery stenosis | Mixed Decompression Techniques | 57 | 47 | | | 602
  Authors and Year: | Thomas, Rea, Pikul et al., 1997
  Reporting: | Patient-reported
  Method: | Visual analog scale of 0 (mild) -10 (severe) pain. Also graded for number of city blocks walked without pain Ex: >3, Gd: 1-3, Fr: 1/2-1, Pr: 1/4-1/2, VPr: <1/4.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 12 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 12 | 0 | 0 | 0 | 6.8 | 2.7 | 2 | 2 | 3 | | 5
1 | 12 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 12 | 37.6 | 24 | 62 | 4.2 | 2.8 | 5 | 2 | 1 | 3 | 1
2 | 14 | Central Lumbar Stenosis | Laminotomy | 14 | 0 | 0 | 0 | | | 1 | 6 | 1 | 2 | 4
2 | 14 | Central Lumbar Stenosis | Laminotomy | 14 | 37.6 | 24 | 62 | | | 4 | 7 | | | 3
  Authors and Year: | Yone, Sakou, Kawauchi et al., 1996
  Reporting: | Patient-reported
  Method: | JOA scale of 0 (< 100 m then pain) to 3 (normal walking).
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 10 | Central Lumbar Stenosis | SWDL with Fusion and Instrumentation | 10 | 0 | | | 0.3
1 | 10 | Central Lumbar Stenosis | SWDL with Fusion and Instrumentation | 10 | 36 | 24 | 60 | 2.1
2 | 17 | Central Lumbar Stenosis | Laminotomy | 17 | 0 | | | 0.4
2 | 17 | Central Lumbar Stenosis | Laminotomy | 17 | 37 | 26 | 68 | 1.7
  Study Design: | Prospective Trial
  Authors and Year: | Kleeman, Hiscoe, and Berg, 2000
  Reporting: | Patient-reported
  Method: | Endurance in minutes up to unlimited
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 51 | 0 | | | 7.4 | | 0 | 0 | 0 | 1 | 50
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 51 | 30 | 13 | 51 | | | 16 | 8 | 13 | 11 | 3
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 48 | 48 | 31 | 69 | | | 19 | 6 | 14 | 8 | 1
  Authors and Year: | Weiner, Walker, Brower et al., 1999
  Reporting: | Patient-reported
  Method: | Meter walked
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 30 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 30 | 0 | | | 109
1 | 30 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 30 | 9 | | | 467
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Vitaz, Raque, Shields et al., 1999
  Reporting: | Patient-reported
  Method: | 4 levels. Stage 1: minimal or no limitation, 2: mild-to moderate limitation, 3: severe limitation, 4: bedridden or wheelchair bound.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 65 | Central Lumbar Stenosis | Mixed Decompression Techniques | 65 | 0 | 0 | 0 | | | 11 | 25 | 22 | 7
1 | 65 | Central Lumbar Stenosis | Mixed Decompression Techniques | 61 | 19.6 | 1 | 63 | | | 42 | 19 | 0 | 0
  Authors and Year: | Airaksinen, Herno, Turunen et al., 1997
  Reporting: | Patient-reported
  Method: | 4 levels. Excellent = could walk a mile; Good = could walk without assistance; Poor = could walk with crutch; Very Poor = could only crawl.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 497 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 438 | 52 | | | | | 171 | 241 | | 22 | 4
  Authors and Year: | Ishac, Alhayek, Fournier et al., 1996
  Reporting: | Physician-reported
  Method: | 4 levels. Resolved, Improved, Unchanged, Worsened
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 29 | 0.2 | | | | | | 21 | 6 | 2
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 29 | 12 | | | | | 8 | 14 | 5 | 2
  Authors and Year: | Mullin, Rea, Irsik et al., 1996
  Reporting: | Patient-reported
  Method: | 5 level rating scale. Ex: walks normally, Gd: walks unaided but with difficulty, Fr: needs aid to climb stairs, Pr: needs aid to walk on flat surface, V Pr: unable to walk.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 72 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 0 | 0 | 0 | | | 1 | 15 | 1 | 3 | 4
1 | 72 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 24 | 31 | 14 | 63 | | | 11 | 5 | 1 | 7 | 0
  Authors and Year: | Jonsson and Stromqvist, 1994
  Reporting: | Patient-reported
  Method: | 4 levels. Ex: more than 5 km, Gd: 1-5 km, Fr: 0.5-1 km, Pr: less than .5 km.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 43 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 40 | 0 | | | | | 0 | 4 | 7 | 29
1 | 43 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 40 | 24 | | | | | 6 | 9 | 13 | 12
  Study Design: | Case-series
  Authors and Year: | Hall, Bartleson, Onofrio et al., 1985
  Reporting: | Patient-reported
  Method: | Distance walked
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 68 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 68 | 0 | 0 | 0 | 180
1 | 68 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 62 | 48 | 35 | 65 | 2400
  Authors and Year: | Johnsson, Willner, and Pettersson, 1981
  Reporting: | Patient-reported
  Method: | Distance in meters until pain starts.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 27 | 0 | 0 | 0 | 262 | 579
1 | 27 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 27 | 22 | 3 | 79 | 1819 | 2031 | | 23 | | 4
  Authors and Year: | Verbiest, 1979
  Reporting: | Patient-reported
  Method: | 2 Levels: Claudication Cured or Residual Symptoms
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 11 | Congenital Lumbar Stenosis | SWDL with Fusion (Arthrodesis) | 11 | 123 | 36 | 204 | | | 8
Trials Examining Surgical Patients with Lateral Lumbar Stenosis
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Baba, Uchida, Maezawa et al., 1996
  Reporting: | Physician-reported
  Method: | Reported number of patients who could walk 500 meters or less before and after surgery.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 31 | Lateral Lumbar Stenosis | Laminotomy | 17 | 38 | 12 | 88 | | | | 15 | | 2
  Authors and Year: | Sanderson and Getty, 1996
  Reporting: | Patient-reported
  Method: | 3 levels. Good: unrestricted walking > 1 hr, Fair: 30 minutes to 1 hour, Poor: < 30 minutes.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 0 | 0 | 0 | | | | 0 | 4 | 53
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 12 | 12 | 12 | | | | 40 | 13 | 4
1 | 66 | Lateral Lumbar Stenosis | Laminotomy | 57 | 101 | 60 | 132 | | | | 37 | 14 | 6
Trials Examining Surgical Patients with Central or Lateral Lumbar Stenosis (type of stenosis unspecified or includes both types of stenosis)
  Study Design: | Controlled Trial
  Authors and Year: | Yone and Sakou, 1999
  Reporting: | Physician-reported
  Method: | JOA score
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 0 | | | 0.6
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 37 | 24 | 52 | 1.7
1 | 14 | Mixed Stenosis with instability | Laminotomy | 14 | 37 | 24 | 52 | 46
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 0 | | | 0.7
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 43 | 24 | 60 | 78
2 | 19 | Mixed Stenosis with instability | Laminotomy with Fusion and Instrumentation | 19 | 43 | 24 | 60 | 2.5
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 0 | | | 0.9
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 33 | 24 | 54 | 81
3 | 27 | Mixed Stenosis without instability | Laminotomy | 27 | 33 | 24 | 54 | 2.6
  Authors and Year: | Javid and Hadar, 1998
  Reporting: | Patient-reported
  Method: | 5 levels. Ex: Much better, Gd: Somewhat better, Fr: no different, Pr: Somewhat worse, VPr: Much worse.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 72 | 57.2 | 12 | 132 | | | 32 | 18 | 7 | 8 | 7
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy | 52 | 56.6 | 12 | 132 | | | 23 | 8 | 9 | 6 | 6
3 | 23 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 22 | 86.6 | 12 | 132 | | | 7 | 8 | 2 | 3 | 2
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Katz, Lipson, Larson et al., 1991
  Reporting: | Patient-reported
  Method: | 6 levels. 1: more than 3 km, 2: more than 2km, 3: 2 blocks to 2km, 4: less than 2 blocks but more than 15 m, 5: less than 15m, 6: bed-bound
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Mixed Stenosis | Mixed Decompression Techniques | 70 | 50 | 34 | 82 | | | 8 | 11 | 19 | 17 | 15
  Study Design: | Case-series
  Authors and Year: | Mackay and Wheelwright, 1998
  Reporting: | Patient-reported
  Method: | Claudication Yes or no, pre and post
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | 50 | 0 | | | | | | 17 | | 33
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy | 50 | 32 | 12 | 49 | | | | 45 | | 5
  Authors and Year: | Katz, Lipson, Chang et al., 1996
  Reporting: | Patient-reported
  Method: | 4 Levels: Over 1 mile, 2 blocks to 1 mile, 50 feet to 2 blocks, less than 50 feet.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 88 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 55 | | 84 | 120 | | | 14 | 12 | 15 | 14
  Authors and Year: | Fast, Robin, and Floman, 1985
  Reporting: | Patient-reported
  Method: | Stated that claudication was relieved by surgery in all but 1 patient.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 19 | 23 | 12 | 36
  Authors and Year: | Hood and Weigl, 1983
  Reporting: | Patient-reported
  Method: | 2 levels: Distance improved or not
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 21 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | | 18 | 60
Trials Examining Surgical Patients with Degenerative Spondylolisthesis
  Study Design: | Randomized Controlled Trial
  Authors and Year: | Bridwell, Sedgewick, O'Brien et al., 1993
  Reporting: | Patient-reported
  Method: | 3 levels. Patients were asked if the surgery had improved (+), not changed (0), or worsened (-) their ability to walk.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 9 | Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 9 | 34 | | | | | | 3 | 3 | 3
2 | 10 | Degenerative Spondylolisthesis | Partial laminectomy and fusion | 10 | 45 | | | | | | 3 | 5 | 2
3 | 24 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation | 24 | 36 | | | | | | 20 | 4
  Study Design: | Controlled Trial
  Authors and Year: | Satomi, Hirabayashi, Toyama et al., 1992
  Reporting: | Patient-reported
  Method: | JOA score 0 (severe pain)-3 (no pain)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 27 | Degenerative Spondylolisthesis | Fusion and instrumentation | 27 | 0 | 0 | 0 | 1.6 | | 4 | 13 | 4 | 6
1 | 27 | Degenerative Spondylolisthesis | Fusion and instrumentation | 27 | 36 | | | 2.7 | | 19 | 8
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 14 | 0 | 0 | 0 | 1 | | 3 | 2 | 9
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques | 14 | 36 | | | 2.3 | | 6 | 7 | 1
  Study Design: | Retrospective Trial with Consecutive Patients
  Authors and Year: | Nishizawa and Fujimura, 1997
  Reporting: | Patient-reported
  Method: | JOA score: 0 (Unable to walk) to 3 (Normal walking)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 58 | Degenerative Spondylolisthesis | Fusion and instrumentation | 58 | 0 | 0 | 0 | 1.2
1 | 58 | Degenerative Spondylolisthesis | Fusion and instrumentation | 58 | 63 | 28 | 128 | 2.8
  Authors and Year: | Takahashi, Kitahara, Yamagata et al., 1990
  Reporting: | Physician-reported
  Method: | Presence or absence of neurogenic claudication
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | Fusion | 32 | 151 | 6 | 360 | | | | 28 | | 4
  Authors and Year: | Knox, Harvell, Nelson et al., 1989
  Reporting: | Patient-reported
  Method: | Number of blocks walked and Pain Scale of 0 (none) to 10 (severe)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 24 | 0 | 0 | 0 | 1.1
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 24 | 21.3 | 4 | 55 | 6.8
  Study Design: | Case-series
  Authors and Year: | Grob, Humke, and Dvorak, 1996
  Reporting: | Patient-reported
  Method: | Distance that could be walked was measured
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 18 | Degenerative/spondylolytic Spondylolisthesis | SWDL with Fusion and Instrumentation | 16 | 0
1 | 18 | Degenerative/spondylolytic Spondylolisthesis | SWDL with Fusion and Instrumentation | 16 | 31 | 24 | 77
Trials Examining Surgical Patients with Lumbar Stenosis and/or Degenerative Spondylolisthesis
  Study Design: | Controlled Trial
  Authors and Year: | Rompe, Eysel, Zollner et al., 1999
  Reporting: | Patient-reported
  Method: | Patients rated walking capacity from 1 (best) to 5 (worst)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 39 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 39 | 0 | 0 | 0 | 3.6 | 1
1 | 39 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy | 25 | 88.8 | | | 2.4 | 0.9
2 | 51 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 51 | 0 | 0 | 0 | 3.5 | 1.1
2 | 51 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 26 | 96 | | | 2.8 | 0.7
3 | 27 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 27 | 0 | 0 | 0 | 3.5 | 0.8
3 | 27 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation | 21 | 88.8 | | | 2.4 | 0.9
  Authors and Year: | Katz, Lipson, Lew et al., 1997
  Reporting: | Patient-reported
  Method: | Scale of 1 to 5 with 1 being no difficulty and 5 being very severe difficulty.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 194 | 0 | | | 3.5 | 0.7
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | | 6 | | | 2.5
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | | 24 | | | 2.6
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | 37 | 0 | | | 3.6 | 0.6
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | | 6 | | | 2.1
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis) | | 24 | | | 2.2
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | 41 | 0 | | | 3.7 | 0.6
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | | 6 | | | 2.6
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy | | 24 | | | 2.5
  Study Design: | Prospective Trial
  Authors and Year: | Jonsson, Annertz, Sjoberg et al., 1997a
  Reporting: | Patient-reported
  Method: | Patients reported ability to walk (<0.5 km, 0.5-1 km, 1-5 km, >5 km)
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 86 | 0 | | | | | 4 | 9 | 13 | 60
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 86 | 4 | | | | | 22 | 22 | 17 | 25
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 86 | 12 | | | | | 23 | 22 | 19 | 22
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 86 | 24 | | | | | 30 | 17 | 13 | 26
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | 86 | 60 | | | | | 20 | 23 | 13 | 30
Trials Examining Surgical Patients and Patients Receiving Conservative Treatment
  Patient Condition: | Central lumbar stenosis
  Study Design: | Controlled Trial
  Authors and Year: | Simotas, Dorey, Hansraj, et al., 2000
  Reporting: | Patient-reported
  Method: | 3 levels. Good: more than 10 blocks (200 ft per block), Fair: 2 to 10 blocks, Poor: less than 2 blocks
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 40 | Central Lumbar Stenosis | Conservative-various treatments | 40 | 33 | 16 | 55 | | | | 18 | 13 | 9
2 | 9 | Central Lumbar Stenosis | Surgery - not described | 9 | 33 | 16 | 55 | | | | 4 | 0 | 5
  Authors and Year: | Mariconda, Zanforlino, Celestino et al., 2000
  Reporting: | Patient-reported
  Method: | 0, 1, 2, 3 scale: 0-only able to walk <100 m, 1-able to walk 100-500 m, 2- can walk >500 m, 3- no restriction in walking
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 0 | | | 0.6 | 1
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 12 | | | 2.2 | 1
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | 20 | 24 | | | 2 | 1.2
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 0 | | | 0.9 | 0.8
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 12 | | | 2.1 | 0.8
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | 17 | 24 | | | 2.1 | 1
  Authors and Year: | Johnsson, Uden, and Rosen, 1991
  Reporting: | Patient-reported
  Method: | Two measurements are reported. A subjective assessment in meters before onset of symptoms and based on a 0-100 visual analog scale where Poor (Worse), Fair (Unchanged), and Good (Improved) were 0-45, 46-55, and 56-1000.
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Time in Months | | | Score | | Rating Category
Patient Group #: | N at start of trial | Specific Disorder: | Treatment: | N | Mean | Min. | Max. | Mean | SD | Ex | Gd | Fr | Pr | VP
1 | 20 | Central Lumbar Stenosis | Conservative-not described | 19 | 0 | 0 | 0 | 1355 | 3081
1 | 20 | Central Lumbar Stenosis | Conservative-not described | 19 | 31 | 7 | 51 | 2342 | 4069 | | 8 | 6 | 5
2 | 30 | Central Lumbar Stenosis - moderate stenosis | SWDL-Standard Wide Decompressive Laminectomy | 30 | 0 | 0 | 0 | 186 | 203
2 | 30 | Central Lumbar Stenosis - moderate stenosis | SWDL-Standard Wide Decompressive Laminectomy | 30 | 50 | 5 | 109 | 1453 | 2935 | | 15 | 8 | 7
3 | 14 | Central Lumbar Stenosis - severe stenosis | SWDL-Standard Wide Decompressive Laminectomy | 14 | 0 | 0 | 0 | 120 | 114
3 | 14 | Central Lumbar Stenosis - severe stenosis | SWDL-Standard Wide Decompressive Laminectomy | 14 | 58 | 3 | 120 | 2373 | 4142 | | 11 | | 0 | 3

Evidence Table 23. Spinal Canal Measurements Related to Low Back Pain and Lumbar Spinal Stenosis All measurements are in millimeters

Patient Condition Back ache
  Authors and Year: | Drinkall, Porter, Hibbert et al., 1984
  Study Design | Case-series
  Imaging Method for Diameter | Ultrasound
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 132 | Healthy Control | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 14.4
  SD | 0.07
2 | 193 | Back Pain | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 14.1
  SD | 0.07

Patient Condition Back Pain
  Authors and Year: | Uden, Johnsson, Jonsson et al., 1985
  Study Design | Case-series
  Imaging Method for Diameter | X-ray Myelography
  Imaging Method for Cross-section | X-ray Myelography
  Imaging Method for Ratio | X-ray Myelography
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 11 | Control | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 14.9
  SD | 4.1
2 | 14 | Atypical symptoms | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 15.6
  SD | 3.8
3 | 33 | Sciatic pain | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 13.3
  SD | 4.1
4 | 10 | Suspicion of claudication | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 13
  SD | 4.6
5 | 23 | Spinal Claudication | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 9.8
  SD | 5.7

Patient Condition Central lumbar stenosis
  Authors and Year: | Mariconda, Zanforlino, Celestino et al., 2000
  Study Design | Controlled Trial
  Imaging Method for Diameter
  Imaging Method for Cross-section | Computed Tomography (CT)
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 20 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | Mean SD | | Mean SD
  Mean | 68
  SD
2 | 17 | Central Lumbar Stenosis | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 78
  SD

  Authors and Year: | Herno, Partanen, Talaslahti et al., 1999
  Study Design | Controlled Trial
  Imaging Method for Diameter
  Imaging Method for Cross-section | Magnetic Resonance Imaging (MRI)
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 41 | Central Lumbar Stenosis - post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | Mean SD | | Mean SD
  Mean | 95
  SD
2 | 15 | Central Lumbar Stenosis - no post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy | Mean SD | | Mean SD
  Mean | 145
  SD

  Authors and Year: | Prasarirha, Suntisathaporn, Vathana et al., 1997
  Study Design | Case-series
  Imaging Method for Diameter | Plain X-ray
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 23 | Healthy Control | Control/Placebo/None | | Mean SD Mean SD | Mean SD Mean SD
  Mean | 15.67
  SD
  Mean | 8.5
  SD | 2.6
2 | 23 | Degenerative Spondylolisthesis | Pretreatment data only | | Mean SD Mean SD | Mean SD Mean SD
  Mean | 13.88
  SD
  Mean | 7.4
  SD | 2.9

  Authors and Year: | Hamdan and Al-Kaissie, 1994
  Study Design | Case-series
  Imaging Method for Diameter
  Imaging Method for Cross-section
  Imaging Method for Ratio | Plain X-ray
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 25 | Central Lumbar Stenosis | Conservative | Mean SD Mean SD | | Mean SD Mean SD
  Mean
  SD
  Mean | 61
  SD | 28
2 | 51 | Low back pain only | Control/Placebo/None | Mean SD Mean SD | | Mean SD Mean SD
  Mean | 130
  SD | 51
  Mean
  SD
3 | 15 | Control (other conditions) | Control/Placebo/None | Mean SD | | Mean SD
  Mean | 144
  SD | 35

  Authors and Year: | Yoshida, Shima, Taniguchi et al., 1992
  Study Design | Case-series
  Imaging Method for Diameter
  Imaging Method for Cross-section | Computed Tomography (CT)
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 10 | Control (herniated disk) | Control/Placebo/None | Mean SD | | Mean SD
  Mean | 356.7
  SD | 90.8
2 | 15 | Central Lumbar Stenosis | Pretreatment data only | Mean SD | | Mean SD
  Mean | 262.8
  SD | 62.8

  Authors and Year: | Johnsson, Uden, and Rosen, 1991
  Study Design | Controlled Trial
  Imaging Method for Diameter | X-ray Myelography
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 20 | Central Lumbar Stenosis | Conservative-not described | | Mean SD | Mean SD
  Mean | 8.6
  SD | 1.7
2 | 30 | Central Lumbar Stenosis - moderate stenosis | SWDL-Standard Wide Decompressive Laminectomy | | Mean SD | Mean SD
  Mean | 7.9
  SD | 2.3
3 | 14 | Central Lumbar Stenosis - severe stenosis | SWDL-Standard Wide Decompressive Laminectomy | | Mean SD | Mean SD
  Mean | 0
  SD | 0

  Authors and Year: | Schonstrom, Bolender, and Spengler, 1985
  Study Design | Case-series
  Imaging Method for Diameter | Computed Tomography (CT)
  Imaging Method for Cross-section | Computed Tomography (CT)
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 24 | Central Lumbar Stenosis | Control/Placebo/None | | | Mean SD
  Mean | 14.1
  SD | 2.7
  Mean | 233.9
  SD | 71.8
2 | 13 | Healthy Control | Control/Placebo/None | | | Mean SD
  Mean | 14.8
  SD | 3.1
  Mean | 178
  SD | 50

  Authors and Year: | Sandhu, Lakhanpal, and Gupta, 1976
  Study Design | Case-series
  Imaging Method for Diameter | Plain X-ray
  Imaging Method for Cross-section
  Imaging Method for Ratio | Plain X-ray
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 50 | Healthy Control | Control/Placebo/None | | Mean SD
  Mean | 16
  SD
  Mean | 4.85
  SD
2 | 10 | Central Lumbar Stenosis | Control/Placebo/None | Mean SD | Mean SD
  Mean | 6.73
  SD

  Authors and Year: | Jones and Thomson, 1968
  Study Design | Case-series
  Imaging Method for Diameter
  Imaging Method for Cross-section
  Imaging Method for Ratio | Plain X-ray
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 50 | Healthy Control | Control/Placebo/None | Mean SD | Mean SD
  Mean | 3.06
  SD
2 | 13 | Central Lumbar Stenosis | Control/Placebo/None | Mean SD | Mean SD
  Mean | 5
  SD

Patient Condition Degenerative Spondylolisthesis
  Authors and Year: | Kim and Lee, 1995
  Study Design | Case-series
  Imaging Method for Diameter | Plain X-ray
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 25 | Healthy Control | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 20.3
  SD | 1.8
2 | 48 | Degenerative Spondylolisthesis | Pretreatment data only | | Mean SD | Mean SD
  Mean | 19.2
  SD | 1.8

  Authors and Year: | Sato, Wakamatsu, Yoshizumi et al., 1989
  Study Design | Controlled Trial
  Imaging Method for Diameter | Plain X-ray
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 257 | Low-back pain controls | Control/Placebo/None | | Mean SD Mean SD | Mean SD Mean SD
  Mean | 21
  SD | 2.4
  Mean
  SD
2 | 98 | Degenerative Spondylolisthesis | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 19.7
  SD | 1.5

Patient Condition Lateral lumbar stenosis
  Authors and Year: | Mikhael, Ciric, Tarkington et al., 1981
  Study Design | Controlled Trial
  Imaging Method for Diameter | Plain X-ray
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 35 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy | | Mean SD | Mean SD
  Mean | 3.6
  SD | 0.8
2 | 50 | Healthy Control | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 7
  SD

Patient Condition Low back pain
  Authors and Year: | Anderson, Adcock, Chovil et al., 1988
  Study Design | Controlled Trial
  Imaging Method for Diameter | Ultrasound
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 16 | Back Pain | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 16
  SD | 2.5
2 | 33 | Healthy Control | Control/Placebo/None | | Mean SD | Mean SD
  Mean | 17.2
  SD | 2.3

Patient Condition Mixed lumbar stenosis
  Authors and Year: | Spetzger, Bertalanffy, Reinges et al., 1997
  Study Design | Case-series
  Imaging Method for Diameter | Computed Tomography (CT)
  Imaging Method for Cross-section | Computed Tomography (CT)
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 29 | Mixed Stenosis | Laminotomy | | | Mean SD
  Mean | 11.6
  SD
  Mean | 60.1
  SD

Patient Condition None
  Authors and Year: | Hultman, Saraste, and Ohlsen, 1992
  Study Design | Case-series
  Imaging Method for Diameter | Computed Tomography (CT)
  Imaging Method for Cross-section | Computed Tomography (CT)
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 38 | Healthy Control | Control/Placebo/None | | | Mean SD
  Mean | 15.9
  SD | 1.6
  Mean | 240.4
  SD | 42.8
2 | 91 | Recurrent Back Pain | Control/Placebo/None | | | Mean SD
  Mean | 15.6
  SD | 1.9
  Mean | 240.7
  SD | 48.8
3 | 21 | Chronic Back Pain | Control/Placebo/None | | | Mean SD
  Mean | 15.1
  SD | 1.9
  Mean | 231.4
  SD | 52.3

Patient Condition Stenosis/Spondylolisthesis
  Authors and Year: | Jonsson, Annertz, Sjoberg et al., 1997a
  Study Design | Prospective Trial
  Imaging Method for Diameter | X-ray Myelography
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy | | Mean SD | Mean SD
  Mean | 6.8
  SD

  Authors and Year: | Johnsson, Uden, and Rosen, 1992
  Study Design | Case-series
  Imaging Method for Diameter | X-ray Myelography
  Imaging Method for Cross-section
  Imaging Method for Ratio
Patient Group # | N | Specific Disorder: | Treatment: | Canal Diameter | Canal Cross Section | Canal Ratio
1 | 32 | Spinal stenosis and spondylolisthesis | No treatment | | Mean SD | Mean SD
  Mean | 7
  SD | 3

Evidence Table 24. Complications of Surgery Related to Treatment of Lumbar Spinal Stenosis

  Authors and Year | Booth, Bridwell, Eisenberg et al., 1999
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation
  Total Complications | 1 | Dural Tears | Thrombosis | Infection | 1 | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Herno, Saari, Suomalainen et al., 1999
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 35 | Central Lumbar Stenosis - no post-surgery stenosis | Mixed Decompression Techniques
  Total Complications | 3 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 57 | Central Lumbar Stenosis - post surgery stenosis | Mixed Decompression Techniques
  Total Complications | 6 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Nakai, Yoshizawa, and Kobayashi, 1999
  Study Design | Prospective Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 23 | Degenerative Spondylolisthesis | Fusion only
  Total Complications | 3 | Dural Tears | Thrombosis | Infection | Instability | 3
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Vitaz, Raque, Shields et al., 1999
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 65 | Central Lumbar Stenosis | Mixed Decompression Techniques
  Total Complications | 7 | Dural Tears | Thrombosis | Infection | 3 | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 4 | Multiple serious complications

  Authors and Year | Epstein, 1998b
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 28 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 1 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 1 | 1 Patient required instrument removal for pain.

  Authors and Year | Javid and Hadar, 1998
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 1 | Dural Tears | 1 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | Infection | 2 | Instability
  Deaths | | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Kalbarczyk, Lukes, and Seiler, 1998
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
3 groups | 148 | Mixed Stenosis | Partial laminectomy and fusion
  Total Complications | 11 | Dural Tears | Thrombosis | 4 | Infection | Instability
  Deaths | 1 | Fractures | Paraplegia | | Incontinence | Collapsed Fusion
  Neurological Disorder | | Note: Complications were not separately reported for each treatment group. It is known that the death from thrombosis was in group 3.
  Adverse Reaction | 7 | 3 Cardiac disturbances, 2 TIAs, 1 urinary tract infection, 1 wound abscess.

  Authors and Year | McCulloch, 1998
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 23 | Degenerative Spondylolisthesis | Partial laminectomy and fusion
  Total Complications | 2 | Dural Tears | Thrombosis | 1 | Infection | 0 | Instability
  Deaths | 0 | Fractures | Paraplegia | | Incontinence | | Collapsed Fusion
  Neurological Disorder | | 1 Minor myocardial infarct
  Adverse Reaction

  Authors and Year | Plotz and Benini, 1998
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 17 | Degenerative Spondylolisthesis | Decompressive Surgery without fusion
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 18 | Degenerative Spondylolisthesis | Decompressive Surgery with fusion and Translaminar Screw Fixation
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
3 | 71 | Degenerative Spondylolisthesis | Decompressive Surgery with fusion and AO Internal Fixator
  Total Complications | 8 | Dural Tears | 5 | Thrombosis | Infection | 3 | Instability
  Deaths | | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Tsai, Yang, and Bray, 1998
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 62 | Mixed Stenosis | Laminotomy
  Total Complications | 6 | Dural Tears | 1 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | | 2 patients had urinary retention. 3 patients needed reoperation for recurrent symptoms.

  Authors and Year | Whitecloud, Castro, Brinker et al., 1998
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 35 | Mixed Stenosis | SWDL with Fusion and Instrumentation
  Total Complications | 30 | Dural Tears | Thrombosis | 0 | Infection | 2 | Instability
  Deaths | | Fractures | Paraplegia | | Incontinence | | Collapsed Fusion
  Neurological Disorder | 4 | Not described.
  Adverse Reaction | | 1 venous puncture, 1 pneumothorax, 2 peritoneal rent, 1 abdominal hernia, 1 pulmonary embolism, etc.

  Authors and Year | Airaksinen, Herno, Turunen et al., 1997
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 497 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 48 | Dural Tears | 13 | Thrombosis | 20 | Infection | 15 | Instability
  Deaths | | Fractures | | Paraplegia | | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Fischgrund, Mackay, Herkowitz et al., 1997
  Study Design | Randomized Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 40 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | 0 | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 0
  Adverse Reaction
2 | 35 | Degenerative Spondylolisthesis | SWDL with Fusion (Arthrodesis)
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | 0 | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 0
  Adverse Reaction

  Authors and Year | Spetzger, Bertalanffy, Reinges et al., 1997
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 29 | Mixed Stenosis | Laminotomy
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | 1 | Infection | 1 | Instability
  Deaths | 0 | Fractures | | Paraplegia | | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Thomas, Rea, Pikul et al., 1997
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 12 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 0 | Dural Tears | 0 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 0
  Adverse Reaction
2 | 14 | Central Lumbar Stenosis | Laminotomy
  Total Complications | 2 | Dural Tears | 0 | Thrombosis | Infection | Instability | 0
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 0
  Adverse Reaction | 2 | 1 patient with pneumonia, 1 patient with urinary tract infection.

  Authors and Year | Thomsen, Christensen, Eiskjaer et al., 1997
  Study Design | Randomized Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 20 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation
  Total Complications | 1 | Dural Tears | 1 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 21 | Degenerative Spondylolisthesis | Partial laminectomy and fusion
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Atlas, Deyo, Keller et al., 1996
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 10 | Dural Tears | 8 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 2 | 1 neuropraxia and 1 hematoma
  Adverse Reaction

  Authors and Year | diPierro, Helm, Shaffrey et al., 1996
  Study Design | Prospective Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 35 | Central Lumbar Stenosis | Partial laminectomy and fusion
  Total Complications | 4 | Dural Tears | Thrombosis | Infection | 2 | Instability | 0
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 2 | Cerebrospinal fluid leak

  Authors and Year | Grob, Humke, and Dvorak, 1996
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 18 | Degenerative/spondylolytic Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | Infection | Instability
  Deaths | | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | | 1 Patient had a postoperative seroma requiring revision. One had a screw that was too long and had to be replaced.

  Authors and Year | Ishac, Alhayek, Fournier et al., 1996
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 3 | Dural Tears | Thrombosis | | Infection | 1 | Instability
  Deaths | 0 | Fractures | Paraplegia | 1 | Incontinence | | Collapsed Fusion
  Neurological Disorder | 1 | Foot drop
  Adverse Reaction

  Authors and Year | Rechtine, Sutterlin, Wood et al., 1996
  Study Design | Prospective Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 18 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 4 | Dural Tears | 3 | Thrombosis | | Infection | 0 | Instability
  Deaths | 0 | Fractures | 0 | Paraplegia | 0 | Incontinence | | Collapsed Fusion
  Neurological Disorder | 0
  Adverse Reaction | 1 | "stripped screw"

  Authors and Year | Sanderson and Getty, 1996
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 66 | Lateral Lumbar Stenosis | Laminotomy
  Total Complications | 6 | Dural Tears | Thrombosis | 4 | Infection | 2 | Instability
  Deaths | 0 | Fractures | Paraplegia | 0 | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Crock, Shiraishi, and Crock, 1995
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 34 | Mixed Stenosis | Partial laminectomy or hemilaminectomy
  Total Complications | | Dural Tears | 1 | Thrombosis | Infection | 2 | Instability | 0
  Deaths | | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 1 | Unilateral foot drop.
  Adverse Reaction

  Authors and Year | Grob, Humke, and Dvorak, 1995
  Study Design | Randomized Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy
  Total Complications | 2 | Dural Tears | 1 | Thrombosis | Infection | | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | 1 | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | Infection | | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 2 | Screws were removed because of persistent local pain.
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation
  Total Complications | 4 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 1 | Diffuse motor weakness of the left lower limb.
  Adverse Reaction | 3 | Loose internal fixator in one patient. Broken screws in two patients.

  Authors and Year | Rompe, Eysel, Hopf et al., 1995
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 24 | Mixed Stenosis | SWDL with Fusion and Instrumentation
  Total Complications | 3 | Dural Tears | 2 | Thrombosis | Infection | Instability | 1
  Deaths | | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 24 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 10 | Dural Tears | 8 | Thrombosis | Infection | Instability
  Deaths | 1 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 1 | Pulmonary embolism
3 | 12 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 2 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 1 | Paraparesis
  Adverse Reaction | 1 | Persistent disturbance of wound healing

  Authors and Year | Jonsson and Stromqvist, 1994
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 43 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | Infection | 1 | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 1 | cauda equina syndrome

  Authors and Year | Yuan, Garfin, Dickman et al., 1994
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 2177 | Degenerative Spondylolisthesis | Fusion and Pedical Screw Fixation
  Total Complications | 381 | Dural Tears | 161 | Thrombosis | Infection | 56 | Instability
  Deaths | 0 | Fractures | 26 | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 138 | 11 cord or root injury; 127 new radicular pain
  Adverse Reaction
2 | 456 | Degenerative Spondylolisthesis | Fusion
  Total Complications | 59 | Dural Tears | 26 | Thrombosis | Infection | 11 | Instability
  Deaths | 0 | Fractures | 0 | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 22 | New radicular pain
  Adverse Reaction

  Authors and Year | Bridwell, Sedgewick, O'Brien et al., 1993
  Study Design | Randomized Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 9 | Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 0 | No peripheral neurologic deficits.
  Adverse Reaction
2 | 10 | Degenerative Spondylolisthesis | Partial laminectomy and fusion
  Total Complications | 1 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 0 | No peripheral neurologic deficits.
  Adverse Reaction | 1 | Postoperative cerebrovascular accident.
3 | 24 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | Infection | 1 | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 0 | No peripheral neurologic deficits.
  Adverse Reaction | 1 | One patient with poor lateral screw placement

  Authors and Year | Postacchini, Cinotti, Perugia et al., 1993
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 26 | Congenital or Degenerative Stenosis, Combined, or Deg. Spondylolisthesis | Laminotomy
  Total Complications | 3 | Dural Tears | Thrombosis | Infection | Instability | 4
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 3 | Moderate to complete deficit of a single nerve root.
  Adverse Reaction
2 | 41 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 1 | Dural Tears | Thrombosis | Infection | Instability | 2
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder | 1 | Increase in a preoperative deficit of the L5 root
  Adverse Reaction

  Authors and Year | Silvers, Lewis, and Asch, 1993
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 248 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 57 | Dural Tears | 32 | Thrombosis | 3 | Infection | 3 | Instability
  Deaths | 2 | Fractures | | Paraplegia | | Incontinence | | Collapsed Fusion
  Neurological Disorder | 1 | Severe paraparesis
  Adverse Reaction

  Authors and Year | Simmons and Simmons, 1992
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 40 | Mixed Stenosis | SWDL with Fusion and Instrumentation
  Total Complications | 8 | Dural Tears | Thrombosis | Infection | 1 | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | 3 | 2 paresthesia, 1 extensor hallucis longus weakness
  Adverse Reaction | 4 | 1 wound edge necrosis, 1 myocardial infarction, 2 urinary tract infections

  Authors and Year | Marchesi, Thalgott, and Aebi, 1991
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 30 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 1 | Dural Tears | Thrombosis | Infection | 1 | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Chang and McAfee, 1989
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 17 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 5 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 5 | 5 urinary tract infections

  Authors and Year | Herron and Trippi, 1989
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 24 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 2 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 2 | 1 intraoperative cardiac pacemaker malfunction, 1 postoperative acute ethanol withdrawal.

  Authors and Year | Johnsson, Redlund-Johnell, Uden et al., 1989
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 61 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 1 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | | One patient died of sepsis shortly after the operation.

  Authors and Year | Knox, Harvell, Nelson et al., 1989
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  Total Complications | 4 | Dural Tears | 1 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 3 | 1 wound dehiscence, 1 iliac crest bone graft site infection, 1 upper gastrointestinal bleed

  Authors and Year | Mauersberger and Nietgen, 1989
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 92 | Mixed Stenosis | Decompressive surgery with or without fusion
  Total Complications | Dural Tears | Thrombosis | Infection | 1 | Instability
  Deaths | Fractures | Paraplegia | Incontinence | 1 | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | The pt with postop incontinence required further surgery for resection of another lumbar segment.

  Authors and Year | Nasca, 1989
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 15 | Lateral Lumbar Stenosis | Decompressive Surgery
  Total Complications | 2 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | | 2 patients required fusion 1 and 3 years later.
5 | 22 | Mixed Stenosis with instability | Decompressive Surgery with fusion and instrumentation
  Total Complications | 4 | Dural Tears | 1 | Thrombosis | Infection | | Instability
  Deaths | | Fractures | | Paraplegia | Incontinence | 1 | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 2 | 2 postop hematomas
6 | 11 | Degenerative Stenosis and scoliosis | Decompressive Surgery with fusion and instrumentation
  Total Complications | 3 | Dural Tears | Thrombosis | Infection | Instability | 1
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 2 | 1 wound dishescence, 1 diffuse-intravascular coagulopathy

  Authors and Year | Young, Veerapen, and O'Laoire, 1988
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 32 | Central Lumbar Stenosis | Decompressive Surgery
  Total Complications | 9 | Dural Tears | 3 | Thrombosis | Infection | 3 | Instability
  Deaths | | Fractures | | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder | | 1 pseudomeningocele, 1 root damage
  Adverse Reaction | | 1 hematoma

  Authors and Year | Lee and deBari, 1986
  Study Design | Randomized Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 12 | Lateral Lumbar Stenosis | SWDL with Fusion (Arthrodesis)
  Total Complications | 0 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction
2 | 12 | Lateral Lumbar Stenosis | SWDL with Fusion and Instrumentation
  Total Complications | 5 | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 5 | 5 patients with Knodt rods had subsequent operations to remove the rods due to local irritation.

  Authors and Year | Hall, Bartleson, Onofrio et al., 1985
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 68 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | | Dural Tears | Thrombosis | Infection | Instability
  Deaths | 1 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Rosomoff, 1981
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 50 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 7 | Dural Tears | Thrombosis | Infection | 6 | Instability | 1
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Scafuri and Weinstein, 1981
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 27 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 3 | Dural Tears | 1 | Thrombosis | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 2 | 1 patient with urinary tract infection. 1 patient with dural cutaneous fistula.

  Authors and Year | Weir and De Leo, 1981
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 81 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 9 | Dural Tears | Thrombosis | 0 | Infection | 1 | Instability
  Deaths | 0 | Fractures | Paraplegia | | Incontinence | 2 | Collapsed Fusion
  Neurological Disorder | 4 | 3 transient neurologic deficit, 1 permanent increase in neurological deficit
  Adverse Reaction | 2 | pulmonary complications

  Authors and Year | Getty, 1980
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 35 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 12 | Dural Tears | Thrombosis | 4 | Infection | 2 | Instability
  Deaths | | Fractures | Paraplegia | | Incontinence | 6 | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Reale, Deifini, Gambacona et al., 1978
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 37 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 5 | Dural Tears | Thrombosis | Infection | 2 | Instability
  Deaths | 0 | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 3 | 2 epiduritis, 1 spondylitis

  Authors and Year | Choudhury and Taylor, 1977
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 28 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 8 | Dural Tears | 1 | Thrombosis | 1 | Infection | Instability
  Deaths | 0 | Fractures | | Paraplegia | | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction | 6 | 6 patients had temporary urinary retention, requiring catheterization for 12-48 hours.

  Authors and Year | Verbiest, 1977
  Study Design | Retrospective Trial with Consecutive Patients
Patient Group # | N | Specific Disorder: | Treatment:
1 | 116 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 8 | Dural Tears | Thrombosis | 1 | Infection | Instability | 0
  Deaths | 1 | Fractures | Paraplegia | | Incontinence | Collapsed Fusion
  Neurological Disorder | 7 | Radicular deficits characterized as 3 bilateral peroneal weakness, 2 disturbance of micturition, and 2 increase in bilateral sensory deficit.
  Adverse Reaction

  Authors and Year | Vestad and Naca, 1977
  Study Design | Case-series
Patient Group # | N | Specific Disorder: | Treatment:
1 | 80 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 2 | Dural Tears | Thrombosis | Infection | 2 | Instability
  Deaths | | Fractures | Paraplegia | Incontinence | | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Fitzgerald and Newman, 1976
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
2 | 14 | Degenerative Spondylolisthesis | Mixed Decompression Techniques
  Total Complications | 2 | Dural Tears | Thrombosis | Infection | Instability | 2
  Deaths | | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Paine, 1976
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 95 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 8 | Dural Tears | Thrombosis | 1 | Infection | 2 | Instability
  Deaths | 1 | Fractures | Paraplegia | | Incontinence | | Collapsed Fusion
  Neurological Disorder | 2 | Increased cauda equina lesion. Complications reported for all 457 patients, not just the 95 with LSS. Length of FU not correctly reported.
  Adverse Reaction | 3 | 2 pulmonary embolus, on fatal. 1 postoperative hemorrhage.

  Authors and Year | Rosenberg, 1976
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
2 | 15 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy
  Total Complications | 5 | Dural Tears | Thrombosis | Infection | Instability | 5
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

  Authors and Year | Tile, McNeil, Zarins et al., 1976
  Study Design | Controlled Trial
Patient Group # | N | Specific Disorder: | Treatment:
1 | 26 | Mixed Stenosis | Mixed Decompression Techniques
  Total Complications | 7 | Dural Tears | Thrombosis | Infection | Instability | 7
  Deaths | 0 | Fractures | Paraplegia | Incontinence | Collapsed Fusion
  Neurological Disorder
  Adverse Reaction

Evidence Table 25. Reported Co-morbidities of Patients with Lumbar Spinal Stenosis

  Patient Condition: | Backache
  Authors and Year: | Splithoff, 1953
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 100 | Healthy Control | Control/Placebo/None
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity | 30
  Spondylolisthesis n=8, Osteoarthritis of the lumbosacral junction n=22
2 | 100 | Backache | Control/Placebo/None
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  Spondylolisthesis n=2, Osteoarthritis of the lumbosacral junction n=26.

  Patient Condition: | Central lumbar stenosis
  Authors and Year: | Kleeman, Hiscoe, and Berg, 2000
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 54 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidities
  Liver | | Hypertension | | Neurological
  Kidney | | Hip | | Pulmonary | 14
  Heart | 36 | Knee | | Herniated Disk
  Diabetes | 6 | Arthritis | 4 | Degenerative Spine | 15
  Other Comorbidities Osteoporosis | 19

  Authors and Year: | Herno, Partanen, Talaslahti et al., 1999
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 41 | Central Lumbar Stenosis - post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity | 15
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  Only the number of patients with co-existing diseases was reported.
2 | 15 | Central Lumbar Stenosis - no post surgery stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity | 6
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  Only the number of patients with co-existing diseases was reported.

  Authors and Year: | Herno, Saari, Suomalainen et al., 1999
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 35 | Central Lumbar Stenosis - no postsurgery stenosis | Mixed Decompression Techniques
  No Reported Comorbidity | 18
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  Comorbidity were reported as a total number and not defined.
2 | 57 | Central Lumbar Stenosis - post surgery stenosis | Mixed Decompression Techniques
  No Reported Comorbidity | 38
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  Comorbidity were reported as a total number and not defined.

  Authors and Year: | Vitaz, Raque, Shields et al., 1999
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 65 | Central Lumbar Stenosis | Mixed Decompression Techniques
  No Reported Comorbidity
  Liver | | Hypertension | 37 | Neurological
  Kidney | | Hip | | Pulmonary | 7
  Heart | 37 | Knee | | Herniated Disk | 33
  Diabetes | 11 | Arthritis | | Degenerative Spine
  Other Comorbidity hypothyroid | 11

  Authors and Year: | Airaksinen, Herno, Turunen et al., 1997
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 497 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity | 255
  Liver | | Hypertension | | Neurological | 35
  Kidney | | Hip | 12 | Pulmonary | 17
  Heart | 38 | Knee | 21 | Herniated Disk
  Diabetes | 13 | Arthritis | 8 | Degenerative Spine
  Other Comorbidity hypothyroid | 35
  35 patients not described.

  Authors and Year: | Matsui, Kanamori, Ishihara et al., 1997
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 27 | Central Lumbar Stenosis | SWDL with Fusion (Arthrodesis)
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 7
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 5
  Spondylolisthesis

  Authors and Year: | Thomas, Rea, Pikul et al., 1997
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 12 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | | Neurological | 1
  Kidney | | Hip | 1 | Pulmonary
  Heart | 1 | Knee | | Herniated Disk
  Diabetes | | Arthritis | | Degenerative Spine
  Other Comorbidity
2 | 14 | Central Lumbar Stenosis | Laminotomy
  No Reported Comorbidity
  Liver | | Hypertension | | Neurological | 3
  Kidney | | Hip | | Pulmonary
  Heart | 1 | Knee | | Herniated Disk
  Diabetes | | Arthritis | | Degenerative Spine
  Other Comorbidity | 1
  Hypothyroid

  Authors and Year: | diPierro, Helm, Shaffrey et al., 1996
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 35 | Central Lumbar Stenosis | Partial laminectomy and fusion
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine | 3
  Other Comorbidity

  Authors and Year: | Ishac, Alhayek, Fournier et al., 1996
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 34 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine | 1
  Other Comorbidity

  Authors and Year: | Grob, Humke, and Dvorak, 1995
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 15 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | 1 | Knee | Herniated Disk | 3
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity
2 | 15 | Central Lumbar Stenosis - single level | Partial laminectomy with fusion and instrumentation
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 6
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
3 | 15 | Central Lumbar Stenosis - multiple segments | Partial laminectomy with fusion and instrumentation
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 7
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Hamdan and Al-Kaissie, 1994
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 25 | Central Lumbar Stenosis | Conservative
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 12
  3 patients with spondylolisthesis, 9 patients with arthritis of the spine

  Authors and Year: | Jonsson and Stromqvist, 1994
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 43 | Central Lumbar Stenosis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity
  Liver | | | Hypertension | | Neurological | 5
  Kidney | | | Hip | 5 | Pulmonary
  Heart | 7 | | Knee | 5 | Herniated Disk
  Diabetes | | | Arthritis | | Degenerative Spine
  Other Comorbidity | | 13
  Spondylolisthesis

  Authors and Year: | Caputy and Luessenhop, 1992
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 100 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | | Hypertension | 29 | Neurological | 5
  Kidney | | | Hip | 5 | Pulmonary
  Heart | 25 | | Knee | 5 | Herniated Disk | 14
  Diabetes | 9 | | Arthritis | | Degenerative Spine
  Other Comorbidity | | 11
  Hypothyroid

  Authors and Year: | Yoshida, Shima, Taniguchi et al., 1992
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 10 | Control (herniated disk) | Control/Placebo/None
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 10
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Johnsson, Uden, and Rosen, 1991
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 20 | Central Lumbar Stenosis | Conservative-not described
  No Reported Comorbidity
  Liver | | | Hypertension | Neurological
  Kidney | | | Hip | Pulmonary
  Heart | 2 | | Knee | Herniated Disk
  Diabetes | | | Arthritis | Degenerative Spine
  Other Comorbidity | | 5
  Degenerative olisthesis
3 | 14 | Central Lumbar Stenosis - severe stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 7
  Degenerative Olisthesis

  Authors and Year: | Kurihara, Tanaka, Tsumura et al., 1988
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 12 | Hyperostotic stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine | 4
  Other Comorbidity
  At least 4 patients also had stenosis of the thoracic and/or cervical spine.

  Authors and Year: | Schonstrom, Bolender, and Spengler, 1985
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 24 | Central Lumbar Stenosis | Control/Placebo/None
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 7
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Chahal, Mundkur, Sancheti et al., 1982
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 32 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 12
  Diabetes | Arthritis | Degenerative Spine | 19
  Other Comorbidity

  Authors and Year: | Johnsson, Willner, and Pettersson, 1981
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 27 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 6
  Spondylolisthesis

  Authors and Year: | Weir and De Leo, 1981
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 81 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological | 67
  Kidney | | Hip | Pulmonary
  Heart | 17 | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Tajima, Fukazawa, and Ishio, 1980
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 13 | Central Lumbar Stenosis | Mixed Decompression Techniques
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
2 | 14 | Central Lumbar Stenosis and disk lesion | Mixed Decompression Techniques
  No Reported Comorbidity | 0
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 14
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Reale, Deifini, Gambacona et al., 1978
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 37 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 12
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Verbiest, 1977
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 116 | Congenital Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 62
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Salibi, 1976
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 20 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 16
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 1
  Spondylolisthesis

  Patient Condition: | Degenerative Spondylolisthesis
  Authors and Year: | Booth, Bridwell, Eisenberg et al., 1999
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 49 | Degenerative Spondylolisthesis | Partial laminectomy with fusion and instrumentation
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  Patients had an average of 2.7 +/- 1.8 comorbidity.

  Authors and Year: | Epstein, 1998a
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 290 | Mixed Stenosis | Mixed Decompression Techniques
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 59
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | McCulloch, 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 23 | Degenerative Spondylolisthesis | Partial laminectomy and fusion
  No Reported Comorbidity | 19
  Liver | | Hypertension | Neurological | 1
  Kidney | | Hip | Pulmonary
  Heart | 1 | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Yuan, Garfin, Dickman et al., 1994
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 2177 | Degenerative Spondylolisthesis | Fusion and Pedical Screw Fixation
  No Reported Comorbidity
  Liver | | | Hypertension | Neurological
  Kidney | | | Hip | Pulmonary
  Heart | | | Knee | Herniated Disk
  Diabetes | 321 | | Arthritis | Degenerative Spine
  Other Comorbidity | | 610
  Osteoporosis
2 | 456 | Degenerative Spondylolisthesis | Fusion
  No Reported Comorbidity
  Liver | | | Hypertension | Neurological
  Kidney | | | Hip | Pulmonary
  Heart | | | Knee | Herniated Disk
  Diabetes | 68 | | Arthritis | Degenerative Spine
  Other Comorbidity | | 128
  Osteoporosis

  Authors and Year: | Marchesi, Thalgott, and Aebi, 1991
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 30 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 8
  Osteoporosis

  Authors and Year: | Knox, Harvell, Nelson et al., 1989
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 39 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  No Reported Comorbidity
  Liver | | | Hypertension | | Neurological
  Kidney | | | Hip | | Pulmonary
  Heart | 2 | | Knee | | Herniated Disk
  Diabetes | | | Arthritis | 11 | Degenerative Spine
  Other Comorbidity | | 1
  rheumatoid arthritis

  Authors and Year: | Inoue, Watanabe, Goto et al., 1988
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 36 | Degenerative Spondylolisthesis | Fusion
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 8
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Kaneda and Kazama, 1986
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 54 | Degenerative Spondylolisthesis | SWDL with Fusion and Instrumentation
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 8
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Alexander Jr, Kelly Jr, Davis Jr et al., 1985
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 50 | Degenerative Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 7
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  7 herniated disks, 11 protruding or bulging disks, 7 extruded disks.

  Authors and Year: | Epstein, Epstein, Carras et al., 1983
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 60 | Degenerative Spondylolisthesis | Mixed Decompression Techniques
  No Reported Comorbidity
  Liver | | Hypertension | | Neurological | 1
  Kidney | | Hip | 12 | Pulmonary
  Heart | 1 | Knee | 7 | Herniated Disk | 2
  Diabetes | 6 | Arthritis | 1 | Degenerative Spine | 1
  Other Comorbidity | 4
  Hypothyroid

  Authors and Year: | Rosenberg, 1976
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 11 | Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 4
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Patient Condition: | Lateral lumbar stenosis
  Authors and Year: | Sanderson and Getty, 1996
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 66 | Lateral Lumbar Stenosis | Laminotomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 18
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Kirkaldy-Willis, Wedge, Yong-Hing et al., 1982
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
2 | 32 | Lateral Lumbar Stenosis with disk herniation | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity | 0
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 32
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
4 | 21 | Lateral and Central Lumbar Stenosis with disk herniation | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity | 0
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 21
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Mikhael, Ciric, Tarkington et al., 1981
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 35 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 7
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 5
  Degenerative spondylolisthesis

  Authors and Year: | Choudhury and Taylor, 1977
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 28 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 4
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity bulging disks | 5

  Authors and Year: | Epstein, Epstein, Rosenthal et al., 1972
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 15 | Lateral Lumbar Stenosis | Foraminotomy/nerve root decompression
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Patient Condition: | Mixed lumbar stenosis
  Authors and Year: | Guigui, Benoist, Delecourt et al., 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 50 | Mixed Stenosis | Decompressive Surgery
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 23
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Javid and Hadar, 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 86 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 0
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 6
  Degenerative Spondylolisthesis
2 | 61 | Central Lumbar Stenosis and Herniated Disk | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 61
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
3 | 23 | Lateral Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Mackay and Wheelwright, 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 50 | Mixed Stenosis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 4
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Scholz, Firsching, and Lanksch, 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 72 | Mixed Stenosis | Decompressive Surgery
  No Reported Comorbidity
  Liver | | Hypertension | | Neurological | 5
  Kidney | | Hip | 2 | Pulmonary
  Heart | 3 | Knee | | Herniated Disk
  Diabetes | 9 | Arthritis | 1 | Degenerative Spine
  Other Comorbidity
  3 cervical myelopathy, 3 cancer

  Authors and Year: | Tsai, Yang, and Bray, 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 62 | Mixed Stenosis | Laminotomy
  No Reported Comorbidity | | 21
  Liver | | Hypertension | 12 | Neurological
  Kidney | | Hip | | Pulmonary | 3
  Heart | 5 | Knee | | Herniated Disk
  Diabetes | 4 | Arthritis | 11 | Degenerative Spine
  Other Comorbidity | 2
  Not described

  Authors and Year: | Whitecloud, Castro, Brinker et al., 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 35 | Mixed Stenosis | SWDL with Fusion and Instrumentation
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 5
  Diabetes | | Arthritis | Degenerative Spine | | 10
  Other Comorbidity | 25
  Either overweight or obese.

  Authors and Year: | Spetzger, Bertalanffy, Reinges et al., 1997
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 29 | Mixed Stenosis | Laminotomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 2
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Atlas, Deyo, Keller et al., 1996
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 81 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  60.5% of patients had self-reported chromic pulmonary disease, heart disease, stroke, cancer, or diabetes.
2 | 67 | Mixed Stenosis | Conservative-many
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  68.2% of patients had self-reported chromic pulmonary disease, heart disease, stroke, cancer, or diabetes.

  Authors and Year: | Katz, Lipson, Chang et al., 1996
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 88 | Degenerative Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | | Neurological
  Kidney | Hip | | Pulmonary
  Heart | Knee | | Herniated Disk
  Diabetes | Arthritis | 9 | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Crock, Shiraishi, and Crock, 1995
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 34 | Mixed Stenosis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity
  Liver | | | Hypertension | Neurological
  Kidney | | | Hip | Pulmonary
  Heart | 5 | | Knee | Herniated Disk
  Diabetes | 1 | | Arthritis | Degenerative Spine
  Other Comorbidity | | 11
  5 patients with degenerative spondylolisthesis of 20% slippage.6 patients with scoliosis.

  Authors and Year: | Lehto and Honkanen, 1995
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 96 | Mixed Stenosis | Decompressive Surgery
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 61
  61 patients were overweight (BMI>25)

  Authors and Year: | Cinotti, Postacchini, and Weinstein, 1994
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 25 | Mixed Stenosis - diabetes | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | 5 | Knee | Herniated Disk
  Diabetes | 25 | Arthritis | Degenerative Spine
  Other Comorbidity
  Cumulative Illness Rating Scale with three classes: 5 patients with less than 2 patients; 6 patients with 3 to 5 points, and 14 patients with more than 6 points.
2 | 25 | Mixed Stenosis - no diabetes | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | 1 | Knee | Herniated Disk
  Diabetes | 0 | Arthritis | Degenerative Spine
  Other Comorbidity
  Cumulative Illness Rating Scale with three classes: 7 patients with less than 2 patients; 9 patients with 3 to 5 points, and 9 patients with more than 6 points.

  Authors and Year: | McCullen, Bernini, Bernstein et al., 1994
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 193 | Mixed Stenosis | Decompressive Surgery
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | 19 | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Silvers, Lewis, and Asch, 1993
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 248 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 42
  Diabetes | 13 | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Simpson, Silveri, Balderston et al., 1993
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 33 | Mixed Stenosis - diabetes | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity | | 0
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | 33 | Arthritis | Degenerative Spine
  Other Comorbidity
2 | 24 | Mixed Stenosis - no diabetes | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | 0 | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Katz, Lipson, Larson et al., 1991
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 88 | Mixed Stenosis | Mixed Decompression Techniques
  No Reported Comorbidity
  Liver | | | Hypertension | | Neurological
  Kidney | | | Hip | | Pulmonary | 6
  Heart | 20 | | Knee | | Herniated Disk
  Diabetes | | | Arthritis | 28 | Degenerative Spine
  Other Comorbidity | | 9
  rheumatoid arthritis

  Authors and Year: | Ganz, 1990
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 36 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 3
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Nasca, 1989
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 15 | Lateral Lumbar Stenosis | Decompressive Surgery
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 4
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 4
  4 patients had herniated disks.
2 | 29 | Central-mixed Stenosis | Decompressive Surgery
  No Reported Comorbidity
  Liver | Hypertension | | Neurological
  Kidney | Hip | | Pulmonary
  Heart | Knee | | Herniated Disk
  Diabetes | Arthritis | 1 | Degenerative Spine
  Other Comorbidity
6 | 11 | Degenerative Stenosis and scoliosis | Decompressive Surgery with fusion and instrumentation
  No Reported Comorbidity
  Liver | | Hypertension | | Neurological
  Kidney | | Hip | | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | 2 | Degenerative Spine
  Other Comorbidity | 8
  8 had osteoporosis

  Authors and Year: | Fast, Robin, and Floman, 1985
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 19 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | 1 | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Hood and Weigl, 1983
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 21 | Mixed Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | 2 | Knee | Herniated Disk
  Diabetes | 2 | Arthritis | Degenerative Spine
  Other Comorbidity
  1 multiple arthroplasties, 1 peripheral vascular disease- this patient died and is not otherwise reported on.

  Authors and Year: | Paine, 1976
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
2 | 48 | Degenerative stenosis with disk herniation | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 48
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Shenkin and Hash, 1976
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 49 | Mixed Stenosis - no prior surgery | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
2 | 21 | Mixed Stenosis - prior surgery for herniated disk | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity

  Patient Condition: | Stenosis/Spondylolisthesis
  Authors and Year: | Radu and Menkes, 1998
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 62 | Central Lumbar Stenosis | Conservative
  No Reported Comorbidity | | 7
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 14
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 38
  20 Spondylolisthesis, 18 Scoliosis

  Authors and Year: | Jonsson, Annertz, Sjoberg et al., 1997a
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 105 | Central Spinal Stenosis and Degenerative Spondylolisthesis | Partial laminectomy or hemilaminectomy
  No Reported Comorbidity | | 19
  Liver | | Hypertension | | Neurological | 5
  Kidney | | Hip | 5 | Pulmonary
  Heart | 3 | Knee | 6 | Herniated Disk
  Diabetes | | Arthritis | | Degenerative Spine
  Other Comorbidity

  Authors and Year: | Katz, Lipson, Lew et al., 1997
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 194 | Mixed Stenosis / Sponsylolisthesis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  45 with spondylolisthesis, and 14 with scoliosis
2 | 37 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion (Arthrodesis)
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  26 with spondylolisthesis, and 1 with scoliosis
3 | 41 | Mixed Stenosis and Spondylolisthesis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  22 with spondylolisthesis, and 5 with scoliosis

  Authors and Year: | Amundsen, Weber, Lilleas et al., 1995
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 100 | Mixed Stenosis | Control/Placebo/None
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 9
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
  56 patients had scoliosis and 12 patients had degenerative spondylolisthesis.

  Authors and Year: | Rompe, Eysel, Hopf et al., 1995
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 24 | Mixed Stenosis | SWDL with Fusion and Instrumentation
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk | 14
  Diabetes | | Arthritis | Degenerative Spine
  Other Comorbidity | 3
  Degenerative spondylolisthesis
3 | 12 | Mixed Stenosis and Spondylolisthesis | SWDL with Fusion and Instrumentation
  No Reported Comorbidity
  Liver | | Hypertension | Neurological
  Kidney | | Hip | Pulmonary
  Heart | | Knee | Herniated Disk
  Diabetes | | Arthritis | Degenerative Spine | 3
  Other Comorbidity | 9
  Degenerative spondylolisthesis

  Authors and Year: | Postacchini, Cinotti, Perugia et al., 1993
Patient Group # | N | Specific Disorder | Treatment | Number of Patients with each Disease or Co-morbidity
1 | 26 | Congenital or Degenerative Stenosis, Combined, or Deg. Spondylolisthesis | Laminotomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 0
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity
2 | 41 | Central Lumbar Stenosis | SWDL-Standard Wide Decompressive Laminectomy
  No Reported Comorbidity
  Liver | Hypertension | Neurological
  Kidney | Hip | Pulmonary
  Heart | Knee | Herniated Disk | 4
  Diabetes | Arthritis | Degenerative Spine
  Other Comorbidity