# References

Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project. HCUPnet [dataset online]. [cited 2000 Mar 13]. Available: http://www.ahcpr.gov/data/hcup/hcupnet.htm.
Airaksinen O, Herno A, Turunen V, et al Surgical outcome of 438 patients treated surgically for lumbar spinal stenosis Spine 1997 Oct 1 22(19):2278 82
Alvarez JA, Hardy RH Jr Lumbar spine stenosis: a common cause of back and leg pain Am Fam Physician 1998 Apr 15 57(8):1825 34, 1839-40
ACR Appropriateness Criteria for Imaging and Treatment Decisions [online]. The American College of Radiology; Reston, VA. [cited 2000 May 31]. Available: http://www.acr.org/departments/appropriateness_criteria/toc.html.
ACR standard for the performance of myelography and cicternography. [article online]. American College of Radiology; 1999 May 25[cited 2000 May 04]. [4 p]. Available: http://www.acr.org.
Amundsen T, Weber H, Nordal HJ, et al Lumbar spinal stenosis: conservative or surgical management? A prospective 10-year study Spine 2000 Jun 1 25(11):1424 35 discussion 1435-6
Amundsen T, Weber H, Lilleas F, et al Lumbar spinal stenosis. Clinical and radiologic features Spine 1995 May 15 20(10):1178 86
Anderson DJ, Adcock DF, Chovil AC, et al Ultrasound lumbar canal measurement in hospital employees with back pain Br J Ind Med 1988 Aug 45(8):552 5 2970864
Antti-Poika I, Soini J, Tallroth K, et al Clinical relevance of discography combined with CT scanning. A study of 100 patients J Bone Joint Surg Br 1990 May 72(3):480 5 2140365
Atlas SJ, Deyo RA, Keller RB, et al The Maine Lumbar Spine Study, Part III. 1-year outcomes of surgical and nonsurgical management of lumbar spinal stenosis Spine 1996 Aug 1 21(15):1787 94; discussion 1794-5
Atlas SJ, Keller RB, Robson D, et al Surgical and nonsurgical management of lumbar spinal stenosis Spine 2000 Mar 25(5):556 62 10749631
Bell GR, Rothman RH, Booth RE, et al A study of computer-assisted tomography. II. Comparison of metrizamide myelography and computed tomography in the diagnosis of herniated lumbar disk and spinal stenosis Spine 1984 Sep 9(6):552 6 6495025
Berlemann U, Jeszenszky DJ, Buhler DW, et al The role of lumbar lordosis, vertebral end-plate inclination, disk height, and facet orientation in degenerative spondylolisthesis J Spinal Disord 1999 Feb 12(1):68 73 10078953
Bernard TN, Yong-Hing K. Surgical management. In: Managing low back pain. 4th ed. Philadelphia (PA): Churchill Livingstone; p. 390-419.
Boden SD, Davis DO, Dina TS, et al Abnormal magnetic-resonance scans of the lumbar spine in asymptomatic subjects. A prospective investigation J Bone Joint Surg Am 1990 Mar 72(3):403 8 2312537
Borenstein DG Chronic low back pain Rheum Dis Clin North Am 1996 Aug 22(3):439 56 8844907
Brewerton DA Degenerative joint disease in the spines of patients with OA hips J Rheumatol 1983 10(Suppl 9):34 5
Bridwell KH, Sedgewick TA, O'Brien MF, et al The role of fusion and instrumentation in the treatment of degenerative spondylolisthesis with spinal stenosis J Spinal Disord 1993 Dec 6(6):461 72 8130395
Bueff HU, Van der Reis W Low back pain Prim Care 1996 23(2):345 64 8784936
Carey TS, Garrett J Patterns of ordering diagnostic tests for patients with acute low back pain. The North Carolina Back Pain Project Ann Intern Med 1996 Nov 15 125(10):807 14
Carragee EJ, Kim DH A prospective analysis of magnetic resonance imaging findings in patients with sciatica and lumbar disk herniation. Correlation of outcomes with disk fragment and canal morphology Spine 1997 Jul 15 22(14):1650 60
Cauchoix J, Benoist M, Chassaing V Degenerative spondylolisthesis Clin Orthop 1976 Mar-Apr(115):122 9
Choiniere M, Melzack R, Girard N, et al Comparisons between patients' and nurses' assessment of pain and medication efficacy in severe burn injuries Pain 1990 Feb 40(2):143 52 2308761
Churchill DN, Taylor DW, Shimizu AG, et al Dialyzer re-use--a multiple crossover study with random allocation to order of treatment Nephron 1988 50(4):325 31 3070414
Ciol MA, Deyo RA, Howell E, et al An assessment of surgery for spinal stenosis: time trends, geographic variations, complications, and reoperations J Am Geriatr Soc 1996 Mar 44(3):285 90 8600197
Ciol MA, Deyo RA, Kreuter W, et al Characteristics in Medicare beneficiaries associated with reoperation after lumbar spine surgery Spine 1994 Jun 15 19(12):1329 34
Clark K Significance of the small lumbar spinal canal: cauda equina compression syndromes due to spondylosis. 2. Clinical and surgical significance J Neurosurg 1969 Nov 31(5):495 8 5351759
Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. New York: Academic Press; 1988. 567 p.
Colditz GA, Miller JN, Mosteller F How study design affects outcomes in comparisons of therapy. I: medical Stat Med 1989 8(4):441 454 2727468
Crosby DL, Brant-Zawadzki M. Imaging of spine trauma. In: Textbook of diagnostic imaging. 2nd ed. Vol. 1. Philadelphia (PA): WB Saunders Company; 1994. p. 332-53.
Crouzet G, Vasdev A, Chirossel JP Computerized tomography in lumbosciaticas of degenerative origin (disk hernia, lumbar arthrosis, narrow lumbar canal). Diagnostic value and radiosurgical correlations J Neuroradiol 1983 10(4):325 44 6229611
Cuckler JM, Bernini PA, Wiesel SW, et al The use of epidural steroids in the treatment of lumbar radicular pain. A prospective, randomized, double-blind study J Bone Joint Surg Am 1985 Jan 67(1):63 6 3155742
Daniel M, Long C, Murphy W, et al Therapists' and chronic pain patients' perceptions of treatment outcome J Nerv Ment Dis 1983 Dec 171(12):729 33 6644281
Davis H Increasing rates of cervical and lumbar spine surgery in the United States, 1979-1990 Spine 1994 May 15 19(10):1117 23; discussion 1123 8059266
Dawson E, Bernbeck J The surgical treatment of low back pain Phys Med Rehabil Clin N Am 1998 May 9(2):489 95, ff 9894129
De Haan JA, Eward AM. Practice variation in the use of lumbar myelograms for routine evaluation of lower back pain and sciatica. In: Issues and answers for improving health in the 21st century. Washington (DC): AHSR; 1997. p. 267.
Deyo RA, Diehl AK, Rosenthal M Reducing roentgenography use. Can patient expectations be altered? Arch Intern Med 1987 Jan 147(1):141 5 2948466
Deyo RA, Tsui-Wu YJ Descriptive epidemiology of low-back pain and its related medical care in the United States Spine 1987 Apr 12(3):264 8 2954221
Djukic S, Vahlensieck M, Resendes M, et al The lumbar spine: postoperative magnetic resonance imaging Bildgebung 1992 Sep 59(3):136 46 1421998
Downing MN, Schnitzlein NH, Clarke LP, et al Magnetic resonance imaging of the lumbar spine Rev Interam Radiol 1986 11(4):127 32
Drinkall JN, Porter RW, Hibbert CS, et al Value of ultrasonic measurement of spinal canal diameter in general practice Br Med J (Clin Res Ed) 1984 Jan 14 288(6411):121 2
Dullerud R, Johansen JG CT-diskography in patients with sciatica. Comparison with plain CT and MR imaging Acta Radiol 1995 Sep 36(5):497 504 7640094
DuPriest CM Nonoperative management of lumbar spinal stenosis J Manipulative Physiol Ther 1993 Jul-Aug 16(6):411 4 8409789
Eberhardt KE, Hollenbach HP, Tomandl B, et al Three-dimensional MR myelography of the lumbar spine: comparative case study to X-ray myelography Eur Radiol 1997 7(5):737 42 9166575
ECRI. Scanning systems, computed tomography, full-body. Plymouth Meeting (PA): ECRI; 1999 Aug. 17 p. (Healthcare product comparison system; no. 08/99).
Eisenberg RL, Margulis AR. Herniated nucleus pulposus. In: What To Order When. Pocket Guide to Diagnostic Imaging. 2nd ed. Philadelphia (PA): Lippincott Williams & Wilkins; 2000 Jan. p. 288-9.
Eisenberg RL, Margulis AR. Spinal stenosis. In: What To Order When. Pocket Guide to Diagnostic Imaging. 2^nd^ ed. Philadelphia (PA): Lippincott Williams & Wilkins; 2000 Jan. p. 292-3.
Eisenstein S The trefoil configuration of the lumbar vertebral canal. A study of South African skeletal material J Bone Joint Surg Br 1980 Feb 62-B(1):73 7 7351439
Elkayam O, Avrahami E, Yaron M The lack of prognostic value of computerized tomography imaging examinations in patients with chronic non progressive back pain Rheumatol Int 1996 16(1):19 21 8783418
Engel CC, von Korff M, Katon WJ Back pain in primary care: predictors of high health-care costs Pain 1996 May-Jun 65(2-3):197 204 8826507
Epstein JA, Epstein BS, Lavine L. Nerve root compression associated with narrowing of the lumbar spinal canal. J Neurol Neurosurg Psychiatry. 1962;25:165-76. [pmid: 13890425].
Eskola A, Pohjolainen T, Alaranta H, et al Calcitonin treatment in lumbar spinal stenosis: a randomized, placebo- controlled, double-blind, cross-over study with one-year followup Calcif Tissue Int 1992 May 50(5):400 3 1596776
Fanuele JC, Birkmeyer NJ, Abdu WA, et al The impact of spinal problems on the health status of patients: have We underestimated the effect? Spine 2000 Jun 15 25(12):1509 14
Fast A, Greenbaum M Degenerative lumbar spinal stenosis Phys Med Rehabil St Art Rev 1995 Oct 9(3):673 82
Firooznia H, Benjamin V, Kricheff II, et al CT of lumbar spine disk herniation: correlation with surgical findings Am J Roentgenol 1984 142(3):587 92 6607651
Fischgrund JS, Mackay M, Herkowitz HN, et al 1997 Volvo Award winner in clinical studies. Degenerative lumbar spondylolisthesis with spinal stenosis: a prospective, randomized study comparing decompressive laminectomy and arthrodesis with and without spinal instrumentation Spine 1997 Dec 15 22(24):2807 12
Fitzgerald J, Newman P Degenerative sponsylolisthesis J Bone Joint Surg Br 1976 58(2):184 92 932080
Fontaine S, Lee D, Maloney W, et al. CAR standards and guidelines for myelography. [article online]. 1996 Jun [cited 2000 May 04]. [8 p]. Available: http://car.ca/standards/myelography.htm.
Fredrickson BE. Pedicular fixation in lumbar stenosis. In: Lumbar Spinal Stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 2000. p. 241-57.
Friberg O Functional radiography of the lumbar spine Ann Med 1989 Oct 21(5):341 6 2532523
Fritz JM, Delitto A, Welch WC, et al Lumbar spinal stenosis: a review of current concepts in evaluation, management, and outcome measurements Arch Phys Med Rehabil 1998 Jun 79(6):700 8 9630153
Fritz JM, Erhard RE, Delitto A, et al Preliminary results of the use of a two-stage treadmill test as a clinical diagnostic tool in the differential diagnosis of lumbar spinal stenosis J Spinal Disord 1997 Oct 10(5):410 6 9355058
Frymoyer JW, Newberg A, Pope MH, et al Spine radiographs in patients with low-back pain. An epidemiological study in men J Bone Joint Surg Am 1984 Sep 66(7):1048 55 6237110
Fukusaki M, Kobayashi I, Hara T, et al Symptoms of spinal stenosis do not improve after epidural steroid injection Clin J Pain 1998 Jun 14(2):148 51 9647457
Gehweiler Jr JA, Daffner RH Low back pain: the controversy of radiologic evaluation AJR Am J Roentgenol 1983 Jan 140(1):109 12 6217731
Gibson JN, Grant IC, Waddell G The Cochrane review of surgery for lumbar disk prolapse and degenerative lumbar spondylosis Spine 1999 Sep 1 24(17):1820 32
Grob D, Humke T, Dvorak J Degenerative lumbar spinal stenosis. Decompression with and without arthrodesis J Bone Joint Surg Am 1995 Jul 77(7):1036 41 7608225
Cost-Effective Diagnostic Imaging: The Clinician's Guide. 3rd ed. St Louis (MO): Mosby - Year Book, Inc.; 1994 Nov; Low back pain. p. 311-9.
Gundry CR, Heithoff KB. Lumbar spine imaging. In: Managing low back pain. 4th ed. Philadelphia (PA): Churchill Livingstone; 1999. p. 176-205.
Gunzburg R, Servais F, Verhas M Tomoscintigraphy of the lumbar spine: prospects and clinical application Eur Spine J 1994 3(6):308 11 7866858
Gunzburg R, Szpalski M, editor (s). Lumbar spinal stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 1999. 352 p.
Hamanishi C, Matukura N, Fujita M, et al Cross-sectional area of the stenotic lumbar dural tube measured from the transverse views of magnetic resonance imaging J Spinal Disord 1994 Oct 7(5):388 93 7819638
Hanakita J, Suwa H, MIzuno M Surgical treatment of lumbar canal stenosis in the elderly Neurol Med Chir (Tokyo) 1999 Jul 39(7):519 22; discussion 522-3 358319 10437380
Hart LG, Deyo RA, Cherkin DC Physician office visits for low back pain. Frequency, clinical evaluation, and treatment patterns from a U.S. national survey Spine 1995 Jan 1 20(1):11 9
Hasselblad V, Hedges LV Meta-analysis of screening and diagnostic tests Psychol Bull 1995 Jan 117(1):167 78 7870860
Annual physician fee schedule payment amount file. Calendar year 1999. [dataset online]. Baltimore (MD): Department of Health and Human Services; 1999 [cited 2000 Feb 29]. Available: http://www.hcfa.gov/stats/pufiles.htm#carrpuf.
Medical Provider Analysis and Review (MEDPAR) [dataset online]. [cited 2000 Mar 13]. Available: http:www.hcfa.gov/stats/medpar/medpar.htm.
Healy JF, Healy BB, Wong WH, et al Cervical and lumbar MRI in asymptomatic older male lifelong athletes: frequency of degenerative findings J Comput Assist Tomogr 1996 Jan-Feb 20(1):107 12 8576458
Hedges LV, Olkin I. Statistical methods for meta-analysis. Boston (MA): Academic Press, Inc.; 1985. 369 p.
Heliovaara M, Vanharanta H, Korpi J, et al Herniated lumbar disk syndrome and vertebral canals Spine 1986 Jun 11(5):433 5 2944229
Herkowitz HN Spine update. Degenerative lumbar spondylolisthesis Spine 1995 May 1 20(9):1084 90 7631240
Herkowitz HN, Abrahan DJ, Fischgrund JS. The diagnosis and management of degenerative lumbar spondylolisthesis. In: CBS Healthwatch [online]. Medscape, Inc.; 1998. [11 p.]. Available: http://www.healthwatch.medscape.com/medscape/p/Library/Library_print.asp?RecID=1522.
Herkowitz HN, Kurz LT Degenerative lumbar spondylolisthesis with spinal stenosis: a prospective study comparing decompression with decompression and intertransverse process arthrodesis J Bone Joint Surg Am 1991 Jul 73(6):802 8 2071615
Herno A, Airaksinen O, Saari T, et al Lumbar spinal stenosis: a matched-pair study of operated and non operated patients Br J Neurosurg 1996 Oct 10(5):461 5 8922704
Herno A, Partanen K, Talaslahti T, et al Long-term clinical and magnetic resonance imaging followup assessment of patients with lumbar spinal stenosis after laminectomy Spine 1999 Aug 1 24(15):1533 7
Herno A, Saari T, Suomalainen O, et al The degree of decompressive relief and its relation to clinical outcome in patients undergoing surgery for lumbar spinal stenosis Spine 1999 May 15 24(10):1010 4
Hindmarsh T, Ekholm SE, Kido DK, et al Lumbar myelography with iohexol and metrizamide. A double-blind clinical trial Acta Radiol Diagn (Stockh) 1984 25(5):365 8 6507131
Hirsch C Etiology and pathogenesis of low back pain Isr J Med Sci 1966 May-Jun 2(3):362 70 4224849
Hultman G, Saraste H, Ohlsen H Anthropometry, spinal canal width, and flexibility of the spine and hamstring muscles in 45-55-year-old men with and without low back pain J Spinal Disord 1992 Sep 5(3):245 53 1387820
Hurri H, Slatis P, Soini J, et al Lumbar spinal stenosis: assessment of long-term outcome 12 years after operative and conservative treatment J Spinal Disord 1998 Apr 11(2):110 5 9588466
Inufusa A, An HS, Lim TH, et al Anatomic changes of the spinal canal and intervertebral foramen associated with flexion-extension movement Spine 1996 Nov 1 21(21):2412 20
Jalovaara P, Lahde P, Iikko E, et al. The significance of residual stenosis after decompression for lumbar spinal stenosis. Ann Chir Gynaecol. 1989;78:304-8. [pmid: 2624404].
Jane JA Sr, Jane JA Jr, Helm GA, et al. Acquired lumbar spinal stenosis. Clin Neurosurg. 1996;43:275-99. [pmid: 9247811].
Jarvik JG, Deyo RA, Koepsell TD Screening magnetic resonance images versus plain films for low back pain: a randomized trial of effects on patient outcomes Acad Radiol 1996 Apr 3Suppl 1:S28 31 8796503
Jarvik JG, Robertson WD, Wessbecher F, et al Variation in the quality of lumbar spin MR images in Washington state Radiology 2000 May 215(2):483 90 10796929
Javid MJ, Hadar EJ Long-term followup review of patients who underwent laminectomy for lumbar stenosis: a prospective study J Neurosurg 1998 Jul 89(1):1 7 9647165
Jenis LG, An HS Spine update. Lumbar foraminal stenosis Spine 2000 Feb 1 25(3):389 94
Jensen MC, Brant-Zawadzki MN, Obuchowski N, et al Magnetic resonance imaging of the lumbar spine in people without back pain N Engl J Med 1994 Jul 14 331(2):69 73
Jinkins JR Gd-DTPA enhanced MR of the lumbar spinal canal in patients with claudication J Comput Assist Tomogr 1993 Jul-Aug 17(4):555 62 8331225
Johnsson K Lumbar spinal stenosis: a retrospective study of 163 cases in southern Sweden Acta Orthop Scand 1995 Oct 66(5):403 5 7484117
Johnsson KE, Uden A, Rosen I The effect of decompression on the natural course of spinal stenosis. A comparison of surgically treated and untreated patients Spine 1991 Jun 16(6):615 9 1862399
Johnsson KE, Uden A, Rosen I. The natural course of lumbar spinal stenosis. Clin Orthop. 1992;279.
Johnsson KE, Willner S, Pettersson H Analysis of operated cases with lumbar spinal stenosis Acta Orthop Scand 1981 52(4):427 33 7315234
Jones RA, Thomson JL. The narrow lumbar canal. J Bone Joint Surg Br. 1968;50:595-605. [pmid: 4235811].
Jonsson B, Annertz M, Sjoberg C, et al A prospective and consecutive study of surgically treated lumbar spinal stenosis. Part II: Five-year followup by an independent observer Spine 1997 Dec 15 22(24):2938 44
Karantanas AH, Zibis AH, Papaliaga M, et al Dimensions of the lumbar spinal canal: variations and correlations with somatometric parameters using CT Eur Radiol 1998 8(9):1581 5 9866765
Katz JN, Dalgas M, Stucki G, et al Degenerative lumbar spinal stenosis. Diagnostic value of the history and physical examination Arthritis Rheum 1995 Sep 38(9):1236 41 7575718
Katz JN, Lipson SJ, Lew RA, et al Lumbar laminectomy alone or with instrumented or noninstrumented arthrodesis in degenerative lumbar spinal stenosis. Patient selection, costs, and surgical outcomes Spine 1997 May 15 22(10):1123 31
Katz JN, Stucki G, Lipson SJ, et al Predictors of surgical outcome in degenertive lumbar spinal stenosis Spine 1999 24(21):2229 33 10562989
Kauppila LI, Eustace S, Kiel DP, et al Degenerative displacement of lumbar vertebrae. A 25-year followup study in Framingham Spine 1998 Sep 1 23(17):1868 73; discussion 1873
Kawauchi Y, Yone K, Sakou T Myeloscopic observation of adhesive arachnoiditis in patients with lumbar spinal canal stenosis Spinal Cord 1996 Jul 34(7):403 10 8963995
Kent DL, Haynor DR, Larson EB, et al Diagnosis of lumbar spinal stenosis in adults: a metaanalysis of the accuracy of CT, MR, and myelography AJR Am J Roentgenol 1992 May 158(5):1135 44 1533084
Khandelwal N, Takhtani D, Malik N, et al CT in nonvisualised vertebral levels caudal to the complete block on lumbar myelogram Neurol India 1996 44(2):59 62
Kikuchi S, Hasue M, Nishiyama K, et al Anatomic and clinical studies of radicular symptoms Spine 1984 Jan-Feb 9(1):23 30 6719254
Kim NH, Lee JW The relationship between isthmic and degenerative spondylolisthesis and the configuration of the lamina and facet joints Eur Spine J 1995 4(3):139 44 7552647
Kirkaldy-Willis WH, Bernard TN Jr, editor (s). Managing low back pain. 4th ed. Philadelphia (PA): Churchill Livingstone; 1999. 434 p.
Kirkaldy-Willis WH, Bernard TN Jr. Making a specific diagnosis. In: Managing Low Back Pain. 4th ed. Philadelphia (PA): Churchill Livingstone; 1999. p. 206-26.
Kirkaldy-Willis WH, Wedge JH, Yong-Hing K, et al Lumbar spinal nerve lateral entrapment Clin Orthop 1982 Sep(169):171 8
Kleeman TJ, Hiscoe AC, Berg EE Patient outcomes after minimally destabilizing lumbar stenosis decompression Spine 2000 25(7):865 870 10751299
Kuroki H, Tajima N, Hirakawa S, et al Comparative study of MR myelography and conventional myelography in the diagnosis of lumbar spinal diseases J Spinal Disord 1998 11(6):487 92 9884292
LaRocca H, Macnab I. Value of pre-employment radiographic assessment of the lumbar spine. Can Med Assoc J. 1969;101:383-8.
Lawrence JS Disk degeneration. Its frequency and relationship to symptoms Ann Rheum Dis 1969 Mar 28(2):121 38 4237972 1031120
Lazennec JY, Ramare S, Arafati N, et al. Importance of sagittal adjustment in lumbosacral fusion. In: Lumbar Spinal Stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 1999. p. 329-44.
Lee CK, deBari A Lumbosacral spinal fusion with Knodt distraction rods Spine 1986 May 11(4):373 5 3750071
Lombardi JS, Wiltse LL, Reynolds J, et al Treatment of degenerative spondylolisthesis Spine 1985 Nov 10(9):821 7 4089657
Long DM, BenDebba M, Torgerson WS, et al Persistent back pain and sciatica in the United States: patient characteristics J Spinal Disord 1996 Feb 9(1):40 58 8727456
Lusins JO, Elting JJ, Cicoria AD, et al SPECT evaluation of lumbar spondylolysis and spondylolisthesis Spine 1994 Mar 1 19(5):608 12
Macdonald EB, Porter R, Hibbert C, et al The relationship between spinal canal diameter and back pain in coal miners. Ultrasonic measurement as a screening test? J Occup Med 1984 Jan 26(1):23 8 6229615
MacGibbon B, Farfan HF A radiologic survey of various configurations of the lumbar spine Spine 1979 May-Jun 4(3):258 66 472898
MacNab I. Backache. Baltimore (MD): Williams and Wilkins; 1977. 235 p.
Magora A, Schwartz A. Relation between the low back pain and x-ray findings. Degenerative osteoarthritis. Scand J Rehabil Med. 1978;8:115-25.
Maher CO, Henderson FC Lateral exit-zone stenosis and lumbar radiculopathy J Neurosurg 1999 Jan 90(1 Suppl):52 8 10413126
Malter AD, McNeney B, Loeser JD, et al 5-year reoperation rates after different types of lumbar spine surgery Spine 1998 Apr 1 23(7):814 20
Mardjetko SM, Connolly PJ, Shott S Degenerative lumbar spondylolisthesis. A meta-analysis of literature 1970-1993 Spine 1994 Oct 15 19(20 Suppl):2256S 2265S
Mariconda M, Zanforlino G, Celestino GA, et al Factors influencing the outcome of degenerative lumbar spinal stenosis J Spinal Disord 2000 Apr 13(2):131 7 10780688
McCowan PR, Bowden SD, Weisel SW Conservative therapy for spinal stenosis Semin Spine Surg 1989 1(3):155 62
McCullen GM, Bernini PM, Bernstein SH, et al Clinical and roentgenographic results of decompression for lumbar spinal stenosis J Spinal Disord 1994 Oct 7(5):380 7 7819637
McCutcheon ME, Thompson WC 3d CT scanning of lumbar discography. A useful diagnostic adjunct Spine 1986 Apr 11(3):257 9 2940710
McLaren AC, Bailey SI. Cauda equina syndrome: a complication of lumbar discectomy. Clin Orthop. 1986 Mar;204:143-9. [pmid: 3956005].
Medical Cost and Quality Assistance (MECQA) [database online]. [cited 1999 Nov 13]. Available: http://www.mecqa.com.
Mikhael MA, Ciric I, Tarkington JA, et al Neuroradiological evaluation of lateral recess syndrome Radiology 1981 Jul 140(1):97 107 7244248
Mirkovic S, Garfin SR, Rydevik B, et al. Pathophysiology of spinal stenosis. Instr Course Lect. 1992;41:165-77. [pmid: 1588061].
Mitchell GE. (Radiology Department; Crouse Irving Memorial Hospital). Personal communication. 1 p.
Modic MT, Masaryk T, Boumphrey F, et al Lumbar herniated disk disease and canal stenosis: prospective evaluation by surface coil MR, CT, and myelography AJR Am J Roentgenol 1986 Oct 147(4):757 65 3489378
Modic MT, Ross JS, Obuchowski NA, et al Contrast-enhanced MR imaging in acute lumbar radiculopathy: a pilot study of the natural history Radiology 1995 May 195(2):429 35 7724762
Morris EW, Di Paola M, Vallance R, et al Diagnosis and decision making in lumbar disk prolapse and nerve entrapment Spine 1986 Jun 11(5):436 9 3750080
Muto M, De Maria G, Izzo R, et al Nondiscal lumbar radiculopathy: Combined diagnostic approach by CT and MR Riv Neuroradiol 1997 10(2):165 73
Nagler W, Bodack MP. Management options in lumbar spinal stenosis. In: Ernst E, Jayson MI, Pope MH, editor (s). Advances in idiopathic low back pain. Vienna: Blackwell-MZV; 1993. p. 292-7.
Nagler W, Hausen HS Conservative management of lumbar spinal stenosis. Identifying patients likely to do well without surgery Postgrad Med 1998 Apr 103(4):69 71, 76, 81-3 passim 9553588
Nelson BW, Carpenter DM, Dreisinger TE, et al Can spinal surgery be prevented by aggressive strengthening exercises? A prospective study of cervical and lumbar patients Arch Phys Med Rehabil 1999 80(1):20 5 9915367
Newman PH Stenosis of the lumbar spine in spondylolisthesis Clin Orthop 1976(115):116 21
Niggemeyer O, Strauss JM, Schulitz KP Comparison of surgical procedures for degenerative lumbar spinal stenosis: a meta-analysis of the literature from 1975 to 1995 Eur Spine J 1997 6(6):423 9 9455673
Nishizawa T, Fujimura Y A clinical study of anterior lumbar interbody fusion for degenerative spondylolisthesis J Orthop Surg 1997 5(1):21 7
Omojola MF, Vas W, Banna M Plain film assessment of spinal canal stenosis Can Assoc Radiol J 1981 32(2):95 6
Onel D, Sari H, Donmez C Lumbar spinal stenosis: clinical/radiologic therapeutic evaluation in 145 patients. Conservative treatment or surgical intervention? Spine 1993 Feb 18(2):291 8 8441947
Osborn RE, Knight JA Retrospective comparison of computed tomography and myelography of the lumbar spine: a study of 37 patients with surgical correlation J Am Osteopath Assoc 1986 86(6):350 4 3733481
Pai VS Ultrasound measurement of the lumbar spinal canal J Orthop Surg 1993 1(1):103 6
Paine KW Results of decompression for lumbar spinal stenosis Clin Orthop 1976 Mar-Apr(115):96 100
Palumbo MA, Lucas P, Akelman E Lumbar spinal stenosis: a review R I Med J 1995 Nov 78(11):321 3
Panjabi MM, Duranceau J, Goel V, et al Cervical human vertebrae. Quantitative three-dimensional anatomy of the middle and lower regions Spine 1991 Aug 16(8):861 9 1948369
Parkkola R, Rytokoski U, Kormano M Magnetic resonance imaging of the disks and trunk muscles in patients with chronic low back pain and healthy control subjects Spine 1993 Jun 1 18(7):830 6
Phillips RB, Howe JW, Bustin G, et al Stress X-rays and the low back pain patient J Manipulative Physiol Ther 1990 Mar-Apr 13(3):127 33 2140121
Plotz GM, Benini A Lumbar degenerative spondylolisthesis: Review of 106 operated cases with degenerative anterior vertebral translation as the predominant aspect of the spondylosis Neurosurg Q 1998 8(4):271 87
Porchet F, Vader JP, Larequi-Lauber T, et al The assessment of appropriate indications for laminectomy J Bone Joint Surg Br 1999 Mar 81B(2):234 9 10204927
Porter RW, Ward D Cauda equina dysfunction. The significance of two-level pathology Spine 1992 Jan 17(1):9 15 1536018
Lumbar spinal stenosis. New York (NY): Springer-Verlag; 1988. 173-218 p.
Postacchini F Management of lumbar spinal stenosis J Bone Joint Surg Br 1996 Jan 78(1):154 64 8898152
Postacchini F Surgical management of lumbar spinal stenosis Spine 1999 May 15 24(10):1043 7 10332799
Postacchini F, Perugia D Degenerative lumbar spondylolisthesis. Part I: Etiology, pathogenesis, pathomorphology, and clinical features Ital J Orthop Traumatol 1991 Jun 17(2):165 73 1839154
Postacchini F, Pezzeri G CT scanning versus myelography in the diagnosis of lumbar stenosis. A preliminary report Int Orthop 1981 5(3):209 15 7338429
Postacchini F, Pezzeri G, Montanaro A, et al Computerized tomography in lumbar stenosis. A preliminary report J Bone Joint Surg Br 1980 Feb 62-B(1):78 82 7351440
Postacchini F, Pezzeri G, Montanaro A, et al Computerized tomography in lumbar stenosis: a preliminary report J Bone Joint Surg Br 1980 62(1):78 82 7351440
Powell MC, Wilson M, Szypryt P, et al Prevalence of lumbar disk degeneration observed by magnetic resonance in symptomless women Lancet 1986 Dec 13 2(8520):1366 7
Prasartritha T, Suntisathaporn N, Vathana P, et al The size of the vertebral canal and the significance of epidural fat in lumbar spinal stenosis J Med Assoc Thai 1997 Apr 80(4):247 56 9175394
Prescher A Anatomy and pathology of the aging spine Eur J Radiol 1998 27(3):181 95 9717634
Ramani PS The relationship of the size of the lumbar spinal canal to the symptomatology of prolapsed lumbar intervertebral disks J Neurosurg Sci 1974 Oct-Dec 18(4):223 7 4468282
Ramani PS Variations in size of the bony lumbar canal in patients with prolapse of lumbar intervertebral disks Clin Radiol 1976 Jul 27(3):301 7 135669
Ramsbacher J, Schilling AM, Wolf KJ, et al Magnetic resonance myelography (MRM) as a spinal examination technique Acta Neurochir (Wien) 1997 139(11):1080 4 300905 9442224
Rankine JJ, Gill KP, Hutchinson CE, et al The therapeutic impact of lumbar spine MRI on patients with low back and leg pain Clin Radiol 1998 53(9):688 93 9766723
Ray CD New techniques for decompression of lumbar spinal stenosis Neurosurgery 1982 May 10(5):587 92 6212772
Rompe JD, Eysel P, Hopf CH, et al Surgical management of central lumbar spinal stenosis - results with decompressive laminectomy only and with concomitant instrumented fusion with the Cotrel-Dubousset-Instrumentation Neuro-Orthopedics 1995 19(1):17 31
Rosenberg NJ Degenerative spondylolisthesis. Predisposing factors J Bone Joint Surg Am 1975 Jun 57(4):467 74 1141255
Rosenberg NJ. Degenerative spondylolisthesis surgical treatment. Clin Orthop. 1976;117:112-20. [pmid: 132322].
Rosenthal R. Meta-analytic procedures for social research. Rev ed. Newbury Park (CA): Sage Publications; 1991. 155 p. (Applied social research methods series; no. 6).
Rosenthal R, Rosnow RL. Essentials of behavioral research: methods and data analysis. New York: McGraw-Hill; 1991. 692 p.
Rowe ML. Low back pain in industry. J Occup Med. 1969;11:161-9. [pmid: 4238904].
Sackett JF. Degenerative change of spinal column causing neurologic deficit. In: Textbook of diagnostic imaging. 2nd ed. Vol. 1. Philadelphia (PA): WB Saunders Company; 1994. p. 322-32.
Sacks H, Chalmers TC, Smith H Randomized versus historical controls for clinical trials Am J Med 1982 72(2):233 40 7058834
Sandhu HS, Lakhanpal VP, Gupta SC Incidence of lumbar spinal canal stenosis in cases of low back ache beyond the age of 35 years: radiographic study Indian J Orthop 1976 10(2):71 7
Sato K, Kikuchi S Clinical analysis of two-level compression of the cauda equina and the nerve roots in lumbar spinal canal stenosis Spine 1997 Aug 15 22(16):1898 903; discussion 1904
Satomi K, Hirabayashi K, Toyama Y, et al A clinical study of degenerative spondylolisthesis. Radiographic analysis and choice of treatment Spine 1992 Nov 17(11):1329 36 1462209
Scafuri RL, Weinstein JN Lumbar spinal stenosis: a prospective review of evaluation and treatment utilizing a new 'back analysis form' Proc Inst Med Chic 1981 Jul-Sep 34(3):79 82 7301825
Schatzker J, Pennal GF Spinal stenosis, a cause of cauda equina compression J Bone Joint Surg Br 1968 Aug 50(3):606 18 4235812
Schonstrom NS, Bolender NF, Spengler DM The pathomorphology of spinal stenosis as seen on CT scans of the lumbar spine Spine 1985 Nov 10(9):806 11 4089655
Schrader PK, Grob D, Rahn BA, et al Histology of the ligamentum flavum in patients with degenerative lumbar spinal stenosis Eur Spine J 1999 Aug 8(4):323 8 10483836
Shakil MS, Vaccaro AR, Albert TJ, et al Efficacy of conservative treatment of lumbar spinal stenosis Semin Spine Surg 1999 11(3):229 33
Shapiro S Medical realities of cauda equina syndrome secondary to lumbar disk herniation Spine 2000 Feb 1 25(3):348 51; discussion 352 10703108
Shapiro S, Cooper PR, Miller CA Cauda equina syndrome secondary to lumbar disk herniation Neurosurgery 1993 32(5):743 7 8492849
Shekelle PG, Markovich M, Louie R Comparing the costs between provider types of episodes of back pain care Spine 1995 Jan 15 20(2):221 6; discussion 227
Shenkin HA, Hash CJ A new approach to the surgical treatment of lumbar spondylosis J Neurosurg 1976 Feb 44(2):148 55 128620
Shiroky JB, Salanga VD, Ropos TJ Spinal stenosis: making the diagnosis, offering relief [corrected] J Musculoskeletal Med 1996 Aug 13(8):46 8, 51-2, 57-8
Silvers HR, Lewis PJ, Asch HL Decompressive lumbar laminectomy for spinal stenosis J Neurosurg 1993 May 78(5):695 701 8468598
Simmons Jr ED, Simmons EH Spinal stenosis with scoliosis Spine 1992 17(6 Suppl):S117 20 1631710
Simotas AC, Dorey FJ, Hansraj KK, et al Nonoperative treatment for lumbar spinal stenosis. Clinical and outcome results and a 3-year survivorship analysis Spine 2000 25(2):197 204 10685483
Sinaki M, Lutness MP, Ilstrup DM, et al Lumbar spondylolisthesis: retrospective comparison and three-year followup of two conservative treatment programs Arch Phys Med Rehabil 1989 Aug 70(8):594 8 2527488
Spengler DM. Current trends in surgery for patients with lumbar spinal stenosis of the degenerative variety. In: Lumbar Spinal Stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 2000. p. 233-40.
Spivak JM Degenerative lumbar spinal stenosis J Bone Joint Surg Am 1998 Jul 80(7):1053 66 9698011
Splithoff CA. Lumbosacral junction. Roentgenographic comparison of patients with and without backaches. JAMA. 1953;152:1610-3.
Stanley D, McLaren MI, Euinton HA, et al A prospective study of nerve root infiltration in the diagnosis of sciatica. A comparison with radiculography, computed tomography, and operative findings Spine 1990 Jun 15(6):540 3 2402693
Stockley I, Getty CJ, Dixon AK, et al Lumbar lateral canal entrapment: clinical, radiculographic and computed tomographic findings Clin Radiol 1988 Mar 39(2):144 9 3356095
Surin V, Hedelin E, Smith L. Degenerative lumbar spinal stenosis: results of operative treatment. Acta Orthop Scand. 1982;53:79-85. [pmid: 6461161].
Swezey RL Outcomes for lumbar stenosis: a 5-year followup study J Clin Rheumatol 1996 2(3):129 34 19078047
Symmons DP, van Hemert AM, Vandenbroucke JP, et al A longitudinal study of back pain and radiological changes in the lumbar spines of middle aged women. II. Radiographic findings Ann Rheum Dis 1991 Mar 50(3):162 6 1826598 1004366
Tait WF, Charlesworth D, Lemon JG Atypical claudication Br J Surg 1985 Apr 72(4):315 6 3986488
Tajima N, Fukazawa T, Ishio M, et al The ligamentum flavum in lumbar spinal canal stenosis Acta Med Nagasaki 1980 25(1-4):16 28
Tallroth K, Ylikoski M, Landtman M, et al Reliability of radiographical measurements of spondylolisthesis and extension-flexion radiographs of the lumbar spine Eur J Radiol 1994 Aug 18(3):227 31 7957297
Tan JC, Roux EB, Dunand J, et al Role of physical therapy in the management of common low back pain Baillieres Clin Rheumatol 1992 Oct 6(3):629 55 1477895
Tatarek, Nancy Elizabeth. Changing views of health: spinal stenosis and its impact on well-being in skeletal biology. Diss Abstr Int 60-08 (A):2999.
Tenhula J, Lenke LG, Bridwell KH, et al Prospective functional evaluation of the surgical treatment of neurogenic claudication in patients with lumbar spinal stenosis J Spinal Disord 2000 13(4):276 82 10941885
Terenzi TJ, Beadle E, Muller D, et al Doppler ultrasound diastolic flow analysis for the early identification of peripheral arterial disease J Manipulative Physiol Ther 1992 Jun 15(5):286 92 1613410
Thomas NW, Rea GL, Pikul BK, et al Quantitative outcome and radiographic comparisons between laminectomy and laminotomy in the treatment of acquired lumbar stenosis Neurosurgery 1997 Sep 41(3):567 74; discussion 574-5 9310973
Thomsen K, Christensen FB, Eiskjaer SP, et al 1997 Volvo Award winner in clinical studies. The effect of pedicle screw instrumentation on functional outcome and fusion rates in posterolateral lumbar spinal fusion: a prospective, randomized clinical study Spine 1997 Dec 15 22(24):2813 22
Torgerson WS. Theory and methods of scaling. New York: John Wiley & Sons, Inc.; 1958. 460 p.
Torgerson WR, Dotter WE Comparative roentgenographic study of the asymptomatic and symptomatic lumbar spine J Bone Joint Surg Am 1976 Sep 58(6):850 3 134040
Turner JA, Ersek M, Herron L, et al Surgery for lumbar spinal stenosis. Attempted meta-analysis of the literature Spine 1992 Jan 17(1):1 8 1531550
Twomey L, Taylor J Age changes in the lumbar spinal and intervertebral canals Paraplegia 1988 Aug 26(4):238 49 3174169
Uden A, Johnsson KE, Jonsson K, et al Myelography in the elderly and the diagnosis of spinal stenosis Spine 1985 Mar 10(2):171 4 4002041
Verbiest H. Results of surgical treatment of idiopathic developmental stenosis of the lumbar vertebral canal: a review of twenty-seven years' experience. J Bone Joint Surg Br. 1977;59:181-8. [pmid: 141452].
Vergauwen S, Parizel PM, van Breusegem L, et al Distribution and incidence of degenerative spine changes in patients with a lumbo-sacral transitional vertebra Eur Spine J 1997 6(3):168 72 9258634
Videman T, Battie MC, Gill K, et al Magnetic resonance imaging findings and their relationships in the thoracic and lumbar spine: insights into the etiopathogenesis of spinal degeneration Spine 1995 20(8):928 35 7644958
Virta L, Ronnemaa T The association of mild-moderate isthmic lumbar spondylolisthesis and low back pain in middle-aged patients is weak and it only occurs in women Spine 1993 Sep 1 18(11):1496 503
Virta L, Ronnemaa T, Laakso M Prevalence of isthmic lumbar spondylolisthesis in nondiabetic subjects and NIDDM patients Diabetes Care 1994 Jun 17(6):592 4 8082530
Visarius H. Concept and clinical aspects of computer assisted spin surgery. In: Lumbar Spinal Stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 2000. p. 345-53.
Waddell G Clinical diagnosis of leg pain and nerve root involvement in low back disorders Acta Orthop Belg 1987 53(2):152 5 2961192
Weiner BK, Walker M, Brower RS Microdecompression for lumbar spinal canal stenosis Spine 1999 24(21):2268 2272 10562995
Widelec J, Bacq C, Peetrons P. Conventional x-rays and computed tomographic scan in lumbar spinal stenosis. In: Lumbar Spinal Stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 1999. p. 91-6.
Wiesel SW, Tsourmas N, Feffer HL, et al A study of computer-assisted tomography. I. The incidence of positive CAT scans in an asymptomatic group of patients Spine 1984 Sep 9(6):549 51 6495024
Willen J, Danielson B, Gaulitz A, et al Dynamic effects on the lumbar spinal canal: Axially loaded CT- myelography and MRI in patients with sciatica and/or neurogenic claudication Spine 1997 22(24):2968 76 9431634
Wilmink JT. Diagnostic imaging in lumbar spinal stenosis: dynamic myelography, computed tomographic myelography, magnetic resonance imaging, and magnetic resonance myelography. In: Lumbar spinal stenosis. Hagerstown (MD): Lippincott Williams & Wilkins; 2000. p. 97-107.
Wiltse LL Surgery for intervertebral disk disease of the lumbar spine Clin Orthop 1977 Nov-Dec(129):22 45
Winston K, Rumbaugh C, Colucci V The vertebral canals in lumbar disk disease Spine 1984 May-Jun 9(4):414 7 6474255
Wisneski RJ, Farmer JC Decompressive surgery for lumbar spinal stenosis Semin Spine Surg 1994 6(2):116 23
Wood KB, Popp CA, Transfeldt EE, et al Radiographic evaluation of instability in spondylolisthesis Spine 1994 Aug 1 19(15):1697 703
Woolsey RM Lumbar spinal stenosis Semin Neurol 1986 Dec 6(4):385 9 3332440
Yone K, Sakou T, Kawauchi Y, et al Indication of fusion for lumbar spinal stenosis in elderly patients and its significance Spine 1996 Jan 15 21(2):242 8
Yoshida M, Shima K, Taniguchi Y, et al Hypertrophied ligamentum flavum in lumbar spinal canal stenosis. Pathogenesis and morphologic and immunohistochemical observation Spine 1992 Nov 17(11):1353 60 1462211
Young S, Veerapen R, O'Laoire SA Relief of lumbar canal stenosis using multilevel subarticular fenestrations as an alternative to wide laminectomy: preliminary report Neurosurgery 1988 Nov 23(5):628 33 3200393
Yuan HA, Garfin SR, Dickman CA, et al A Historical Cohort Study of Pedicle Screw Fixation in Thoracic, Lumbar, and Sacral Spinal Fusions Spine 1994 Oct 15 19(20 Suppl):2279S 2296S
Zdeblick TA The treatment of degenerative lumbar disorders. A critical review of the literature Spine 1995 Dec 15 20(24 Suppl):126S 137S 8747267
Zwarts MJ Magnetic stimulation of the peripheral nervous system: local versus generalized disorders Electromyogr Clin Neurophysiol 1998 Jul-Aug 38(5):309 16 9741010