# Future Research

At least some of the gaps in current research on lumbar spinal stenosis probably arise from the suboptimal designs of the studies that have been conducted to date. In addition, at least some additional gaps likely arise from the manner in which patient characteristics and results are reported, even in well-designed trials. Other gaps seem to result from the somewhat varied patient inclusion criteria used in these studies. The purpose of the present section is to provide evidence supporting these suppositions and to thereby illuminate where these gaps lie.

## Study Design

Well-designed RCTs provide the highest quality of evidence for treatment effectiveness because each treatment arm is composed of comparable patient groups having the same characteristics (e.g., age, gender, extent of disease, capacity to respond to treatment). Nonrandomized trials may result in one treatment arm having patients who can appear to respond better or worse to treatment due to the characteristics of the patient group. Additionally, trials without a control group do not examine the potential for minimal treatment to cause recovery, nor do they allow one to accurately gauge the magnitude of any change that occurs after treatment.

Only four RCTs of conservative treatments for lumbar spinal stenosis were found in our search of the literature. One hundred seventy-eight publications of conservative treatments may have included lumbar spinal stenosis patients. However, most of these trials did not contain a control group or did not make a specific diagnosis of lumbar spinal stenosis using imaging technology (see Table 47).

Table 47. Trial Designs, Number of Patients, and Reporting of Prior Conservative Therapy in Surgical and Conservative Treatment Trials Related to Lumbar Spinal Stenosis

Type of Treatment | Surgery 147 Studies | Conservative 4 Studies
Study Design Randomized controlled trials Controlled trials ^1^ Prospective trials Retrospective with consecutive patients Case series | 7 47 7 28 57 | 4 0 0 0 0
Year of Publication 1960 1970 1980 1990 2000 | 3 17 38 86 3 | 0 0 2 2 0
Number of Patients in All Arms of Trail 10-25 26-50 51-100 >100 | 25 59 41 22 | 0 3 1 0
Months of Nonoperative Therapy Reported Not reported | 15 132 | --- ---

1 A controlled trial is any trial that contains more than one treatment group and is not a randomized controlled trial. These trials may have either a prospective or retrospective design

Of the 253 publications examining surgical treatments for lumbar spinal stenosis, 147 surgical trials met the inclusion criteria for analysis (see Table 47). Of these publications, only seven were RCTs. Within this group, patients with central stenosis or lateral stenosis were examined in one trial each, and degenerative spondylolisthesis was examined in four trials. The seventh trial was the only study to randomize patients with moderate symptoms to either conservative or surgical treatment.

Forty-seven trials contained more than one treatment arm and have been classified as controlled trials. In these studies, the patient groups were usually not matched and received treatment based on the surgeon's judgment of the patient's condition. Nine of these controlled trials had a nonoperated control group. However, the extent of disease in these patients was generally not as severe as that in patients who received surgery.

Ninety-two trials examined only one surgical technique. These trials were separately classified as prospective (7), retrospective with consecutive patients (28), and case series (57, retrospective but did not report examining consecutive patients).

## Reporting of Patient Characteristics, Signs, and Symptoms

Reasonable evidence-based conclusions can sometimes be reached from observational studies. Doing so, however, often requires that the studies under consideration provide detailed descriptions of the enrolled patients. Reporting of patient characteristics, signs, and symptoms is inconsistent among the published trials of both conservative and surgical treatments for lumbar spinal stenosis. Evidence Table 1 for the conservative trials, Evidence Table 2 for the surgical trials, and Evidence Table 3 for the natural history trials present a list of patient information commonly reported in clinical trials of lumbar spinal stenosis. The tables indicate with a Yes or No if the trials reported each item. These patient characteristics, signs, and symptoms may potentially influence the outcome of any treatment regime and could be used in a regression analysis of outcome modifiers. Mean age and duration of illness before treatment is the only patient information reported in all four conservative treatment trials. The presence of neurogenic claudication, back or leg pain, and extent of stenosis are reported in one publication each. Comorbidity such as hip and knee disorders are not reported in any of the four trials (see Figure 24).

Figure 24. Histogram of Number of Trials Reporting Patient Signs, Symptoms, and Other Characteristics in Randomized Controlled Trials of Conservative Treatments

Among the surgical trials, only mean age was reported in more than 80 percent of the publications (see Figure 25). The next most frequently reported patient characteristic was the number of levels surgically involved (54 percent). Neurogenic claudication was reported in 46 percent of trials. Back pain and leg pain were reported in 40 percent of trials and duration of illness before surgery, prior back surgery, leg weakness, and sensory dysfunction were reported in 31 percent to 35 percent of trials. Extent of stenosis and the number of patients with herniated disks were reported in 18 percent of trials. The combination of mean age, number of surgical levels involved, and the presence of neurogenic claudication were reported in 40 trials ( 27 percent of all surgical trials). The addition of reporting back pain dropped the number of trials reporting all four items to 29 (20 percent). Only five trials (3.5 percent) provided information on mean age, surgical levels, neurogenic claudication, back pain, leg pain, duration of illness before surgery, prior back surgery, leg weakness, and sensory dysfunction. The lack of detailed reporting of patient signs and symptoms complicates any attempt at correlating signs and symptoms with the extent of recovery after treatment.

Figure 25. Histogram of Number of Trials Reporting Patient Signs, Symptoms, and Other Characteristics in Trials of Surgical Treatments

## Patient Inclusion Criteri

Lack of detailed reporting of patient characteristics can sometimes be overcome if studies employ rather restrictive patient inclusion criteria. Available information suggests that such criteria were only infrequently applied in studies of lumbar spinal stenosis. Most studies, 125 of the 147 surgical trials (85 percent), enrolled patients of markedly different ages and typically had age ranges of 30 to 80 years.

Figure 26 shows that although the average age of patients in these studies was somewhat similar (most trials were of middle-aged or older patients), there was nevertheless a wide range of mean ages. Among the 125 studies that reported a mean age and age range, the means start at 34 years and go to a high of 85 years. Further, the age variation is even greater within studies. The ranges of individual studies often extended to 30 years on either side of the mean. Granted, ranges and means can be distorted by a few "outliers," but whether these ranges were the result of such outliers could not be determined. This is because published studies typically provide no estimate of the number of patients younger or older than the mean age.

Figure 26. Plot of Mean Ages and Age Ranges from 125 Studies of Lumbar Spinal Stenosis

Several reviews examining the diagnosis and treatment of lumbar spinal stenosis have recommended that a period of conservative therapy be administered before proceeding to surgery (Fritz, Delitto, Welch et al., 1998; Jenis and An, 2000; McCowan, Bowden, and Weisel, 1989; Nagler and Hausen, 1998; Palumbo, Lucas, and Akelman, 1995; Shakil, Vaccaro, Albert et al., 1999; Shiroky, Salanga, and Ropos, 1996; Woolsey, 1986; Zdeblick, 1995). If the conservative therapy fails to improve symptoms and function, then surgery is warranted. Given this recommendation, however, only 15 of the 147 trials of surgical treatments reported that their patients received, and showed no improvement after, a course of conservative treatment. In these 15 studies, the actual amount of prior conservative treatment ranged from as little as 2 weeks to as much as 16 years. Some trials stated that they required an "adequate" period of treatment before surgery but did not define adequate.