# Evidence Tables

Evidence Table 1. Study information: Patients with chest pain suspicious for ischemia

Author, Year | Journal | Location/Setting | N | Inclusion Criteria | Exclusion Criteria
Author, Year | Predictors (clinical, ECG) | Primary Outcome | Secondary Outcomes | Analytical Method
Chin, 1994 | J Gen Intern Med | Multicenter Chest Pain Study Emergency Department Three university hospitals Four community hospitals | 500 | 1/84--8/85 >30 years old Nontraumatic chest pain More than bibasilar rales | None
Cunningham, 1989 | J Gen Intern Med | Multicenter Chest Pain Study Emergency Department Three university hospitals Four community hospitals | 7,734 | 1/84--8/85 >30 years old Nontraumatic chest pain Up to three visits per patient | Insufficient followup in nonadmitted patients
Herlitz, 1997 | Coronary Art Dis | Emergency Department Sahlgrenska University Hospital, Goteborg, Sweden | 5,016 | 2/86--11/87 Acute chest pain | None
Kontos, 1997 | J Am Coll Cardiol | Emergency Department Medical College of Virginia/Virginia Commonwealth University | 532 | 6/94--8/95 "Lower risk" chest pain patients who underwent early rest myocardial perfusion imaging and serial cardiac enzymes | Abnormal ECG Nondiagnostic ECG Known coronary disease "Typical" symptoms
Lee, 1992 | Am J Cardiol | Emergency Department Brigham and Women's Hospital, Boston, MA (one site for Multicenter Chest Pain Center) | 1,915 | 1/84--11/86 >30 years old Nontraumatic chest pain | Nonadmitted patients who refused to consent to return in 48--72 hours for measurement of cardiac enzymes and ECG Admitted patients who died during the index hospitalization
Rude, 1983 | Am J Cardiol | Multicenter Investigation of the Limitation of Infarct Size (MILIS) Five hospitals: Barnes Hospital Brigham & Women's Hospital MGH Medical Center Hospital Parkland Memorial Hospital | 3,697 | >30 min of ischemic chest pain Admitted to CCU | >75 years old Symptom onset >18 hours Cardiogenic shock Pregnant Permanent pacemaker Recent MI or major surgery Terminal diseases Major organ system failure Cardiomyopathy Acute cerebrovascular disease Participating in conflicting protocol Previous participation in MILIS Inability to complete followup
Tierney, 1985 | Crit Care Med | Emergency Department Wishard Memorial Hospital | 540 | 11/82--4/83 Men>30 years old Women>40 years old Chest pain | Prisoners Recent chest trauma Recent history of smoke inhalation or corrosive ingestion Incomplete followup
Villanueva, 1992 | Am J Cardiol | Emergency Department Virginia Medical Center | 265 | Men >30 years old Women >40 years old Chest pain>30 min within 4 hours of presentation No obvious other cause | None
Chin, 1994 | Age, gender, initial SBP, initial DBP, lung/cardiac exam, ST elevation, new Q waves, ST depression, prior MI, prior angina, time since onset of chest pain, longest episode of chest pain, quality of pain, radiation of pain, comparison of pain with prior angina | Death or "major complication" Major complication defined as nonfatal VF, new Mobitz-II heart block, new AV dissociation, cardiogenic shock, cardiac arrest, endotracheal intubation, or intra-aortic balloon pump | Length of stay | Logistic or linear regression
Cunningham, 1989 | Gender | MI | Unstable angina Stable angina Other cardiac condition Noncardiac chest pain | Logistic regression
Herlitz, 1997 | Age, gender, prior MI, angina pectoris, CHF, diabetes, hypertension, current smoking | 5-year mortality | MI | Cox proportional hazards model
Kontos, 1997 | Age, gender, hypertension, diabetes, tobacco use, family history of CDH, Hypercholesterolemia previous MI, symptom duration, positive Sestamibi | During initial evaluation or within 5 days of admission: MI, revascularization, or cardiac death | None | Stepwise logistic regression
Lee, 1992 | Age, gender, history of CAD, ECG changes of ischemia or infarction not known to be old (in the ED), admitted to the hospital, admitted to the CCU, VF, recurrent ischemic pain, infarct extension, shock, PVCs >6/min) inpatient procedures (cardioversion, catherization, CABG, IABP, intubation, thrombolytic therapy) | >12 months after discharge Cardiovascular mortality | None | Stepwise Cox proportional hazards model
Rude, 1983 | Age, gender, race, prior MI, marital status, duration of symptoms, ECG findings | MI | None | Forward stepwise logistic regression
Tierney, 1985 | Age, gender, race, chest pain characteristics, prior MI, prior angina, prior atypical chest pain, hypertension, CHF, diabetes, smoking, heart rate, blood pressure, cyanosis, rales S3, diaphoresis, chest wall tenderness, nausea, dyspnea, respiratory rate, ECG findings | MI | None | Backward elimination logistic regression
Villanueva, 1992 | Age, gender, type of chest pain, history of MI, CVA, revascularization, CHF, smoking, diabetes, hypercholesterolemia, hypertension, family history of coronary disease, BP, pulse, rales, S3, S4, peripheral edema, ECG findings | Cardiovascular mortality | Nonfatal MI, CVA, life-threatening arrhythmia, revascularization, valve surgery | Stepwise Cox proportional hazards model

Evidence Table 2. Multivariate demographic predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | | Age Group (if specified) | Demographic Characteristics
Study Information | | Age Group (if specified) | Age | | Gender | | Race/Ethnicity
Author | Year | Age Group (if specified) | Def'n | Estimate | Male | Estimate | Def'n | Estimate
Chin | 1994 | | > vs <70 y | + | | NS
Cunningham | 1989 | | | | | +
Herlitz ^1^ | 1997 | <50 y 50--75 y >75 y | Per y Per y Per y | NS + + | | NS + +
Kontos | 1997 | | > vs <60 y | NS | | +
Lee | 1992 | | Per 10 y | + | | NS
Rude | 1983 | | Per y | + | | ^2^ | W vs. other | NS
Tierney | 1985 | | Not stated | NS | | NS | Not stated | NS
Villanueva | 1992 | | Per 15 y | + | | NS | Not stated | NS

1 All results adjusted for age, time of chest pain onset, type of pain, location of pain, comparison with prior MI or worsening angina, prior diagnosis of similar pain, blood pressure, chest tenderness, rales, any ECG changes, prior CHD, new ST elevation or depression.

2 Stated that sex was significantly associated with MI rates but did not define sex.

Evidence Table 3[a]. Multivariate medical history predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | Age Group | Past Medical History
Study Information | Age Group | MI | | Unstable Angina | | Stable Angina | | PTCA
Author, Year | Age Group | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Chin, 1994 | | Prior MI dx | NS | | | Angina hx | NS
Cunningham, 1989
Herlitz, 1997 | <50 y 50--75 y >75 y | Prior MI dx Prior MI dx Prior MI dx | NS NS NS | | | Angina hx Angina hx Angina hx | NS NS NS
Kontos, 1997 | | Prior MI dx | NS
Lee, 1992 | | Prior MI or angina hx | ++
Rude, 1983 | | Prior MI dx | NS
Tierney, 1985 | | Prior MI dx | +++ | | | Angina hx | NS
Villanueva, 1992 | | Prior MI dx | NS | | | | | Any revasc | NS

Evidence Table 3[b]. Multivariate medical history predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | Age Group (if specified) | Past Medical History
Author, Year | Age Group (if specified) | CABG | | CHF | | CVA/TIA | | HTN | | Diabetes | | Smoking
Author, Year | Age Group (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Chin, 1994
Cunningham, 1989
Herlitz, 1997 | <50 y 50--75 y >75 y | | | CHF dx CHF dx CHF dx | NS ++ + | | | HTN dx HTN dx HTN dx | +++ + NS | Diabetes dx Diabetes dx Diabetes dx | NS + + | Current smoker Current smoker Current smoker | +++ + NS
Kontos, 1997 | | | | | | | | HTN dx | NS | Diabetes dx | ++ | Hx of tobacco use | NS
Lee, 1992 | | CABG hx | NS
Rude, 1983
Tierney, 1985 | | | | CHF dx | NS | | | HTN dx | NS | Diabetes dx | NS | Smoking hx | NS
Villanueva, 1992 | | Any revasc | NS | CHF dx | NS | CVA dx | NS | HTN dx | NS | Diabetes dx | NS | Smoking hx | NS

Evidence Table 4. Multivariate symptom predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | Age Group (if specified) | Symptom Characteristics
Study Information | Age Group (if specified) | Frequency | | Duration | | Other
Author, Year | Age Group (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Chin, 1994 | | | | >20 min onset <4 h | NS NS | Pressing or crushing Radiation pattern Comparison with prior angina | NS NS NS
Cunningham, 1989
Herlitz, 1997 | >50 y 50--75 y <75 y
Kontos, 1997 | | | | | | Typical angina | ++
Lee, 1992
Rude, 1983 | | | | < vs. >18 h | +
Tierney, 1985 | | | | Duration between onset and ER treatment | NS | Diaphoresis Constant or dull Pressure-like Episodic Sharp or pleuritic Nausea Dyspnea | +++ NS NS NS NS NS NS
Villanueva, 1992 | | | | | | Typical angina | NS

Evidence Table 5. Multivariate physical examination predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | Age Group (if specified) | Initial Vital Signs/Physical Examination
Study Information | Age Group (if specified) | BP | | HR | | Pulmonary Rales
Author, Year | Age Group (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Chin, 1994 | | < vs >120 mmHg | +++ | | | Part of inclusion criteria for study | N/A
Cunningham, 1989
Herlitz, 1997 | <50 y 50--75 y >75 y
Kontos, 1997
Lee, 1992 | | | | | | CHF on admission | ++
Rude, 1983
Tierney, 1985 | | Per mmHg | NS | Per bpm | NS | On initial exam | NS
Villanueva, 1992 | | Per mmHg | NS | Per bpm | NS | Present or absent | NS

Evidence Table 6. Multivariate ECG predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | Age Group (if specified) | Electrocardiogram Findings
Author, Year | Age Group (if specified) | ST Depression | | Transient ST Elevation | | T-Wave Inversion | | Other
Author, Year | Age Group (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Chin, 1994 | | | | | | | | ST-T changes | ++
Cunningham, 1989
Herlitz, 1997 | <50 y 50--75 y >75 y | >1 mm >1 mm >1 mm | NS NS NS | | | TWI TWI TWI | NS NS NS
Kontos, 1997
Lee, 1992 | | | | | | | | Evidence of ischemia | ++
Rude, 1983 | | >0.1 mV Precordial Lateral Diaphragmatic | +++ + +++
Tierney, 1985 | | Not stated | NS | | | Not stated | NS | Rhythm disturbance | NS
Villanueva, 1992 | | Not stated | NS | Alone With Q waves | +++ +++ | Not stated | NS | Paced rhythm Q waves alone Nonspecific St-T changes LVH with strain LVH alone LBBB RBBB Normal rhythm | +++ NS NS NS NS NS NS -

Evidence Table 7. Multivariate other predictors of adverse outcomes: Patients with chest pain suspicious for ischemia

Study Information | Age Group (if specified) | Other | | Unadjusted Event Rates Primary Outcomes
Author, Year | Age Group (if specified) | Def'n | Estimate | Unadjusted Event Rates Primary Outcomes
Chin, 1994 | | | | Major complication or death: 22%
Cunningham, 1989 | | | | MI: 10% (women), 19% (men)
Herlitz, 1997 | <50 y 50--75 y >75 y | Normal ECG Normal ECG Normal ECG | - - - | 5-year mortality 2.8% 21.4% 56.7%
Kontos, 1997 | | | | MI: or revascularization: 16.5%
Lee, 1992 | | Shock after admission | +++ | CV death (mean 30.1 +/!9.4 mos): 6%
Rude, 1983 | | Marital status | NS | MI 19.9%
Tierney, 1985 | | Atypical chest pain Cyanosis S3 Chest wall tenderness | NS NS NS NS
Villanueva, 1992 | | Family hx of CAD S3 S4 Hypercholesterolemia Peripheral edema | ++ +++ NS NS NS | Cardiac death in-hospital = 0/160 Cardiac death at 2-year followup = 4.5% of all patients MI in-hospital = 21.9% (35/160) MI at 2-year followup = 54/265 = 20.4% Major complication or death in-hospital = 40/160 = 25% Major complication or death at 2 years = 67/265 = 25.3%

Evidence Table 8. Study information: Patients with diagnosed unstable angina

Author, Year | Journal | Location/Setting | N | Inclusion Criteria | Exclusion Criteria
Author, Year | Predictors (clinical, ECG) | Primary Outcome | Secondary Outcomes | Analytical Method
Armstrong, 1998 | Circulation | GUSTO-llb Trial 373 hospitals 13 countries | 8,001 | 5/94--10/9 Chest discomfort within prior 12 hours associated either with transient or persistent ST elevation or depression of >0.5 mm or persistent T-wave inversion of >0.1 mm. | Taking warfarin on admission, active bleeding, prior stroke, contraindication to heparin therapy, renal insufficiency, SBP >200 mmHg, DBP >110 mmHg, or women of child-bearing age Note: This analysis concentrated only on patients without ST elevation
Calvin, 1995 | JAMA | CCU, stepdown unit Rush-Presbyterian-St. Luke's Medical Center, Chicago, IL | 393 | 6/92--12/93 Unstable angina defined as either: (1) Ischemic chest pain responsive to nitrates or associated with ST depression, lasting >20 minutes and occurring at rest (2) Progressive angina defined as exertional ischemic pain increasing in frequency or duration or at decreasing levels of physical exertion | Non-Q-wave MI (CK >2 times upper limit of normal within the first 12 hours and CK-MB fraction >0.05)
Cannon, 1997 | J Am Coll Cardiol | Thrombolysis in Myocardial Infarction (TIMI) III Registry ECG Ancillary Study Nine hospitals | 1,416 | 10/90--4/93 Unstable angina or non-Q-wave MI (typical ischemic chest discomfort) or equivalent lasting >5 min and occurring within 96 hours of (or during) admission, and having an unstable pattern (rest, new onset, severe or frequent, or accelerating angina within 21 days of an acute MI) | Nonischemic or atypical chest pain, persistent new ST-elevation or Q-wave MI admission directly for revascularization, no available qualifying ECG, initiation of digoxin between prequalifying and qualifying ECG, ST elevation on the qualifying ECG only
Castaner, 1990 | Eur Heart J | Cardiac unit University of Barcelona Barcelona, Spain | 104 | 12/81--8/85 Recent onset angina (<1 month) (Exertion and/or at rest) | Previous MI
Coronado, 1997 | J Am Coll Cardiol | Acute Cardiac Ischemia Time-Intensive Predictive Instrument (ACI-TIPI) Trial Emergency department 10 hospitals | 10,783 | 4/93--12/93 Consenting adults >30 years Symptoms suggestive of acute cardiac ischemia (chest pain, chest pressure, left arm pain, jaw pain, upper abdominal pain, dizziness, nausea, vomiting, or dyspnea) | Chest pain of traumatic or clear noncardiac etiology, transferred patients, unobtainable consent, <30 years old suspected cocaine use
Lloyd-Jones, 1998 | Am J Cardiol | CCU, Stepdown Unit Massachusetts General Hospital Brigham & Women's Hospital Boston, MA | 280 | 10/91--9/92 Adults admitted from the emergency department with a diagnosis of unstable angina or acute myocardial infarction | Transferred from other inpatient hospitalization, initial admission to the medical ward, acute MI with ST elevation on admission, final assessment of no acute coronary disease, presence of a clear precipitating factor, pre-existing reason for high mortality
Lundin, 1995 | Cardiology | CCU Danderyd Hospital Danderyd, Sweden | 100 | Unspecified time frame Unstable angina (changing pattern of symptoms in setting of previously stable exertional angina pectoris, new onset angina within 3 weeks at low workloads or at rest, and absence of criteria indicating acute MI) | Prior MI within 4 weeks malignancy or other serious disease, <24 h of vectorcardiography, high frequency of interference, LBBB or RBBB, pacemaker treatment.
Patel, 1998 | Eur Heart J | CCU Three hospitals United Kingdom | 212 | 1990--92 30--75 years old, presenting within 24 hours of an acute episode of unstable angina (new onset angina [<1 month], recent deterioration of stable angina with symptoms on minimal effort, rest or nocturnal angina, or angina within 1 month of an acute MI) | Acute MI (chest pain >30 min, and either ST elevation >0.2 mV or evolving Q waves or elevated cardiac enzymes), on medications that might obscure interpretation of ST segment changes, LVH, LBBB
van Miltenburg-van Zijl, 1995 | J Am Coll Cardiol | Hospital admission Two hospitals Rotterdam, The Netherlands | 282 | 1988--89 Admitted with suspected unstable angina (rest chest pain or on minimal exertion without ECG changes of acute MI or signs of other causes of chest pain) | Transferred from another hospital, unstable angina from secondary condition, acute MI as primary confirmed dx, noncardiac etiology of chest pain
Wilcox, 1991 | J Am Coll Cardiol | CCU Royal Prince Alfred Hospital Sydney, Australia | 107 | 4/86--4/88 <75 years old, unstable angina stabilized with medical therapy (no rest pain for >3 days); Unstable angina defined as either rest angina or progressively worsening exertional angina to warrant admission to the CCU | Transferred from another hospital referral for PTCA or CABG, unable to exercise contraindication to exercise testing, uninterpretable ECG, development of CHF
Armstrong, 1998 | Age, sex, race, height, weight, hypertension, diabetes, hypercholesterolemia, current or past smoking, family history of CHD, prior MI, prior angina, prior cerebrovascular disease, prior PTCA, prior CABG, prior CHF, peripheral vascular disease, SBP, DBP, HR, Killip class, time to hospital, time to treatment, use of invasive procedures (primary PTCA, angiography, PTCA, or CABG), medications (thrombolysis, ACE inhibitor, nitrates, calcium channel blocker, beta blocker, aspirin), in-hospital complications (CHF, bleeding, shock, stroke) | 1 year mortality | None | Logistic regression
Calvin, 1995 | Age, sex, Charlson comorbidity score, diabetes, hypertension, family history, hypercholesterolemia, tobacco smoking history, previous MI more than 14 days earlier, Braunwald Unstable Angina Classification: Progressive angina, rest pain <48 h, post-MI (<14 days earlier), transient ST changes at baseline or with chest pain, not receiving a beta-blocker or rate-lowering calcium channel blocker, requiring IV nitroglycerin | During the index hospitalization: Major complication = death, MI after the first 24 hours, CHF, VT, VF MI = new Q waves, CK >300 ´l after the first 12 hours, and a CK-MB fraction >0.05 | Death or MI | Logistic regression Forward and backward stepwise procedures
Cannon, 1997 | Age, sex, race (white, black, other), prior hospitalization for unstable angina, prior MI, medication in the prior weeks (aspirin <24 h, heparin, warfarin, thrombolytic therapy, nitrates, beta-blockers, calcium channel blockers, ACE inhibitors), rales >1/3 lungs, acute pulmonary edema, cardiogenic shock, other major illness, non-Q-wave MI at entry | Adverse outcomes at 1 year: Death or postenrollment MI | In-hospital recurrent ischemia (with ST- or T-wave changes); Postdischarge readmission for recurrent ischemic pain | Cox proportional hazards model
Castaner, 1990 | Exercise angina, rest angina, single versus several episodes of angina, abnormal ECG, persistent symptoms after hospital admission, ECG changes with chest pain, number of risk factors (0-4: exertional angina, history of several episodes of chest pain, abnormal ECG, or recurrent angina after admission) | During mean followup of 36 months: Medical events (death or MI) | Combined events: Death or MI or need for revascularization | Cox proportional hazards model
Coronado, 1997 | Gender Adjusted for: age, diabetes, hypertension, prior MI, CHF on admission, initial blood pressure, ethnicity, in-hospital procedures (thrombolysis, heart catherization, PTCA, CABG) | In-hospital mortality | None | Logistic regression
Lloyd-Jones, 1998 | Age, sex, hypertension, diabetes, current smoker, prior total cholesterol >240 mg/dL, prior MI, prior PTCA or CABG, prior CHF or LVEF <0.40, aspirin use at presentation, beta-blocker use at presentation, unstable angina class (based on 1994 AHCPR Guideline), duration of angina >4 h, CHF at presentation, ECG changes at presentation (new ST depression, isolated T-wave inversion, LVH, LBBB, RBBB, old Q wave) | In-hospital acute MI | None | Logistic regression
Lundin, 1995 | Age, sex, prior angina pectoris, prior MI, CHF, diabetes, rest pain after admission, findings on continuous vectorcardiography (QRS-vector difference, ST-vector magnitude, ST-change vector magnitude) | Up to 1 year followup Cardiac death or nonfatal MI | None | Stepwise Cox proportional hazards model
Patel, 1998 | Age, sex, smoking history, family history of CHD, diabetes, hypertension, prior MI, previous stable angina, new onset angina, post-MI angina, admission ECG findings (ST depression, isolated T-wave inversion, old Q waves), recurrent chest pain after admission, transient myocardial ischemia on continuous ST segment | Long-term followup (median 2.6 y), adverse outcome = cardiac death or nonfatal MI | Unfavorable outcome = cardiac death, nonfatal MI, or recurrent severe angina requiring revascularization | Cox proportional hazards model
van Miltenburg-van Zijl, 1995 | Age, sex, prior MI, hypertension, Braunwald class (I-III), Braunwald clinical circumstances (B, C), ECG changes, intensity of medical treatment before admission (minimal, extensive oral) | 6-month followup: Survival without MI | Survival without MI or revascularization | Stepwise Cox proportional hazards model
Wilcox, 1991 | Age, sex, current cigarette smoking, hypertension, diabetes, prior stable angina pectoris, prior MI, prior CABG, recurrent rest pain during admission, CD elevation >2X upper limit, treatment with a beta-blocker or calcium channel blocker, ECG findings (evolutionary T-wave changes, transient ST- or T-wave changes during rest pain, preexercise ST depression or T-wave inversions), angina during exercise test, positive exercise test, workload, and maximal rate-pressure product | Long-term follow-up (4 & 12 months): Cardiac death, nonfatal MI, or readmission for unstable angina | None | Backward stepwise elimination logistic regression

Evidence Table 9. Multivariate demographic predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Event Classification (if specified) | Demographic Characteristics
Study Information | Event Classification (if specified) | Age | | Gender | | Race/Ethnicity
Author, Year | Event Classification (if specified) | Def'n | Estimate | Male | Estimate | Def'n | Estimate
Armstrong, 1998 | | 75 vs. 55 y | +++ | | NS | W vs. other | NS
Calvin, 1995 | | Per 10 y | + | | NS
Cannon, 1997 | | Per 10 y | + | | NS | N/A | NS
Castaner, 1990
Coronado, 1997 | | Per 10 y | + | | NS | N/A | NS
Lloyd-Jones, 1998 | | N/A | NS | | NS | W vs. other | NS
Lundin, 1995 | | Per year | + | | --- | CHF on admission
Patel, 1998 | Death | > vs. <65 y | + | | NS
van Miltenburg-van Zijl, 1995 | Death Death or MI Death or MI or revascularization | > vs. <70 y > vs. <70 y > vs. <70 y | +++ ++ NS | | +++ NS ++
Wilcox, 1991 | | | | | NS

Evidence Table 10. Multivariate medical history predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Event Classification (if specified) | Past Medical History
Author, Year | Event Classification (if specified) | MI | | Unstable Angina | | Stable Angina | | PTCA
Author, Year | Event Classification (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Armstrong, 1998 | | Prior MI dx | + | | | Prior angina dx | + | Prior PTCA hx | NS
Calvin, 1995 | | MI1s within 14 d MI >14 d | +++ NS | Progressive angina | NS
Cannon, 1997 | | Prior MI dx | NS | Prior hospitalization for unstable angina | NS
Castaner, 1990 | | | | Rest angina | NS | Exercise angina | NS
Coronado, 1997 | | Prior MI dx | NS
Lloyd-Jones, 1998 | | Prior MI dx | NS | Inclusion criteria | N/A | | | No prior revascularization | +++
Lundin, 1995 | | Prior MI dx | +++ | Inclusion criteria | N/A | Angina pectoris hx | NS
Patel, 1998 | Prior MI dx | ++ | New onset angina | NS | Previous stable angina | NS
van Miltenburg-van Zijl, 1995 | Death Death or MI Death, MI, or revascularization | Prior MI dx Prior MI dx Prior MI dx | NS NS NS | Inclusion criteria Inclusion criteria Inclusion criteria | N/A N/A N/A
Wilcox, 1991 | | Prior MI dx | NS | Inclusion criteria | N/A | Prior stable angina hx | NS

Evidence Table 10. (cont'd) Multivariate medical history predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Event Classification (if specified) | Past Medical History
Author, Year | Event Classification (if specified) | CABG | | CHF | | CVA/TIA | | HTN | | Diabetes | | Smoking
Author, Year | Event Classification (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Armstrong, 1998 | | Prior CABG | + | CHF dx | + | Prior CVD | NS | HTN dx | NS | Diabetes dx | + | Past/ current smoking hx | NS
Calvin, 1995 | | | | CHF dx | NS | | | HTN dx | NS | Diabetes dx | ++ | Smoking hx | NS
Cannon, 1997
Castaner, 1990
Coronado, 1997 | | | | | | | | HTN dx | NS | Diabetes dx | +
Lloyd-Jones, 1998 | | See PTCA | See PTCA | CHF dx or LVEF <0.40 | NS | | | HTN dx | NS | Diabetes dx | NS | Current smoker | NS
Lundin, 1995 | | | | CHF dx | NS | | | | | Diabetes dx | +++
Patel, 1998 | | | | | | | | HTN dx | +++ | Diabetes dx | NS | Smoking hx | NS
van Miltenburg-van Zijl, 1995 | Death Death or MI Death, MI, or revascularization | | | | | | | HTN dx HTN dx HTN dx | +++ NS NS
Wilcox, 1991 | | CABG hx | NS | | | | | HTN dx | NS | Diabetes dx | +++ | Current smoker | NS

Evidence Table 11. Multivariate symptom predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Event Classification (if specified) | Symptom Characteristics
Study Information | Event Classification (if specified) | Frequency | | Duration | | Other
Author, Year | Event Classification (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Armstrong, 1998
Calvin, 1995 | | | | Rest pain < or >48 h | NS
Cannon, 1997
Castaner, 1990 | | Single vs. several episodes | NS | | | Recurrent chest pain after admission | NS
Coronado, 1997
Lloyd-Jones, 1998 | | Inclusion criteria | N/A | >4 h | +++
Lundin, 1995 | | Part of inclusion criteria | N/A
Patel, 1998 | | Inclusion criteria | N/A
van Miltenburg-van Zijl, 1995 | Death Death or MI Death, MI or revascularization | | | | | Braunwald Class C Braunwald Class C Braunwald Class C | +++ ++ +
Wilcox, 1991 | | | | | | Rest pain after admission | +++

Evidence Table 12. Multivariate physical examination predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Event Classification (if specified) | Initial Vital Signs/Physical Exam
Study Information | Event Classification (if specified) | Blood Pressure | | Heart Rate | | Pulmonary Rates
Author, Year | Event Classification (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Armstrong, 1998 | | SBP DBP | NS NS | Per bpm | + | Killip class II vs. I Killip class III/IV vs. I | + ++
Calvin, 1995
Cannon, 1997 | | | | | | Rales >1/3 of lung fields | NS
Castaner, 1990 | | | | | | Acute pulmonary edema | NS
Coronado, 1997 | | BP on presentation | NS | | | CHF on x-ray | ++
Lloyd-Jones, 1998 | | | | | | CHF on presentation | NS
Lundin, 1995
Patel, 1998
van Miltenburg-van Zijl, 1995 | Death Death or MI Death, MI or revascularization
Wilcox, 1991

Evidence Table 13. Multivariate ECG predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Event Classification (if specified) | Electrocardiographic Findings
Study Information | Event Classification (if specified) | ST Depression | | Transient ST Elevation | | T-Wave Inversion | | Other
Author, Year | Event Classification (if specified) | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate | Def'n | Estimate
Armstrong, 1998
Calvin, 1995 | | Baseline ST depression Recurrent angina with ST depression | ++ NS
Cannon, 1997 | | ST deviation > 0.5 mm (depression or transient ST elevation) | ++ | See ST Depression | See ST Depression | Isolated T-wave change | NS | LBBB | ++
Castaner, 1990 | | | | | | | | Abnormal ECG | NS
Coronado, 1997
Lloyd-Jones, 1998 | | > 0.1 mV in > 2 leads (new) | ++ | | | Isolated T-wave inversion | NS | LVH LBBB RBBB Old Q-wave | NS NS NS NS
Lundin, 1995 | | | | | | | | Number of ST-change vector magnitude episodes | +
Patel, 1998 | | >0.1 mV ST depression | NS | | | Isolated T-wave inversion | NS | Transient ischemia | ++
van Miltenburg-van Zijl, 1995 | Death Death or MI Death, MI, or revascularization | | | | | | | ECG changes ECG changes ECG changes | NS NS +
Wilcox, 1991 | | | | | | | | Evolutionary T-wave changes Transient ST-T changes >0.05 mV ST elevation or depression, T-wave inversion, or pseudo-normalization Pretest ST depression (> 0.1 mV) Pretest T-wave inversion (> 0.3 mV) on continuous Holter | +++ NS NS NS

Evidence Table 14. Multivariate other predictors of adverse outcomes: Patients with diagnosed unstable angina

Study Information | Other | | Unadjusted Event Rates | Comments
Author, Year | Def'n | Estimate | Unadjusted Event Rates | Comments
Armstrong, 1998 | Recurrent ischemia -Day 0-1 -Day 2-3 | + + | Death at 1 year: Unstable angina patients (7.0%) Non-ST-elevation MI patients (11.1%)
Calvin, 1995 | Requiring IV nTG on admission No beta-blocker or rate-lowering CCB Positive family hx Hypercholesterolemia Exacerbating condition Aspirin use Heparin use Charlson comorbidity score | ++ +++ NS NS NS NS NS NS | Major complication: 20% Death or MI: 8%
  Predictors for Death or MI only | Estimate
  Prior MI within 14 d | +++
  No beta-blocker or rate-lowering CCB | +++
  Baseline ST depression | +++
  Diabetes | ++
Cannon, 1997 | Thrombolysis in past week Other major illness Nitrates in past week Cardiogenic shock Non-Q-wave MI at entry Heparin in past week Warfarin past week Beta-blockers in past week Calcium channel blockers in past week | +++ + + NS NS NS NS NS NS | Death or nonfatal MI at 1 year: 9.5% Death, MI, or recurrent ischemia: 28.3%
Castaner, 1990 | Number of risk factors | ++ | Death or MI (mean 36 months): 13% Death, MI, or revascularization: 35%
  Predictors of combined events | Estimate
  Number of risk factors | ++
Coronado, 1997 | | | In-hospital mortality: N/A
Lloyd-Jones, 1998 | No prior beta-blocker therapy Prior aspirin use Unstable angina class | ++ NS NS | Non-ST-elevation MI: 24%
Lundin, 1995 | | | Cardiac death or nonfatal MI: 15%
Patel, 1998 | Recurrent severe chest pain | + | Cardiac death or MI at 2.6 y: 12.7%
  Predictors of any unfavorable outcome | Estimate
  Resting ST depression | +
  Recurrent pain | +
  Transient ischemia | +
van Miltenburg-van Zijl, 1998 | Maximal antianginal therapy (death) Maximal IV antianginal therapy (death, MI, or revasc) | +++ ++ | In-hospital death or MI: 4.3% Death or MI at 6 months: 9.6%
Wilcox, 1991 | Beta-blocker therapy (calcium channel blocker therapy) | NS NS | Cardiac death, MI, or readmission at mean 12.8 months: 27%

Evidence Table 15. Demographics

Author | Year | Mean Age | Median Age | Lower Age Limit | Upper Age Limit | Percent Male
Adams | 1994 | | | | | 61
Antman | 1995
Antman | 1996 | 59 | | 21 | 76 | 67
Antman | 1998 | 64 | | 54 | 71 | 63
Apple | 1995
Bakker | 1993b
Bakker | 1993a | 64 | | | | 70
Benamer | 1998 | 61 | | | | 75
Brscic | 1998 | 62 | | | | 73
Chang | 1998 | 59 | | | | 48
Christenson | 1998 | 63 | | 53 | 72 | 69
D'Costa | 1997
de Winter | 1996 | 63 | | | | 61
de Filippi | 1998 | 52 | | | | 46
Galvani | 1997 | 66 | | | | 68
Gerhardt | 1993 | | | 36 | 91 | 70
Gerhardt | 1997b
Gerhardt | 1997a
Gokhan Cin | 1996 | 49 | | | | 68
Green | 1998 | 58 | | 22 | 95 | 49
Gust | 1998 | 69 | | 48 | 84 | 69
Hamm | 1992 | 62 | | | | 73
Hamm | 1997 | 62 | | | | 59
Heeschen | 1998
Hetland | 1996 | | | 31 | 95 | 69
Hetland | 1998 | 68 | | | | 64
Katus | 1991 | 53 | | | | 77
Kost | 1998
Koukkunen | 1998 | | 69 | 19 | 96 | 56
Laurino | 1997 | | 64 | | | 57
Lindahl | 1996 | | 70 | | | 65
Luscher | 1997 | | 64 | 31 | 80 | 71
Luscher | 1998 | | 66 | | | 67
Mockel | 1998 | 57 | | 21 | 82 | 69
Mohler | 1998 | 56 | | | | 57
Ohman | 1996 | | 63 | | | 69
Olatidoye | 1998 | 64 | | | | 49
Pettijohn | 1997
Polanczyk | 1998 | 61 | | | | 50
Ravkilde | 1993 | 68 | | 39 | 84 | 71
Ravkilde | 1995 | 64 | | 36 | 89 | 64
REACTT Study | 1997 | 59 | | 26 | 98 | 60
Rebuzzi | 1998 | 64 | | 30 | 75 | 72
Sayre | 1998 | 53 | | 22 | 93 | 48
Seino | 1993
Seino | 1996 | 60 | | 37 | 81 | 75
Stokke | 1998 | | 65 | | | 55
Stork | 1997
Stubbs | 1996 | 61 | | | | 73
Tucker | 1997
Wu | 1995 | 66 | | | | 57
Yang | 1995 | | | | | 79

Evidence Table 16. Patient characteristics (Part I)

Author | Year | Percent Hx of MI | Percent Hx of CAD | Percent CHF | Percent HTN | Percent DM | Percent Smokers
Adams | 1994
Antman | 1995
Antman | 1996 | 40 | 59 | | 42 | | 38
Antman | 1998 | 38 | | | 60 | 33 | 26
Apple | 1995
Bakker | 1993b
Bakker | 1993a | 30 | 58 | | 32 | 11 | 39
Benamer | 1998 | 33 | | | 53 | 24 | 55
Brscic | 1998 | 46
Chang | 1998
Christenson | 1998 | 26 | | | 52 | 21
D'Costa | 1997
de Winter | 1996 | 41 | 59
de Filippi | 1998 | | | | 55 | 27 | 56
Galvani | 1997 | 48
Gerhardt | 1993
Gerhardt | 1997b
Gerhardt | 1997a
Gokhan Cin | 1996
Green | 1998
Gust | 1998 | | 16
Hamm | 1992
Hamm | 1997
Heeschen | 1998
Hetland | 1996
Hetland | 1998 | 40
Katus | 1991
Kost | 1998
Koukkunen | 1998 | 39 | 67
Laurino | 1997
Lindahl | 1996 | 29 | | 9 | 33 | 13 | 19
Luscher | 1997 | 49 | 67 | | 38 | 15 | 23
Luscher | 1998 | 20
Mockel | 1998 | | 58 | | 59 | 18 | 66
Mohler | 1998 | 42 | | | 60 | 25 | 60
Ohman | 1996 | 26 | | | 51 | 22
Olatidoye | 1998 | | 55 | | 52 | 25
Pettijohn | 1997
Polanczyk | 1998 | 31 | 47 | | 61 | 24 | 22
Ravkilde | 1993 | 49 | | | 27 | 9
Ravkilde | 1995 | 28 | 42 | 16 | 9 | 9 | 52
REACTT Study | 1997
Rebuzzi | 1998 | | | | 37 | 11 | 43
Sayre | 1998
Seino | 1993
Seino | 1996
Stokke
Stork | 1997
Stubbs | 1996 | 36 | | | 27 | 16 | 31
Tucker | 1997
Wu | 1995 | 31 | | 9 | 47 | 22 | 31
Yang | 1995

Evidence Table 17. Patient characteristics (Part 2)

Author | Year | Percent Beta Blocker | Percent Aspirin | Valvular HD | Percent Ischemic ECG Changes
Adams | 1994
Antman | 1995
Antman | 1996 | 34 | 47 | | 73
Antman | 1998 | 49 | 81
Apple | 1995
Bakker | 1993b
Bakker | 1993a
Benamer | 1998 | | | | 67
Brscic | 1998 | | | [image] | 100
Chang | 1998
Christenson | 1998 | | | | 100
D'Costa | 1997
de Winter | 1996 | 31
de Filippi | 1998 | | | | 5
Galvani | 1997 | 31 | | [image] | 100
Gerhardt | 1993
Gerhardt | 1997b
Gerhardt | 1997a
Gokhan Cin | 1996 | 39 | | [image]
Green | 1998 | | | | 2
Gust | 1998
Hamm | 1992 | | | [image]
Hamm | 1997 | | | | 46
Heeschen | 1998
Hetland | 1996
Hetland | 1998
Katus | 1991 | | | [image]
Kost | 1998
Koukkunen | 1998
Laurino | 1997
Lindahl | 1996 | 37 | 34 | [image] | 100
Luscher | 1997 | 47 | 52
Luscher | 1998
Mockel | 1998 | | | | 67
Mohler | 1998
Ohman | 1996 | | | | 100
Olatidoye | 1998
Pettijohn | 1997
Polanczyk | 1998
Ravkilde | 1993 | 29 | 26
Ravkilde | 1995
REACTT Study | 1997
Rebuzzi | 1998 | 31 | 100 | | 38
Sayre | 1998
Seino | 1993
Seino | 1996 | 20 | | | 100
Stokke | 1998
Stork | 1997
Stubbs | 1996 | 29 | | | 44
Tucker | 1997
Wu | 1995
Yang | 1995

Evidence Table 18. Exclusion criteria (Part I)

Author | Year | Exclusions Listed? | Female | Heart Failure | ST Elevation | Q-Wave MI | Recent MI
Adams | 1994 | No
Antman | 1995 | Yes | | | | | [image]
Antman | 1996 | Yes | | | | | [image]
Antman | 1998 | Yes | | | | [image]
Apple | 1995 | No
Bakker | 1993b | Yes
Bakker | 1993a | Yes
Benamer | 1998 | Yes | | | | | [image]
Brscic | 1998 | Yes | | [image] | | | [image]
Chang | 1998 | No
Christenson | 1998 | Yes
D'Costa | 1997 | No
de Winter | 1996 | Yes | | | [image]
de Filippi | 1998 | Yes | | | [image]
Galvani | 1997 | Yes | | | | | [image]
Gerhardt | 1993 | No
Gerhardt | 1997b | No
Gerhardt | 1997a | No
Gokhan Cin | 1996 | Yes | | [image] | | | [image]
Green | 1998 | Yes
Gust | 1998 | Yes | | | | | [image]
Hamm | 1992 | Yes | | | | | [image]
Hamm | 1997 | Yes | | | [image] | | [image]
Heeschen | 1998 | No
Hetland | 1996 | Yes
Hetland | 1998 | No
Katus | 1991 | Yes
Kost | 1998 | Yes
Koukkunen | 1998 | No
Laurino | 1997 | No
Lindahl | 1996 | Yes | | | [image] | [image]
Luscher | 1997 | Yes | | [image] | [image]
Luscher | 1998 | Yes
Mockel | 1998 | Yes | | [image] | [image]
Mohler | 1998 | Yes
Ohman | 1996 | Yes
Olatidoye | 1998 | Yes | | | | | [image]
Pettijohn | 1997 | Yes
Polanczyk | 1998 | Yes
Ravkilde | 1993 | No
Ravkilde | 1995 | Yes | | | | | [image]
REACTT Study | 1997 | Yes
Rebuzzi | 1998 | Yes
Sayre | 1998 | Yes
Seino | 1993 | No
Seino | 1996 | Yes
Stokke | 1998 | Yes
Stork | 1997 | No
Stubbs | 1996 | No
Tucker | 1997 | Yes
Wu | 1995 | No
Yang | 1995 | No

Evidence Table 19. Exclusion criteria (Part 2)

Author | Year | Exclusions Listed? | No Ischemia on ECG | Anemia | Cocaine or Other Drug Use | Lytics | Primary PTCA
Adams | 1994 | No
Antman | 1995 | Yes | | | | [image] | [image]
Antman | 1996 | Yes | | | | [image]
Antman | 1998 | Yes
Apple | 1995 | No
Bakker | 1993b | Yes
Bakker | 1993a | Yes
Benamer | 1998 | Yes
Brscic | 1998 | Yes | [image]
Chang | 1998 | No
Christenson | 1998 | Yes | [image]
D'Costa | 1997 | No
de Winter | 1996 | Yes
de Filippi | 1998 | Yes
Galvani | 1997 | Yes | [image]
Gerhardt | 1993 | No
Gerhardt | 1997b | No
Gerhardt | 1997a | No
Gokhan Cin | 1996 | Yes
Green | 1998 | Yes
Gust | 1998 | Yes | | | | [image]
Hamm | 1992 | Yes
Hamm | 1997 | Yes
Heeschen | 1998 | No
Hetland | 1996 | Yes
Hetland | 1998 | No
Katus | 1991 | Yes
Kost | 1998 | Yes
Koukkunen | 1998 | No
Laurino | 1997 | No | | | | [image]
Lindahl | 1996 | Yes
Luscher | 1997 | Yes | | [image]
Luscher | 1998 | Yes
Mockel | 1998 | Yes
Mohler | 1998 | Yes
Ohman | 1996 | Yes | [image]
Olatidoye | 1998 | Yes
Pettijohn | 1997 | Yes
Polanczyk | 1998 | Yes
Ravkilde | 1993 | No
Ravkilde | 1995 | Yes
REACTT Study | 1997 | Yes | | [image]
Rebuzzi | 1998 | Yes
Sayre | 1998 | Yes
Seino | 1993 | No
Seino | 1996 | Yes
Stokke | 1998 | Yes | | | | [image]
Stork | 1997 | No
Stubbs | 1996 | No
Tucker | 1997 | Yes
Wu | 1995 | No
Yang | 1995 | No

Evidence Table 20. Exclusion criteria (Part 3)

Author | Year | Exclusions Listed? | Recent PTCA | Recent CABG | LBBB
Adams | 1994 | No
Antman | 1995 | Yes | [image]
Antman | 1996 | Yes | [image] | | [image]
Antman | 1998 | Yes | | [image]
Apple | 1995 | No
Bakker | 1993b | Yes
Bakker | 1993a | Yes
Benamer | 1998 | Yes
Brscic | 1998 | Yes
Chang | 1998 | No
Christenson | 1998 | Yes
D'Costa | 1997 | No
de Winter | 1996 | Yes
de Filippi | 1998 | Yes | | | [image]
Galvani | 1997 | Yes
Gerhardt | 1993 | No
Gerhardt | 1997b | No
Gerhardt | 1997a | No
Gokhan Cin | 1996 | Yes
Green | 1998 | Yes
Gust | 1998 | Yes | [image]
Hamm | 1992 | Yes
Hamm | 1997 | Yes
Heeschen | 1998 | No
Hetland | 1996 | Yes
Hetland | 1998 | No
Katus | 1991 | Yes | | | [image]
Kost | 1998 | Yes
Koukkunen | 1998 | No
Laurino | 1997 | No
Lindahl | 1996 | Yes | | | [image]
Luscher | 1997 | Yes
Luscher | 1998 | Yes | [image] | [image]
Mockel | 1998 | Yes
Mohler | 1998 | Yes
Ohman | 1996 | Yes
Olatidoye | 1998 | Yes
Pettijohn | 1997 | Yes
Polanczyk | 1998 | Yes
Ravkilde | 1993 | No
Ravkilde | 1995 | Yes
REACTT Study | 1997 | Yes
Rebuzzi | 1998 | Yes
Sayre | 1998 | Yes
Seino | 1993 | No
Seino | 1996 | Yes
Stokke | 1998 | Yes | [image]
Stork | 1997 | No
Stubbs | 1996 | No
Tucker | 1997 | Yes
Wu | 1995 | No
Yang | 1995 | No

Evidence Table 21. Troponin test characteristics

Author | Year | Troponin T Test | Troponin I Test | Providers Blinded to Result
Adams | 1994 | | Serum | Yes
Antman | 1995 | Rapid bedside | | Yes
Antman | 1996 | | Serum | Yes
Antman | 1998 | Rapid beside | | Yes
Apple | 1995 | Serum | Serum | Not stated
Bakker | 1993b | Serum | | Not stated
Bakker | 1993a | Serum | | Yes
Benamer | 1998 | | Serum | Unclear
Brscic | 1998 | | Serum | Yes
Chang | 1998 | | Serum | No
Christenson | 1998 | Serum | Serum | Not stated
D'Costa | 1997 | | Serum | Yes
de Winter | 1996 | Serum | | Yes
de Filippi | 1998 | Rapid bedside | | Yes
Galvani | 1997 | Serum | Serum | Yes
Gerhardt | 1993 | Serum | | Not stated
Gerhardt | 1997b | Rapid bedside | | Not stated
Gerhardt | 1997a | Serum | Rapid bedside | Yes
Gokhan Cin | 1996 | Serum | | Yes
Green | 1998 | Serum | | Yes
Gust | 1998 | Rapid bedside | | Yes
Hamm | 1992 | Serum | | Yes
Hamm | 1997 | Rapid bedside | Rapid bedside | No
Heeschen | 1998 | | Rapid bedside | Not stated
Hetland | 1996 | Serum | | Yes
Hetland | 1998 | Serum | Serum | Not stated
Katus | 1991 | Serum | | Not stated
Kost | 1998 | Serum | Serum | Yes
Koukkunen | 1998 | Serum | | Yes
Laurino | 1997 | | Serum | Yes
Lindahl | 1996 | Serum | | Yes
Luscher | 1997 | Serum | Serum | Yes
Luscher | 1998 | Rapid bedside | | Unclear
Mockel | 1998 | Serum | | Yes
Mohler | 1998 | Serum | | Yes
Ohman | 1996 | Serum | | Yes
Olatidoye | 1998 | Serum | Serum | Yes
Pettijohn | 1997 | Serum | | Not stated
Polanczyk | 1998 | | Serum | Yes
Ravkilde | 1993 | Serum | | Yes
Ravkilde | 1995 | Serum | | Not stated
REACTT Study | 1997 | Rapid bedside | | Yes
Rebuzzi | 1998 | Serum | | Yes
Sayre | 1998 | Serum | | Yes
Seino | 1993 | Serum | | Not stated
Seino | 1996 | Serum | | Not stated
Stokke | 1998 | Serum | Serum | Yes
Stork | 1997 | Serum | | Unclear
Stubbs | 1996 | Serum | | Yes
Tucker | 1997 | Serum | Serum | Yes
Wu | 1995 | Serum | | Yes
Yang | 1995 | Serum | | Not stated

Evidence Table 22. Time (hours) from presentation to troponin T and troponin I tests

Author | Year | Time to 1st T | Time to 2nd T | Time to 3rd T | Time to 1st I | Time to 2nd I | Time to 3rd I
Adams | 1994 | | | | 12 | 24 | 36
Antman | 1995 | 0 | 8 | 16
Antman | 1996 | | | | 0
Antman | 1998 | 0
Apple | 1995
Bakker | 1993b | 0
Bakker | 1993a | 0
Benamer | 1998 | | | | 0 | 12 | 24
Brscic | 1998 | | | | 0 | 12 | 24
Chang | 1998
Christenson | 1998 | 0 | | | 0
D'Costa | 1997 | | | | 0 | 6 | 12
de Winter | 1996
de Filippi | 1998 | 0
Galvani | 1997 | | | | 0 | 8 | 16
Gerhardt | 1993 | 4 | 10 | 16
Gerhardt | 1997b
Gerhardt | 1997a | 4 | 10 | 16 | 4 | 10 | 16
Gokhan Cin | 1996 | 0 | 8 | 16 | 0 | 8 | 16
Green | 1998
Gust | 1998
Hamm | 1992 | 0 | 8 | 16
Hamm | 1997 | 0 | 4 | | 0 | 4
Heeschen | 1998 | | | | 4 | 8
Hetland | 1996 | | 6
Hetland | 1998 | 2 | 6 | | 2 | 6
Katus | 1991
Kost | 1998 | 0 | 3 | 6 | 0 | 3 | 6
Koukkunen | 1998 | 0 | 2 | 4
Laurino | 1997 | | | | 0 | 1 | 2
Lindahl | 1996 | 0 | 12 | 24
Luscher | 1997 | 0 | 6 | 12 | 0 | 6 | 12
Luscher | 1998 | 0 | 1 | 3
Mockel | 1998 | 0 | 4
Mohler | 1998 | 4 | 8 | 16
Ohman | 1996 | 0
Olatidoye | 1998 | 0 | | | 0
Pettijohn | 1997 | 0 | 8 | 16
Polanczyk | 1998 | | | | 0 | 8 | 16
Ravkilde | 1993 | 0 | 6 | 12
Ravkilde | 1995
REACTT Study | 1997 | 0 | 3 | 6
Rebuzzi | 1998 | 0
Sayre | 1998
Seino | 1993
Seino | 1996 | 0 | 2 | 4
Stokke | 1998 | 1 | 2 | | 1 | 2
Stork | 1997
Stubbs | 1996
Tucker | 1997 | 0 | 1 | 2 | 0 | 1 | 2
Wu | 1995 | 0
Yang | 1995

Evidence Table 23. Troponin T and troponin I tests threshold for positivity

Author | Year | Troponin T Threshold | Troponin T Units | Troponin I Threshold | Troponin I Units
Adams | 1994 | | | 3.1 | ng/ml
Antman | 1995 | 0.2 | ng/ml
Antman | 1996 | | | 0.4 | ng/ml
Antman | 1998 | 0.2 | ng/ml
Apple | 1995 | | | 3.1 | ng/ml
Bakker | 1993b | 0.1 | ng/ml
Bakker | 1993a | 0.1 | ng/ml
Benamer | 1998 | | | 0.4 | ng/ml
Brscic | 1998 | | | 0.6 | ng/ml
Chang | 1998 | | | 2.0 | ng/ml
Christenson | 1998 | | | 1.5 | ng/ml
D'Costa | 1997 | | | 1.0 | ng/ml
de Winter | 1996 | 0.1 | ng/ml
de Filippi | 1998 | 0.08 | ng/ml
Galvani | 1997 | 3.1 | | 3.1 | ng/ml
Gerhardt | 1993 | 0.2 | ng/ml
Gerhardt | 1997b
Gerhardt | 1997a | 0.1 | ng/ml | 0.1 | ng/ml
Gokhan Cin | 1996 | 0.2 | ng/ml
Green | 1998 | 0.14 | ng/ml
Gust | 1998 | 0.2 | ng/ml
Hamm | 1992 | 0.2 | ng/ml
Hamm | 1997 | 0.18 | ng/ml | 0.1 | ng/ml
Heeschen | 1998 | | | 0.1 | ng/ml
Hetland | 1996 | 0.05 | ng/ml
Hetland | 1998 | 0.05 | ng/ml | 0.05 | ng/ml
Katus | 1991 | 0.5 | ng/ml
Kost | 1998 | 0.1 | ng/ml | 1.5 | ng/ml
Koukkunen | 1998 | 0.1 | ng/ml
Laurino | 1997 | | | 0.6 | ng/ml
Lindahl | 1996 | 0.06 | ng/ml
Luscher | 1997 | 0.1 | ng/ml | 2.0 | ng/ml
Luscher | 1998 | 0.2 | ng/ml
Mockel | 1998 | 0.2 | ng/ml
Mohler | 1998 | 0.1 | ng/ml
Ohman | 1996 | 0.1 | ng/ml
Olatidoye | 1998 | 0.2 | ng/ml | 1.7 | ng/ml
Pettijohn | 1997 | 0.1 | ng/ml
Polanczyk | 1998 | | | 0.4 | ng/ml
Ravkilde | 1993 | 0.2 | ng/ml
Ravkilde | 1995 | 0.2 | ng/ml
REACTT Study | 1997
Rebuzzi | 1998 | 0.2 | ng/ml
Sayre | 1998 | 0.2 | ng/ml
Seino | 1993 | 0.25 | ng/ml
Seino | 1996 | 0.2 | ng/ml
Stokke | 1998 | | | 1.0 | ng/ml
Stork | 1997
Stubbs | 1996 | 0.2 | ng/ml
Tucker | 1997 | 0.1 | ng/ml | 0.6 | ng/ml
Wu | 1995 | 0.1 | ng/ml
Yang | 1995 | 0.3 | ng/ml

Evidence Table 24. Study description

Author | Year | Multicenter | Patients Eligible | Patient Enrolled | Patient Cohort
Adams | 1994 | | 201 | 199 | Suspected ischemia (+/- chest pain)
Antman | 1995 | | 533 | 100 | Chest pain
Antman | 1996 | [image] | 1,473 | 1,404 | Chest pain
Antman | 1998 | [image] | 630 | 597 | Chest pain
Apple | 1995 | | | 107 | Chest pain
Bakker | 1993b | | | 297 | Suspected ischemia (+/- chest pain)
Bakker | 1993a | | 416 | 290 | Chest pain
Benamer | 1998 | | 309 | 195 | Unstable angina
Brscic | 1998 | | 99 | 92 | Unstable angina
Chang | 1998 | | | 110 | Chest pain
Christenson | 1998 | [image] | 855 | 770 | Chest pain
D'Costa | 1997 | | | 316 | Suspected ischemia (+/- chest pain)
de Winter | 1996 | | 131 | 128 | Chest pain
de Filippi | 1998 | | | 171 | Chest pain
Galvani | 1997 | [image] | 106 | 91 | Unstable angina
Gerhardt | 1993 | | | 207 | Suspected ischemia (+/- chest pain)
Gerhardt | 1997b | [image] | | 487 | Suspected ischemia (+/- chest pain)
Gerhardt | 1997a | | | 502 | Suspected ischemia (+/- chest pain)
Gokhan Cin | 1996 | | 72 | 72 | Unstable angina
Green | 1998 | | 338 | 292 | Chest pain
Gust | 1998 | | | 68 | Chest pain
Hamm | 1992 | [image] | | 84 | Unstable angina
Hamm | 1997 | | 870 | 773 | Chest pain
Heeschen | 1998 | | | 637 | Chest pain
Hetland | 1996 | | | 133 | Chest pain
Hetland | 1998 | | 170 | 170 | Suspected ischemia (+/- chest pain)
Katus | 1991 | | | 387 | Chest pain
Kost | 1998 | | | 54 | Chest pain
Koukkunen | 1998 | | 646 | 624 | Chest pain
Laurino | 1997 | | | 115 | Chest pain
Lindahl | 1996 | [image] | | 581 | Unstable angina
Luscher | 1997 | [image] | 1,209 | 516 | Chest pain
Luscher | 1998 | | 99 | 92 | Chest pain
Mockel | 1998 | | 106 | 106 | Suspected ischemia (+/- chest pain)
Mohler | 1998 | | 100 | 100 | Chest pain
Ohman | 1996 | [image] | | 320 | Chest pain
Olatidoye | 1998 | | 123 | 107 | Unstable angina
Pettijohn | 1997 | | 263 | 129 | Unstable angina
Polanczyk | 1998 | | 1,139 | 1,047 | Chest pain
Ravkilde | 1993 | [image] | | 127 | Unstable angina
Ravkilde | 1995 | | 235 | 196 | Chest pain
REACTT Study | 1997 | [image] | 926 | 721 | Suspected ischemia (+/- chest pain)
Rebuzzi | 1998 | [image] | 102 | 102 | Unstable angina
Sayre | 1998 | | 700 | 667 | Chest pain
Seino | 1993 | | 22 | 22 | Chest pain
Seino | 1996 | | 35 | 35 | Acute coronary syndrome
Stokke | 1998 | | | 22 | Unstable angina
Stork | 1997 | | | 19 | Unstable angina
Stubbs | 1996 | | 460 | 183 | Chest pain
Tucker | 1997 | | 248 | 177 | Chest pain
Wu | 1995 | | | 131 | Unstable angina
Yang | 1995 | | | 94 | Unstable angina

Evidence Table 25. Definition of a positive troponin result

Author | Year | Definition of Positive | No. of Positive Troponin T | No. of Positive Troponin I
Adams | 1994 | Any pos test | | 91
Antman | 1995 | Initial pos test | 27
Antman | 1996 | Any pos test | | 573
Antman | 1998 | Any post test | 116
Apple | 1995 | Initial pos test | | 12
Bakker | 1993b | Any pos test | 207
Bakker | 1993a | 2 of 3 pos tests | 134
Benamer | 1998 | Any pos test | | 60
Brscic | 1998 | Any pos test | | 22
Chang | 1998 | Not stated | | 40
Christenson | 1998 | Initial pos test | | 220
D'Costa | 1997 | Initial pos test | | 53
de Winter | 1996 | Any pos test | 24
de Filippi | 1998 | Initial pos test | 39
Galvani | 1997 | Any pos test | | 22
Gerhardt | 1993 | Any pos test | 116
Gerhardt | 1997b | Unclear | 33
Gerhardt | 1997a | Any pos test | 310
Gokhan Cin | 1996 | First two samples | 24
Green | 1998 | Initial pos test | 25
Gust | 1998 | Initial pos test | 5
Hamm | 1992 | Any pos test | 33
Hamm | 1997 | Any pos test | 123 | 171
Heeschen | 1998 | Any pos test | | 462
Hetland | 1996 | Initial pos test | 44
Hetland | 1998 | Initial pos test | 68 | 68
Katus | 1991 | Any pos test | 225
Kost | 1998 | Any pos test | 11 | 9
Koukkunen | 1998 | Any pos test | 186
Laurino | 1997 | Initial pos test
Lindahl | 1996 | Any pos test | 399
Luscher | 1997 | Any pos test up to 6 hours | 249 | 213
Luscher | 1998 | Any pos test | 35
Mockel | 1998 | Any pos test | 11
Mohler | 1998 | Any pos test | 31
Ohman | 1996 | Initial pos test | 131
Olatidoye | 1998 | Initial pos test | 14 | 13
Pettijohn | 1997 | Any pos test | 35
Polanczyk | 1998 | Any pos test | | 233
Ravkilde | 1993 | Any pos test | 44
Ravkilde | 1995 | Any pos test | 25
REACTT Study | 1997 | Any pos test | 91
Rebuzzi | 1998 | Initial pos test | 14
Sayre | 1998 | Any pos test | 84
Seino | 1993 | Any pos test | 14
Seino | 1996 | Any pos test | 23
Stokke | 1998 | 2 of 3 pos tests | 6 | 4
Stork | 1997 | Unclear | 11
Stubbs | 1996 | Initial pos test | 62
Tucker | 1997 | Initial pos test | 26 | 4
Wu | 1995 | Initial pos test | 27
Yang | 1995 | Any pos test | 34

Evidence Table 26. Myocardial infarction during admission

Author | Year | No. of Patients | MIs During Admission | MIs with Pos Troponin T | MIs with Pos Troponin I
Adams | 1994 | 188 | 89 | | 86
Antman | 1995 | 100 | 34 | 22
Antman | 1996 | 1,401 | 453 | | 335
Antman | 1998 | 597 | 10 | 2
Apple | 1995 | 107 | 17 | | 6
Bakker | 1993b | 290 | 153 | 98
Bakker | 1993a | 297 | 155 | 155
Benamer | 1998 | 195 | 11 | | 9
Chang | 1998 | 110 | 41 | | 37
Christenson | 1998 | 770 | 559 | | 199
D'Costa | 1997 | 316 | 62 | | 49
Galvani | 1997 | 91 | 8 | | 4
Gerhardt | 1993 | 207 | 106 | 103
Gerhardt | 1997b | 87 | 27 | 27
Gerhardt | 1997a | 502 | 251 | 251
Gokhan Cin | 1996 | 72 | 14 | 12
Gust | 1998 | 68 | 16 | 4
Hamm | 1992 | 84 | 14 | 13
Hamm | 1997 | 773 | 9 | 7 | 9
Heeschen | 1998 | 637 | 159 | | 156
Hetland | 1996 | 133 | 45 | 24
Hetland | 1998 | 170 | 68 | 68 | 68
Katus | 1991 | 387 | 177 | 177
Kost | 1998 | 54 | 10 | 9 | 9
Koukkunen | 1998 | 624 | 89 | 89
Laurino | 1997 | 115 | 25 | | 8
Luscher | 1998 | 92 | 35 | 34
Mockel | 1998 | 106 | 14 | 7
Mohler | 1998 | 100 | 21 | 21
Polanczyk | 1998 | 1,047 | 142 | | 119
REACTT Study | 1997 | 721 | 102 | 71
Sayre | 1998 | 667 | 34 | 33
Seino | 1993 | 22 | 2 | 2
Seino | 1996 | 35 | 5 | 5
Stokke | 1998 | 22 | 3 | 1 | 3
Stork | 1997 | 19 | 4 | 4
Tucker | 1997 | 177 | 27 | 9 | 1
Yang | 1995 | 94 | 11 | 11

Evidence Table 27. Deaths during admission

Author | Year | No. of Patients | Death Definition | Deaths | Deaths with Pos T | Deaths with Pos I
Antman | 1998 | 597 | Total death | 9 | 2
Benamer | 1998 | 195 | Total death | 1 | | 1
Christenson | 1998 | 770 | Total death | 50 | | 26
Galvani | 1997 | 91 | Cardiac death | 2 | | 2
Gokhan Cin | 1996 | 72 | Total death | 8 | 7
Hamm | 1992 | 84 | Total death | 6 | 5
Hamm | 1997 | 773 | Cardiac death | 11 | 9 | 11
Mockel | 1998 | 106 | Total death | 1 | 1

Evidence Table 28. Composite endpoint during admission

Author | Year | No. of Patients | Definition of CE | CE During Adm | CE with Pos Troponin T | CE with Pos Troponin I
Antman | 1995 | 100 | Death or MI | 7 | 5
Antman | 1998 | 597 | Death, MI, or recurrent angina | 147
Benamer | 1998 | 100 | Death, MI, PTCA, or CABG | 23 | | 14
Christenson | 1998 | 770 | Death, MI, PTCA, or CABG | 642 | | 209
Hamm | 1992 | 84 | Death or MI | 11 | 10
Hamm | 1997 | 773 | Cardiac death or MI | 20 | 16 | 20
Polanczyk | 1998 | 1,047 | Multiple events | 94 | | 44
Ravkilde | 1993 | 127 | Cardiac death or MI | 9 | 6
Seino | 1993 | 22 | MI, PTCA, CABG | 8 | 8
Seino | 1996 | 35 | MI or PTCA | 13 | 12
Yang | 1995 | 94 | Death or MI | 12 | 11

Evidence Table 29. Angioplasty during admission

Author | Year | No. of Patients | PTCA During Admission | PTCA with Pos Troponin T | PTCA with Pos Troponin I
Benamer | 1998 | 100 | 68 | | 25
Gokhan Cin | 1996 | 54 | 23 | 10
Hamm | 1992 | 84 | 31 | 16
Mockel | 1998 | 106 | 6 | 1
Seino | 1993 | 22 | 5 | 5

Evidence Table 30. Bypass grafting (CABG) during admission

Author | Year | No. of Patients | CABG During Admission | CABG with Pos Troponin T | CABG with Pos Troponin I
Benamer | 1998 | 100 | 11 | | 6
Gokhan Cin | 1996 | 54 | 7 | 4
Hamm | 1992 | 84 | 17 | 8
Mockel | 1998 | 106 | 20 | 1
Seino | 1993 | 22 | 1 | 1

Evidence Table 31. Myocardial infarction during followup

Author | Year | No. of Patients | Followup (weeks) | MIs During Followup | MIs with Pos Troponin T | MIs with Pos Troponin I
Antman | 1998 | 597 | 2 | 10 | 2
Brscic | 1998 | 92 | 4 | 1 | | 1
de Winter | 1996 | 170 | 26 | 2 | 1
deFilippi | 1998 | 171 | 52 | 5 | 2
Galvani | 1997 | 91 | 4 | 8 | | 4
Gokhan Cin | 1996 | 102 | 1 | 14 | 12
Hamm | 1997 | 773 | 4 | 5 | 4 | 4
Luscher | 1997 | 516 | 4 | 34 | 22 | 18
Mockel | 1998 | 106 | 12 | 16 | 7
Olatidoye | 1998 | 107 | 4 | 8 | 5 | 5
Pettijohn | 1997 | 129 | 24 | 8 | 4
Ravkilde | 1993 | 127 | 24 | 5 | 3
Ravkilde | 1995 | 124 | 112 | 5 | 3
Rebuzzi | 1998 | 102 | 12 | 15 | 7
Wu | 1995 | 131 | 3 | 11 | 8

Evidence Table 32. Death during followup

Author | Year | No. of Patients | Followup (weeks) | Death Definition | Deaths | Deaths with Pos Troponin T | Deaths with Pos Troponin I
Antman | 1996 | 1,404 | 6 | Total death | 29 | | 21
Antman | 1998 | 597 | 2 | Total death | 9 | 2
Benamer | 1998 | 195 | 1 | Total death | 1 | | 1
Brscic | 1998 | 92 | 4 | Total death | 4 | | 2
Christenson | 1998 | 770 | 4 | Total death | 50 | | 26
deFilippi | 1998 | 171 | 52 | Cardiac death | 4 | 4
Galvani | 1997 | 91 | 4 | Cardiac death | 2 | | 2
Gokhan Cin | 1996 | 72 | 1 | Total death | 8 | 6
Hamm | 1992 | 84 | 1 | Total death | 6 | 5
Hamm | 1997 | 773 | 4 | Cardiac death | 20 | 16 | 19
Lindahl | 1996 | 581 | 20 | Cardiac death | 13 | 13
Luscher | 1997 | 516 | 4 | Cardiac death | 9 | 8 | 7
Mockel | 1998 | 106 | 12 | Total death | 3 | 1
Ohman | 1996 | 320 | 4 | Total death | 17 | 13
Pettijohn | 1997 | 129 | 24 | Cardiac death | 5 | 2
Ravkilde | 1993 | 127 | 24 | Cardiac death | 4 | 3
Ravkilde | 1995 | 124 | 112 | Cardiac death | 6 | 3
Rebuzzi | 1998 | 102 | 12 | Total death | 1 | 1
Stubbs | 1996 | 183 | 147 | Cardiac death | 26 | 12

Evidence Table 33. Composite endpoint during followup

Author | Year | No. of Patients | Followup (weeks) | Definition of CE | CE During Followup | CE with Pos Troponin T | CE with Pos Troponin I
Antman | 1995 | 100 | 1 | Death or MI | 7 | 5
Antman | 1998 | 597 | 2 | Death, MI, or recurrent angina | 147 | 39
Benamer | 1998 | 195 | 1 | Death, MI, PTCA, or CABG | 23 | | 14
Brscic | 1998 | 92 | 4 | Death, MI, PTCA, or CABG | 47 | | 13
Christenson | 1998 | 770 | 4 | Death, MI, PTCA, or CABG | 642 | | 209
de Winter | 1996 | 170 | 26 | Cardiac death, MI, PTCA, or CABG | 24 | 8
de Filippi | 1998 | 171 | 52 | Cardiac death or MI | 9 | 6
Galvani | 1997 | 91 | 4 | Cardiac death or MI | 9 | | 5
Green | 1998 | 268 | 2 | Multiple events | 45 | 14
Hamm | 1992 | 84 | 1 | Death or MI | 11 | 10
Hamm | 1997 | 773 | 4 | Cardiac death or MI | 20 | 11 | 12
Lindahl | 1996 | 581 | 20 | Cardiac death or MI | 59 | 51
Luscher | 1997 | 516 | 4 | Cardiac death or MI | 39 | 27 | 23
Luscher | 1998 | 92 | 12 | Cardiac death or MI | 9 | 7
Olatidoye | 1998 | 107 | 4 | Death or MI | 8 | 5 | 5
Pettijohn | 1997 | 129 | 24 | Cardiac death, MI, or CABG | 23 | 12
Polanczyk | 1998 | 1,047 | 1 | Multiple events | 94 | | 44
Ravkilde | 1993 | 127 | 24 | Cardiac death or MI | 9 | 6
Ravkilde | 1995 | 124 | 112 | Cardiac death or MI | 11 | 6
Rebuzzi | 1998 | 102 | 12 | Death or MI | 15 | 7
Sayre | 1998 | 588 | 9 | Multiple events | 50 | 21
Seino | 1993 | 22 | 1 | MI, PTCA, CABG | 8 | 8
Seino | 1996 | 35 | 1 | MI or PTCA | 13 | 12
Stubbs | 1996 | 183 | 147 | Death or MI | 39 | 18
Wu | 1995 | 131 | 3 | Multiple events | 92 | 26
Yang | 1995 | 94 | 1 | Death or MI | 12 | 11

Evidence Table 34. Angioplasty during followup

Author | Year | No. of Patients | Followup (weeks) | PTCAs During Followup | PTCAs with Pos Troponin T | PTCAs with Pos Troponin I
Christenson | 1998 | 770 | 4 | 248 | | 56
de Winter | 1996 | 170 | 26 | 18 | 6
Luscher | 1997 | 516 | 4 | 51 | 25 | 22
Ohman | 1996 | 320 | 4 | 94 | 38
Ravkilde | 1993 | 127 | 24 | 3 | 2
Stubbs | 1996 | 183 | 147 | 16 | 8

Evidence Table 35. Bypass grafting during followup

Author | Year | No. of Patients | Followup (weeks) | CABGs During Followup | CABGs with Pos Troponin T | CABGs with Pos Troponin I
Christenson | 1998 | 770 | 4 | 131 | | 37
de Winter | 1996 | 170 | 26 | 3 | 1
Luscher | 1997 | 516 | 4 | 51 | 25 | 22
Ohman | 1996 | 320 | 4 | 62 | 25
Pettijohn | 1997 | 129 | 24 | 10 | 6
Ravkilde | 1993 | 127 | 24 | 11 | 7
Stubbs | 1996 | 183 | 147 | 32 | 14

Evidence Table 36. Randomized studies comparing protocols in chest pain units with routine hospital care

Author | Year | Intervention N | Control N | Eligibility Criteria | Intervention | Control | Followup
Farkouh | 1998 | 212 | 212 | Intermediate risk ^1^ | Chest pain unit protocol | Routine hospital admission | 30 days 6 months
Gomez | 1996 | 50 | 50 | Low risk ^2^ | ED-based rapid rule-out protocol in chest pain unit | Routine hospital care | 30 days
Roberts | 1997 | 82 | 83 | Low risk ^2^ | ED-based accelerated diagnostic protocol (ADP) | Telemetry unit | 2 weeks 8 weeks

1 AHRQ Guidelines: Unstable angina defined as angina symptoms at rest >20 min; new onset angina on exertion meeting Canadian Cardiovascular Society Class (CCSC) >3; recent acceleration of preexisting angina to at least CCSC 3; variant angina or post-MI angina.

2 Predicted probability of infarction: <7% as determined by Goldman algorithm (1988).

Evidence Table 37. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Baseline characteristics

Author, Year | Percent with Prior MI | | Percent with Diabetes | | Percent with Hypertension | | Percent with Smoking History
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Intervention | Control
Farkouh, 1998 | 13.7 | 15.1 | 7.6 | 10.8 | 36.3 | 41 | 17.0 | 13.7
Gomez, 1996 | NA | NA | 0 | 10 | 30 | 44 | 22 | 16
Roberts, 1997 | NA | NA | 8.5 | 14.5 | 43.9 | 43.4 | 56.1 | 49.4

Evidence Table 38. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Preliminary intervention protocol

Author, Year | Observation | Monitoring | ECG | CK-MB Levels | Positive CK-MB Test | Aspirin | Heparin | Oxygen | IV Access | Nitrates
Farkouh, 1998 | 6 h | Continuous ST-segment monitoring | Baseline | Time 0, 2, 4 h | >9.6 ng/mL | 325 mg | If needed | NA | If needed | No
Gomez, 1996 | NA | Continuous ST-segment monitoring | Printed every 15 min and when ST segment thresholds are exceeded | 0, 3, 6, 9 h | NA | 325 mg | No | For dyspnea oroxygen saturation < 90% | Yes | No
Roberts, 1997 | 12 h | 12 h rhythm monitoring | 0, 6, 12 h | 0, 4, 8, 12 h | >4.7 ng/mL | Yes | No | 2 L by nasal cannula | Yes | If needed

Evidence Table 39. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Indications for admission

Author, Year | Recurrent Chest Pain | Ischemic ECG Changes | Ventricular Arrythma | Positive CK-MB Levels | Positive Stress Test | Positive Imaging | Positive Echo | Other
Farkouh, 1998 | Yes | NA | Yes | >9.6 ng/mL | <5 treadmill | Yes (or equivocal) | NA | Yes
Gomez, 1996 | NA | Yes | NA | Yes | Yes | Yes (or equivocal) | Yes | Yes
Roberts, 1997 | Yes | Yes | NA | >4.7 ng/mL | Yes | NA | NA | NA

Evidence Table 40. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Patients admitted

Author, Year | Intervention | | | Control
Author, Year | Admitted Before Stress Test | Admitted After Stress Test | Total Admitted | Total Admitted
Farkouh, 1998 | 60 (28%) | 55 (26%) | 115 (54%) | 212 (100%)
Gomez, 1996 | 1 (2%) | 1 (2%) | 2 (4%) | 50 (100%)
Roberts, 1997 | 21 (25.6%) | 16 (19.5%) | 37 (45.1%) | 83 (100%)

Evidence Table 41. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Intervention protocol-stress testing

Author, Year | Discharge Critieria | Exercise | Pharmacologic | Nuclear | Echo | Positive Stress Test Definition
Farkouh, 1998 | If negative results during observation ^1^ | Yes | Yes | Yes | Yes | <5 on Duke treadmill scoring OR positive imaging result
Gomez, 1996 | If negative enzyme tests; no ischemic ECG changes | Yes (Cornell protocol) | Yes | No | Yes | Positive or nondiagnostic exercise treadmill test
Roberts, 1997 | If negative clinical or testing findings | Yes (Bruce protocol) | No | No | No | Positive or indeterminate test results

1 Exercise stress testing performed if patient was able to walk on treadmill at rate of at least 2.5 miles/h with no ECG evidence of left ventricular hypertrophy, ventricular paced rhythm, left bundle-branch block, or Wolff-Parkinson-White Syndrome.

Evidence Table 42. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: early outcomes

Author, Year | Intervention N | Control N | Followup | Intervention | | | | Control
Author, Year | Intervention N | Control N | Followup | Composite Endpoints | | | | Composite Endpoints
Author, Year | Intervention N | Control N | Followup | Death | MI | Definition | N | Death | MI | N | P Value
Farkouh, 1998 | 212 | 212 | In hospital and 30-day | 1 | 5 | NA | NA | 0 | 13 | NA | 0.15
Gomez, 1996 | 50 | 50 | In hospital | 0 | 1 | NA | NA | 0 | 1 | NA | NS
Roberts, 1997 | 82 | 83 | In hospital | 0 | 4 | Positive CAD: AMI, ACI, possible ACI, CAD | 22 | 0 | NA | 14 | <0.12

Evidence Table 43. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Death or MI

Author, Year | Intervention N | Control N | Late Outcomes
Author, Year | Intervention N | Control N | Followup | Intervention | | | Control
Author, Year | Intervention N | Control N | Followup | Death | MI | Composite | Death | MI | Composite | P Value
Farkouh, 1998 | 212 | 212 | Keep 30 days & within 6 months | 1 | 2 | NA | 0 | 0 | NA | NA
Gomez, 1996 | 50 | 50 | 30-day | 0 | 0 | NA | 0 | 0 | NA | NS
Roberts, 1997 | 82 | 83 | 2 & 8 week | ^1^ | NA | NA | NA | NA | NA | NA

1 158 patients alive (95.8%) at 8 weeks.

Evidence Table 44. Randomized studies evaluating chest pain units or accelerated diagnostic protocols: Subsequent hospitalization, physician evaluation, and emergency department visits

Author, Year | Followup | Intervention | | | Control
Author, Year | Followup | Rehospitalized | Return to ED | Return to Doctor | Rehospitalized | Return to ED | Return to Doctor | P Value
Farkouh, 1998 | 6 months | NA | 8% | NA | NA | 4.2% | NA | 0.14
Gomez, 1996 | 30 days | NA | 6% | NA | 5% | NA | 2% | NS
Roberts, 1997 | 8 weeks | 6.10% | NA | NA | 4.8% | NA | NA | NS

Evidence Table 45. Randomized studies comparing protocols in chest pain units with routine hospital care: Length of stay

Author, Year | Intervention N | Control N | Length of Stay Intervention Mean (± SD), h | Length of Stay Control Mean (± SD), h | P Value
Farkouh, 1998 | 212 | 212 | 9.2 (median) | 24-72 (range) | NA
Gomez, 1996 | 50 | 50 | 15.4 (SD 12.2) | 54.6 (SD 126) | 0.0001
Roberts, 1997 | 82 | 83 | 33.1 (SD 28.4) | 44.8 (SD 31.8) | <0.01

Evidence Table 46. Randomized studies comparing protocols in chest pain units with routine hospital care: Cost

Author, Year | Cost Analysis Method | Mean Cost of Initial Stay | | | Mean Cost of 30-Day Followup
Author, Year | Cost Analysis Method | Intervention | Control | P Value | Intervention | Control | P Value
Farkouh, 1998 | Resource-based relative-value units | NA | 61% higher cost | NA | NA | NA | NA
Gomez, 1996 | Charges | $1,297 (SD $1,677) | $5,719 (SD $14,668) | 0.0001 | $1,424 (SD $1,735) | $5,860 (SD $14,638) | 0.0001
Roberts, 1997 | Total cost | $1,528 (SD $1,012) | $2,095 (SD $813) | <0.001 | NA | NA | NA

Evidence Table 47. Controlled clinical trials evaluating the use of an acute cardiac ischemia time-intensive predictive instrument

Author, Year | Study Design | No. of Hospitals | Intervention | Control | Intervention N | Control N | Total
Sarasin, 1994 | Controlled trial | 1 | ACI-TIPI | No ACI-TIPI | 294 | 235 | 529
Selker, 1998 | Controlled trial | 10 ^1^ | ACI-TIPI | No ACI-TIPI | 4,738 | 5,951 | 10,689

1 Hospitals were categorized as high-capacity CCU/low-capacity telemetry unit or low-capacity CCU/high-capacity telemetry unit.

Evidence Table 48. Controlled clinical trials evaluating the use of an acute cardiac ischemia time-insensitive predictive instrument: Baseline characteristics

Author, Year | Percent with Prior MI | | Percent with Diabetes | | Percent with Hypertension | | Percent with Smoking History
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Intervention | Control
Sarasin, 1994 | 28 | 30 | 9 | 14 | 37 | 43 | NA | NA
Selker, 1998 | 27 | 26 | 21 | 21 | NA | NA | NA | NA

Evidence Table 49. Trials evaluating the use of an acute cardiac ischemia time-insensitive predictive instrument: Patients

Author, Year | ACI Defined | Patient Characteristics
Author, Year | ACI Defined | Diagnosis of Infarction | | Diagnosis of Angina Pectoris
Author, Year | ACI Defined | Intervention | Control | Intervention | Control
Sarasin, 1994 | AMI, unstable angina, new-onset angina | 94 (32%) | 75 (32%) | 76 ^1^ (26%) | 63 ^1^ (27%)
Selker, 1998 | Unstable angina or acute infarction | 379 (8%) | 476 (8%) | 758 (16%) | 893 (15%)

1 Unstable angina pectoris.

Evidence Table 50. Effect of acute cardiac ischemia time-insensitive predictive instrument on triage patients without acute cardiac ischemia at high-capacity cardiac care unit hospitals (N=3,335)

Author, Year | Percent Admitted to CCU | | Percent Admitted to Non-CCU | | Percent Discharged Home
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Overall P Value
Sarasin, 1994 | NA | NA | NA | NA | NA | NA | NA
Selker, 1998 | 12 | 15 | 36 | 35 | 52 | 49 | 0.09

Evidence Table 51. Effect of acute cardiac ischemia time-insensitive predictive instrument on triage patients without ischemia at low-capacity cardiac care unit hospitals (N=4,815)

Author, Year | Percent Admitted to CCU | | Percent Admitted to Non-CCU | | Percent Discharged Home
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Overall P Value
Sarasin, 1994 | NA | NA | NA | NA | NA | NA | NA
Selker, 1998 | 8 | 7 | 57 | 58 | 34 | 35 | >0.2

Evidence Table 52. Effect of acute cardiac ischemia time-insensitive predictive instrument on triage patients with stable angina in high-capacity cardiac care unit hospitals (N=300)

Author, Year | Percent Admitted to CCU | | Percent Admitted to Non-CCU | | Percent Discharged Home
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Overall P Value
Sarasin, 1994 | NA | NA | NA | NA | NA | NA | NA
Selker, 1998 | 13 | 26 | 65 | 54 | 22 | 20 | 0.02

Evidence Table 53. Effect of acute cardiac ischemia time-insensitive predictive instrument on triage patients with stable angina pectoris at low-capacity cardiac care unit hospitals (N=373)

Author, Year | Percent Admitted to CCU | | Percent Admitted to Non-CCU | | Percent Discharged Home
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Overall P Value
Sarasin, 1994 | NA | NA | NA | NA | NA | NA | NA
Selker, 1998 | 19 | 19 | 60 | 70 | 21 | 10 | 0.02

Evidence Table 54. Effect of acute cardiac ischemia time-insensitive predictive instrument on triage patients with myocardial infarction or unstable angina in high-capacity cardiac care unit hospitals (N=634)

Author, Year | Percent Admitted to CCU | | Percent Admitted to Non-CCU | | Percent Discharged Home
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Overall P Value
Sarasin, 1994 | NA | NA | NA | NA | NA | NA | NA
Selker, 1998 | 62 | 62 | 35 | 35 | 3 | 3 | >0.2

Evidence Table 55. Effect of acute cardiac ischemia time-insensitive predictive instrument on triage patients with myocardial infarction or unstable angina in low-capacity cardiac care unit hospitals (N=1,232)

Author, Year | Percent Admitted to CCU | | Percent Admitted to Non-CCU | | Percent Discharged Home
Author, Year | Intervention | Control | Intervention | Control | Intervention | Control | Overall P Value
Sarasin, 1994 | NA | NA | NA | NA | NA | NA | NA
Selker, 1998 | 44 | 43 | 52 | 54 | 3 | 2 | >0.2

Evidence Table 56. Effect of acute cardiac ischemia time-insensitive predictive instrument on 30-day mortality

Author, Year | Intervention | Control | P Value
Sarasin, 1994 | 24/294 (8%) | 21/235 (9%) | NS
Selker, 1998 | 116/4,478 (2.6%) | 137/5,638 (2.4%) | >0.2

Evidence Table 57. Effect of acute cardiac ischemia time-insensitive predictive instrument on 30-day rehospitalization

Author, Year | Intervention | Control | P Value
Sarasin, 1994 | NA | NA | NA
Selker, 1998 | 10.40% | 9.10% | 0.2

Evidence Table 58. Effect of acute cardiac ischemia time-insensitive predictive instrument on time to triage: Emergency department presentation to emergency department discharge

Author, Year | Patients Diagnosed with ACI | | | Patients Diagnosed without ACI
Author, Year | Intervention | Control | P Value | Intervention | Control | P Value
Sarasin, 1994 | 4.4 h | 4.2 h | NS | 3.6 h | 4.3 h | NS
Selker, 1998 | NA | NA | NA | NA | NA | NA