# Summary Tables

Summary Table 1. Summary findings for independent clinical and ECG predictors of adverse outcomes (death, MI, major complications): Chest pain suspicious for cardiac ischemia

Summary Table 1. Summary findings for independent clinical and ECG predictors of adverse outcomes (death, MI, major complications): Chest pain suspicious for cardiac ischemia

Category | Possible Independent Risk Factor for Adverse Outcome ^1^ | Not Significantly Associated with Outcomes ^2^
Demographic features | Increasing age (5/7) Male gender (3/7) | Race (2/2)
Medical history | Prior MI (2/6) Diabetes (2/4) CHF (1/3) HTN (1/4) Smoking (1/4) | Prior stable angina (3/3) Prior CABG (1/1)
Symptom characteristics | Typical angina (1/2) Duration (1/3) | Pressing or crushing (2/2) Radiation pattern (1/1) Comparison with prior angina (1/1) Constant or dull (1/1) Episodic (1/1) Sharp or pleuritic (1/1) Nausea (1/1) Pleuritic (1/1) Diaphoresis (1/1) Dyspnea (1/1)
Initial physical exam | CHF on admission (1/3) Blood pressure (1/3) | Heart rate (2/2)
Electrocardiogram ^3^ | ST depression (1/4) ST-T changes (1/2) Any evidence of ischemia (1/1) | T-wave inversions (2/2)
Miscellaneous | Shock after admission (1/1) S_3_ (1/2) | Atypical chest pain (1/1) Cyanosis (1/1) S_4_ (1/1) Chest wall tenderness (1/1) Marital status (1/1) Family history of coronary artery disease (1/1) Peripheral edema (1/1) Hypercholesterolemia (1/1)

1 Parentheses refer to number of studies where finding was observed over the number of studies where the variable was evaluated. Listed variables were found to be significant in at least one study.

2 Not found to be significant in final multivariate model based on each individual study's criteria for selection and statistical significance.

3 A normal electrocardiogram on presentation was a strong protective factor against adverse cardiac outcome in one study.Data from Lee, Ting, Shammash, et al., 1992, used from the Multicenter Chest Pain Study for risk factors of age and prior MI. Gender data from Cunningham, Lee, Cook et al., 1989.

Summary Table 2. Summary findings for independent clinical and ECG predictors of adverse outcomes (death, MI, major complications): Diagnosed unstable angina

Summary Table 2. Summary findings for independent clinical and ECG predictors of adverse outcomes (death, MI, major complications): Diagnosed unstable angina

Category | Possible Independent Risk Factor of Adverse Outcome ^1^ | Not Significantly Associated with Outcomes ^2^
Demographic features | Increasing age (7/8) Gender (2/9) ^3^ | Race/ethnicity (4/4)
Medical history | Prior MI (4/9) Diabetes (5/7) Hypertension (2/7) Absence of prior revascularization (1/1) Prior CABG (1/2) Prior CHF (1/4) Prior angina (1/5) | Smoking (5/5) Prior PTCA (1/1) Prior stroke (1/1)
Symptom characteristics | Postinfarction angina (1/2) Rest pain after admission (1/2) Rest angina within 48 h before admission (1/1) | Frequency (1/1) Rest pain < or >48 h (1/1)
Initial physical exam | CHF on presentation (2/4) Heart rate (1/1) Blood pressure (1/2)
Electrocardiogram | ST depression >0.1 mV (2/3) ST deviation > 0.5 mV (1/1) Evolutionary T-wave changes (1/1) Left bundle branch block (1/2) | T-wave inversion (3/3) Transient ST-T changes (1/1) Abnormal ECG (1/1) Right bundle branch block (1/1) Old Q wave (1/1)
Miscellaneous | No prior beta-blocker therapy (2/4) Requiring IV NTG (2/2) Recurrent severe chest pain (2/2) Maximal antianginal therapy (1/1) Thrombolysis in prior week (1/1) Other major illness (1/1) Nitrate use in week before admission (1/1) | Calcium blocker therapy (2/2) Positive family hx (1/1) Exacerbating condition (1/1) Charlson comorbidity score (1/1) Cardiogenic shock (1/1) NQWMI at entry (1/1) Unstable angina class (1/1)

1 Parentheses refer to number of studies where finding was observed over the number of studies where the variable was evaluated.

2 Not found to be significant in final multivariate model based on each individual study's criteria for selection and statistical significance.

3 One study found male gender to be associated with worse outcomes, and a second found female gender to be associated with worse outcomes.NQWMI = Non-Q-wave myocardial infarction.

Summary Table 3. Risk of death with positive troponin T

Summary Table 3. Risk of death with positive troponin T

Author | Year | Followup (weeks) | Mortality | Abs. Risk Diff. ^1^ | Relative Risk | Lower RR CI | Upper RR CI
Antman | 1998 | 2 | 1.5% | 0.3% | 1.18 | 0.25 | 5.63
Gokhan Cin | 1996 | 1 | 11.1% | 20.8% | 6.00 | 1.31 | 27.53
Hamm | 1992 | 1 | 7.1% | 13.2% | 7.73 | 0.94 | 63.23
Hamm | 1997 | 4 | 2.6% | 12.4% | 21.14 | 7.19 | 62.16
Luscher | 1997 | 4 | 1.7% | 2.8% | 8.58 | 1.08 | 68.10
Mockel | 1998 | 12 | 2.8% | 7.0% | 4.32 | 0.43 | 43.85
Ohman | 1996 | 4 | 5.3% | 7.8% | 4.69 | 1.56 | 14.06
Pettijohn | 1997 | 24 | 3.9% | 2.5% | 1.79 | 0.31 | 10.27
Ravkilde | 1993 | 24 | 3.1% | 5.6% | 5.66 | 0.61 | 52.81
Ravkilde | 1995 | 112 | 4.8% | 9.0% | 3.96 | 0.85 | 18.45
Stubbs | 1996 | 147 | 14.2% | 7.8% | 1.67 | 0.82 | 3.39

1 Difference in mortality between troponin positive and negative patients.

Summary Table 4. Risk of death with positive troponin I

Summary Table 4. Risk of death with positive troponin I

Author | Year | Followup (weeks) | Mortality | Abs. Risk Diff. ^1^ | Relative Risk | Lower RR CI | Upper RR CI
Antman | 1996 | 6 | 1.5% | 2.7% | 3.81 | 1.70 | 8.53
Brscic | 19981 | 4 | 2.2% | 6.2% | 3.18 | 0.48 | 21.29
Christenson | 1998 | 4 | 3.4% | 7.5% | 2.71 | 1.59 | 4.61
Hamm | 1997 | 4 | 2.5% | 10.9% | 66.89 | 9.02 | 496.09
Luscher | 1997 | 4 | 1.4% | 2.6% | 4.98 | 1.04 | 23.73

1 Difference in mortality between troponin positive and negative patients.

Summary Table 5. Risk of death or MI with positive troponin T

Summary Table 5. Risk of death or MI with positive troponin T

Author | Year | Followup (weeks) | Mortality | Abs. Risk Diff. ^1^ | Relative Risk | Lower RR CI | Upper RR CI
Antman | 1995 | 1 | 7.0% | 15.8% | 6.76 | 1.39 | 32.79
DeFilippi | 1998 | 52 | 5.3% | 13.1% | 6.77 | 1.77 | 25.83
Hamm | 1992 | 1 | 13.1% | 28.3% | 15.45 | 2.07 | 115.17
Hamm | 1997 | 4 | 2.6% | 7.6% | 6.46 | 2.73 | 15.26
Lindahl | 1996 | 20 | 10.2% | 8.4% | 2.91 | 1.41 | 6.00
Luscher | 1997 | 4 | 7.6% | 6.3% | 2.41 | 1.25 | 4.66
Luscher | 1998 | 12 | 9.8% | 16.5% | 5.70 | 1.25 | 25.91
Olatidoye | 1998 | 4 | 7.5% | 32.5% | 11.07 | 2.97 | 41.30
Ravkilde | 1995 | 112 | 8.9% | 18.9% | 4.75 | 1.58 | 14.32
Rebuzzi | 1998 | 12 | 14.7% | 40.9% | 5.50 | 2.37 | 12.78
Stubbs | 1996 | 147 | 21.3% | 11.7% | 1.67 | 0.97 | 2.90
Yang | 1995 | 1 | 12.8% | 30.7% | 19.41 | 2.62 | 143.93

1 Difference in mortality between troponin positive and negative patients.

Summary Table 6. Risk of death or MI with positive troponin I

Summary Table 6. Risk of death or MI with positive troponin I

Author | Year | Followup (weeks) | Mortality | Abs. Risk Diff. ^1^ | Relative Risk | Lower RR CI | Upper RR CI
Galvani | 1997 | 4 | 9.9% | 16.9% | 3.92 | 1.15 | 13.33
Hamm | 1997 | 4 | 2.6% | 5.7% | 5.28 | 2.19 | 12.71
Luscher | 1997 | 4 | 7.6% | 5.5% | 2.04 | 1.11 | 3.78
Olatidoye | 1998 | 4 | 7.5% | 35.3% | 12.05 | 3.26 | 44.60

1 Difference in mortality between troponin positive and negative patients.

Summary Table 7. Subgroup analysis of the risk of death associated with a positive troponin test

Summary Table 7. Subgroup analysis of the risk of death associated with a positive troponin test

Subgroup | Negative Troponin Events/Total | Positive Troponin Events/Total | Summary Relative Risk | 95% Confidence Interval | Number of Trials
Troponin T
Total death | 32/1,187 | 46/473 | 3.1 | 2.0-4.9 | 5
Cardiac death | 31/1,689 | 52/744 | 3.8 | 2.4-6.0 | 7
Unstable angina patients ^1^ | 21/397 | 26/198 | 2.5 | 1.4-4.5 | 5
Chest pain patients ^1^ | 42/2,479 | 72/1,019 | 4.0 | 2.7-5.9 | 7
Troponin I
Total death | 34/1,451 | 49/815 | 3.1 | 2.0-4.9 | 3
Cardiac death | 3/905 | 26/384 | 25 | 11-55 | 2
Unstable angina patients ^1^ | 2/70 | 2/22 | 3.2 | 0.3-40 | 1
Chest pain patients ^1^ | 35/2,286 | 73/1,177 | 5.1 | 3.4-7.6 | 4
Troponin T and I Combined ^2^
Total death | 42/2,088 | 69/1,068 | 3.3 | 2.2-4.8 | 7
Cardiac death | 28/1,641 | 55/792 | 5.0 | 3.2-7.9 | 7

1 Outcomes of cardiac death and total death are pooled.

2 Some studies provided both troponin T and I data. For the combined analysis, data from one marker were chosen randomly.

Summary Table 8. Subgroup analysis of the risk of death or myocardial infarction associated with a positive troponin test in patients with unstable angina

Summary Table 8. Subgroup analysis of the risk of death or myocardial infarction associated with a positive troponin test in patients with unstable angina

Subgroup | Negative Troponin Events/Total | Positive Troponin Events/Total | Summary Odds Ratio | 95% Confidence Interval | Number of Trials
Troponin T | 43/667 | 62/301 | 3.7 | 2.5-5.6 | 5
Troponin I | 7/163 | 10/35 | 5.7 | 1.8-19 | 2
Troponin T and I Combined ^1^ | 47/737 | 67/322 | 3.8 | 2.6-5.5 | 6

1 One study provided both troponin T and I data. For the combined analysis, data from one marker were chosen randomly.