# Bibliography

Adams JE 3rd, Schechtman KB, Landt Y, et al. Comparable detection of acute myocardial infarction by creatine kinase MB isoenzyme and cardiac troponin I. Clin Chem. 1994;40(7 Pt 1):1291-5. [pmid: 8013101].
Alonsozana GL, Christenson RH. The case for cardiac troponin T: Marker for effective risk stratification of patients with acute cardiac ischemia. Clin Chem. 1996;42(5):803-8. [pmid: 8653918].
Amsterdam EA, Lewis WR. Identification of low risk patients with chest pain in the emergency department: Another look at cardiac troponins. J Am Coll Cardiol. 1998;32(1):15-6. [pmid: 9669243].
Antman EM, Grudzien C, Sacks DB. Evaluation of a rapid bedside assay for detection of serum cardiac troponin T. JAMA. 1995;273(16):1279-82. [pmid: 7715040].
Antman EM, Sacks DB, Rifai N, et al. Time to positivity of a rapid bedside assay for cardiac-specific troponin T predicts prognosis in acute coronary syndromes: A thrombolysis in myocardial infarction (TIMI) 11A substudy. J Am Coll Cardiol. 1998;31(2):326-30. [pmid: 9462575].
Antman EM, Tanasijevic MJ, Thompson B, et al. Cardiac-specific troponin I levels to predict the risk of mortality in patients with acute coronary syndromes. N Engl J Med. 1996;335(18):1342-9. [pmid: 8857017].
Apple FS, Voss E, Lund L, et al. Cardiac troponin, CK-MB and myoglobin for the early detection of acute myocardial infarction and monitoring of reperfusion following thrombolytic therapy. Clin Chim Acta. 1995;237(1-2):59-66. [pmid: 7664479].
Armstrong PW, Fu Y, Chang WC, et al. Acute coronary syndromes in the GUSTO-IIb trial: Prognostic insights and impact of recurrent ischemia. The GUSTO-IIb Investigators. Circulation. 1998;98(18):1860-8. [pmid: 9799205].
Aufderheide TP, Hendley GE, Thakur RK, et al. The diagnostic impact of prehospital 12-lead electrocardiography. Ann Emerg Med. 1990;19(11):1280-7. [pmid: 2240725].
Aufderheide TP, Kereiakes DJ, Weaver WD, et al. Planning, implementation, and process monitoring for prehospital 12-lead ECG diagnostic programs. Prehospital Disaster Med. 1996;11(3):162-71. [pmid: 10163378].
Ayres SM The electrocardiogram in the acute coronary syndromes J Am Coll Cardiol 1990 16(4) 1026 8View this and related citations using 2212354
Bakker AJ, Gorgels JP, van Vlies B, et al. The mass concentrations of serum troponin T and creatine kinase-MB are elevated before creatine kinase and creatine kinase-MB activities in acute myocardial infarction. Eur J Clin Chem Clin Biochem. 1993a;31(11):715-24.
Bakker AJ, Koelemay MJ, Gorgels JP, et al. Failure of new biochemical markers to exclude acute myocardial infarction at admission. Lancet. 1993b;342(8881):1220-2.
Bakker AJ, Koelemay MJ, Gorgels JP, et al. Troponin T and myoglobin at admission: Value of early diagnosis of acute myocardial infarction. Eur Heart J. 1994;15(1):45-53.
Barish RA, Doherty RJ, Browne BJ. Reengineering the emergency evaluation of chest pain. J Healthc Qual. 1997;19(5):6-12; quiz 60.
Bell MR, Montarello JK, Steele PM. Does the emergency room electrocardiogram identify patients with suspected myocardial infarction who are at low risk of acute complications?. Aust N Z J Med. 1990;20(4):564-9. [pmid: 2222349].
Benamer H, Steg PG, Benessiano J, et al. Comparison of the prognostic value of C-reactive protein and troponin I in patients with unstable angina pectoris. Am J Cardiol. 1998;82(7):845-50. [pmid: 9781965].
Bertolet BD, Dinerman J, Hartke R Jr, et al. Unstable angina: Relationship of clinical presentation, coronary artery pathology, and clinical outcome. Clin Cardiol. 1993;16(2):116-22. [pmid: 8435924].
Betriu A, Heras M, Cohen M, et al Unstable angina: Outcome according to clinical presentation J Am Coll Cardiol 1992 19(7) 1659 63View this and related citations using 1593063
Braunwald E, Jones RH, Mark DB, et al. Diagnosing and managing unstable angina. Agency for Health Care Policy and Research. Circulation. 1994;90(1):613-22. [pmid: 8026048].
Braunwald E, Maseri A, Armstrong PW, et al. Rationale and clinical evidence for the use of GP IIb/IIIa inhibitors in acute coronary syndromes. Eur Heart J. 1998;19 Suppl D:D22-D30. [pmid: 9597519].
Bresler MJ, Gibler WB. Acute myocardial infarction: Subtleties of diagnosis in the emergency department. Ann Emerg Med. 1990;Suppl:1-15. [pmid: 2301786].
Brscic E, Chiappino I, Bergerone S, et al. Prognostic implications of detection of troponin I in patients with unstable angina pectoris. Am J Cardiol. 1998;82(8):971-3. [pmid: 9794354].
Bugiardini R, Borghi A, Sassone B, et al. Prognostic significance of silent myocardial ischemia in variant angina pectoris. Am J Cardiol. 1991;68(17):1581-6. [pmid: 1746457].
Cairns JA, Singer J, Gent M, et al. One year mortality outcomes of all coronary and intensive care unit patients with acute myocardial infarction, unstable angina or other chest pain in Hamilton, Ontario, a city of 375,000 people. Can J Cardiol. 1989;5(5):239-46. [pmid: 2758367].
Califf RM, Mark DB, Harrell FE Jr, et al Importance of clinical measures of ischemia in the prognosis of patients with documented coronary artery disease J Am Coll Cardiol 1988 11(1) 20 6View this and related citations using 3335698
Calvin JE, Klein LW, VandenBerg BJ, et al. Risk stratification in unstable angina. Prospective validation of the Braunwald classification. JAMA. 1995;273(2):136-41. [pmid: 7799494].
Cannon CP, McCabe CH, Stone PH, et al The electrocardiogram predicts one-year outcome of patients with unstable angina and non-Q wave myocardial infarction: Results of the TIMI III Registry ECG Ancillary Study. Thrombolysis in Myocardial Ischemia J Am Coll Cardiol 1997 30(1) 133 40View this and related citations using 9207634
Castaner A, Roig E, Serra A, et al. Risk stratification and prognosis of patients with recent onset angina. Eur Heart J. 1990;11(10):868-75. [pmid: 2265639].
Chang CC, Ip MP, Hsu RM, et al. Evaluation of a proposed panel of cardiac markers for the diagnosis of acute myocardial infarction in patients with atraumatic chest pain. Arch Pathol Lab Med. 1998;122(4):320-4. [pmid: 9648898].
Chin MH, Cook EF, Lee TH, et al. Correlates of major complications and mortality in patients presenting to the emergency department with chest pain and more than bibasilar rales. J Gen Intern Med. 1994;9(12):659-65. [pmid: 7876947].
Christenson RH, Duh SH, Newby LK, et al. Cardiac troponin T and cardiac troponin I: Relative values in short- term risk stratification of patients with acute coronary syndromes. GUSTO-IIa Investigators. Clin Chem. 1998;44(3):494-501. [pmid: 9510853].
Cohen M, Hawkins L, Greenberg S, et al. Usefulness of ST-segment changes in greater than or equal to 2 leads on the emergency room electrocardiogram in either unstable angina pectoris or non-Q-wave myocardial infarction in predicting outcome. Am J Cardiol. 1991;67(16):1368-73. [pmid: 2042567].
Collinson PO, Moseley D, Stubbs PJ, et al. Troponin T for the differential diagnosis of ischaemic myocardial damage. Ann Clin Biochem. 1993;30(Pt 1):11-6. [pmid: 8434860].
Coronado BE, Griffith JL, Beshansky JR, et al. Hospital mortality in women and men with acute cardiac ischemia: A prospective multicenter study. J Am Coll Cardiol. 1997;29(7):1490-6. [pmid: 9180109].
Cunningham MA, Lee TH, Cook EF, et al. The effect of gender on the probability of myocardial infarction among emergency department patients with acute chest pain: A report from the Multicenter Chest Pain Study Group. J Gen Intern Med. 1989;4(5):392-8. [pmid: 2677270].
Davis MA, Keerbs A, Hoffman JR, et al. Admission decisions in emergency department chest pain patients at low risk for myocardial infarction: Patient versus physician preferences. Ann Emerg Med. 1996;28(6):606-11. [pmid: 8953947].
D'Costa M, Fleming E, Patterson MC. Cardiac troponin I for the diagnosis of acute myocardial infarction in the emergency department. Am J Clin Pathol. 1997;108(5):550-5. [pmid: 9353094].
deFilippi CR, Parmar RJ, Potter MA, et al. Diagnostic accuracy, angiographic correlates and long-term risk stratification with the troponin T ultra sensitive rapid assay in chest pain patients at low risk for acute myocardial infarction. Eur Heart J. 1998;19(Suppl N):N42-N47. [pmid: 9857939].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
de Winter RJ, Koster RW, Schotveld JH, et al. Prognostic value of troponin T, myoglobin, and CK-MB mass in patients presenting with chest pain without acute myocardial infarction. Heart. 1996;75(3):235-9. [pmid: 8800984].
Diamond GA, Forrester JS. Analysis of probability as an aid in the clinical diagnosis of coronary-artery disease. N Engl J Med. 1979;300(24):1350-8. [pmid: 440357].
Douglas PS, Ginsburg GS. The evaluation of chest pain in women. N Engl J Med. 1996;334(20):1311-5. [pmid: 8609950].
Dracup K, Alonzo AA, Atkins JM, et al. The physician's role in minimizing prehospital delay in patients at high risk for acute myocardial infarction: Recommendations from the National Heart Attack Alert Program. Working Group on Educational Strategies to Prevent Prehospital Delay in Patients at High Risk for Acute Myocardial Infarction. Ann Intern Med. 1997;126(8):645-51. [pmid: 9103133].
Duncan B, Fulton M, Morrison SL, et al. Prognosis of new and worsening angina pectoris. Br Med J. 1976;1(6016):981-5. [pmid: 1268534].
Farkouh ME, Smars PA, Reeder GS, et al. A clinical trial of a chest-pain observation unit for patients with unstable angina. Chest Pain Evaluation in the Emergency Room (CHEER) Investigators. N Engl J Med. 1998;339(26):1882-8. [pmid: 9862943].
Fesmire FM, Percy RF, Wears RL, et al. Risk stratification according to the initial electrocardiogram in patients with suspected acute myocardial infarction. Arch Intern Med. 1989;149(6):1294-7. [pmid: 2730248].
Fineberg HV, Scadden D, Goldman L. Care of patients with a low probability of acute myocardial infarction. Cost effectiveness of alternatives to coronary-care-unit admission. N Engl J Med. 1984;310(20):1301-7. [pmid: 6425687].
Fleischmann KE, Goldman L, Robiolio PA, et al. Echocardiographic correlates of survival in patients with chest pain. J Am Coll Cardiol. 1994;23(6):1390-6. [pmid: 8176098].
Galvani M, Ottani F, Ferrini D, et al. Prognostic influence of elevated values of cardiac troponin I in patients with unstable angina. Circulation. 1997;95(8):2053-9. [pmid: 9133515].
Gazes PC, Mobley EM Jr, Faris HM Jr, et al. Preinfarctional (unstable) angina-a prospective study-ten year follow-up. Prognostic significance of electrocardiographic changes. Circulation. 1973;48(2):331-7. [pmid: 4726213].
Gerhardt W, Katus H, Ravkilde J, et al. S-troponin T in suspected ischemic myocardial injury compared with mass and catalytic concentrations of S-creatine kinase isoenzyme MB. Clin Chem. 1991;37(8):1405-11. [pmid: 1868602].
Gerhardt W, Ljungdahl L. Detection of myocardial damage by serial measurements of cardiac troponin T, CK MB mass, and TROPT rapid test. Cardiovasc Drugs Ther. 1997;11(Suppl 1):227-40. [pmid: 9211015].
Gerhardt W, Ljungdahl L, Collinson PO, et al. An improved rapid troponin T test with a decreased detection limit: A multicentre study of the analytical and clinical performance in suspected myocardial damage. Scand J Clin Lab Invest. 1997;57(6):549-57. [pmid: 9350075].
Gerhardt W, Ljungdahl L, Herbert AK. Troponin-T and CK MB (mass) in early diagnosis of ischemic myocardial injury. The Helsingborg Study, 1992. Clin Biochem. 1993;26(4):231-40. [pmid: 8242886].
Gibler WB. Chest pain evaluation in the ED: beyond triage. Am J Emerg Med. 1994a;12(1):121-2. [pmid: 8285958].
Gibler WB. Evaluating patients with chest pain in the ED: Improving speed, efficiency, and cost-effectiveness, or teaching an old dog new tricks. Ann Emerg Med. 1994b;23(2):381-2. [pmid: 8304625].
Gibler WB. Evaluation of chest pain in the emergency department. Ann Intern Med. 1995;123(4):317-8.
Gibler WB. Chest pain units: do they make sense now?. Ann Emerg Med. 1997;29(1):168-71. [pmid: 8998100].
Gibler WB, Kereiakes DJ, Dean EN, et al. Prehospital diagnosis and treatment of acute myocardial infarction: A north-south perspective. The Cincinnati Heart Project and the Nashville Prehospital TPA Trial. Am Heart J. 1991;121(1 Pt 1):1-11. [pmid: 1898678].
Gibler WB, Lewis LM, Erb RE, et al. Early detection of acute myocardial infarction in patients presenting with chest pain and nondiagnostic ECGs: Serial CK-MB sampling in the emergency department [published erratum appears in Ann Emerg Med 1991 Apr;20(4):420]. Ann Emerg Med. 1990;19(12):1359-66. [pmid: 2240745].
Gibler WB, Runyon JP, Levy RC, et al. A rapid diagnostic and treatment center for patients with chest pain in the emergency department. Ann Emerg Med. 1995;25(1):1-8. [pmid: 7802357].
Gibler WB, Sayre MR, Levy RC, et al. Serial 12-lead electrocardiographic monitoring in patients presenting to the emergency department with chest pain. J Electrocardiol. 1993;26(Suppl):238-43. [pmid: 8189131].
Gibler WB, Young GP, Hedges JR, et al. Acute myocardial infarction in chest pain patients with nondiagnostic ECGs: Serial CK-MB sampling in the emergency department. The Emergency Medicine Cardiac Research Group. Ann Emerg Med. 1992;21(5):504-12. [pmid: 1570904].
Gokhan Cin V, Gok H, Kaptanoglu B. The prognostic value of serum troponin T in unstable angina. Int J Cardiol. 1996;53(3):237-44. [pmid: 8793576].
Goldman L. Using prediction models and cost-effectiveness analysis to improve clinical decisions: Emergency department patients with acute chest pain. Proc Assoc Am Physicians. 1995;107(3):329-33. [pmid: 8608418].
Goldman L, Cook EF, Brand DA, et al. A computer protocol to predict myocardial infarction in emergency department patients with chest pain. N Engl J Med. 1988;318(13):797-803. [pmid: 3280998].
Goldman L, Cook EF, Johnson PA, et al. Prediction of the need for intensive care in patients who come to the emergency departments with acute chest pain. N Engl J Med. 1996;334(23):1498-504. [pmid: 8618604].
Goldman L, Weinberg M, Weisberg M, et al. A computer-derived protocol to aid in the diagnosis of emergency room patients with acute chest pain. N Engl J Med. 1982;307(10):588-96. [pmid: 7110205].
Gomez MA, Anderson JL, Karagounis LA, et a An emergency department-based protocol for rapidly ruling out myocardial ischemia reduces hospital time and expense: Results of a randomized study (ROMIO) J Am Coll Cardiol 1996 28(1) 25 33View this and related citations using 8752791
Graff L, Joseph T, Andelman R, et al. American College of Emergency Physicians information paper: Chest pain units in emergency departments-a report from the Short-Term Observation Services Section. Am J Cardiol. 1995;76(14):1036-9. [pmid: 7484857].
Graff L, Zun LS, Leikin J, et al. Emergency department observation beds improve patient care: Society for Academic Emergency Medicine debate. Ann Emerg Med. 1992;21(8):967-75. [pmid: 1497166].
Graff LG, Dallara J, Ross MA, et al. Impact on the care of the emergency department chest pain patient from the chest pain evaluation registry (CHEPER) study. Am J Cardiol. 1997;80(5):563-8. [pmid: 9294982].
Green GB, Beaudreau RW, Chan DW, et al. Use of troponin T and creatine kinase-MB subunit levels for risk stratification of emergency department patients with possible myocardial ischemia. Ann Emerg Med. 1998;31(1):19-29. [pmid: 9437337].
Gust R, Gust A, Bottiger BW, et al. Bedside troponin T testing is not useful for early out-of-hospital diagnosis of myocardial infarction. Acta Anaesthesiol Scand. 1998;42(4):414-7. [pmid: 9563859].
Haines DE, Raabe DS, Gundel WD, et al. Anatomic and prognostic significance of new T-wave inversion in unstable angina. Am J Cardiol. 1983;52(1):14-8. [pmid: 6602539].
Hamm CW, Goldmann BU, Heeschen C, et al. Emergency room triage of patients with acute chest pain by means of rapid testing for cardiac troponin T or troponin I. N Engl J Med. 1997;337(23):1648-53. [pmid: 9385123].
Hamm CW, Ravkilde J, Gerhardt W, et al. The prognostic value of serum troponin T in unstable angina. N Engl J Med. 1992;327(3):146-50. [pmid: 1290492].
Hargarten KM, Aprahamian C, Stueven H, et al. Limitations of prehospital predictors of acute myocardial infarction and unstable angina. Ann Emerg Med. 1987;16(12):1325-9. [pmid: 3688592].
Hedges JR, Gibler WB, Young GP, et al. Multicenter study of creatine kinase-MB use: Effect on chest pain clinical decision making. Acad Emerg Med. 1996;3(1):7-15. [pmid: 8749961].
Hedges JR, Young GP, Henkel GF, et al. Serial ECGs are less accurate than serial CK-MB results for emergency department diagnosis of myocardial infarction. Ann Emerg Med. 1992;21(12):1445-50. [pmid: 1443839].
Hedges JR, Young GP, Henkel GF, et al. Early CK-MB elevations predict ischemic events in stable chest pain patients. Acad Emerg Med. 1994;1(1):9-16. [pmid: 7621159].
Hedges L. Fixed effects models. In: Cooper H, Hedges L, editors. The handbook of research synthesis. New York: Russel Sage Foundation; 1994. p. 307-35.
Heeschen C, Goldmann BU, Moeller RH, et al. Analytical performance and clinical application of a new rapid bedside assay for the detection of serum cardiac troponin I. Clin Chem. 1998;44(9):1925-30. [pmid: 9732978].
Heng MK, Norris RM, Singh BM, et al. Prognosis in unstable angina. Br Heart J. 1976;38(9):921-5. [pmid: 134743].
Herlitz J, Karlson BW, Sjolin M, et al. Predictors of death and mode of death among patients with acute chest pain in various age groups. Coron Artery Dis. 1997;8(11-12):719-26. [pmid: 9472462].
Hetland O, Dickstein K. Cardiac markers in the early hours of acute myocardial infarction: Clinical performance of creatine kinase, creatine kinase MB isoenzyme (activity and mass concentration), creatine kinase MM and MB subform ratios, myoglobin and cardiac troponin T. Scand J Clin Lab Invest. 1996;56(8):701-13. [pmid: 9034351].
Hetland O, Dickstein K. Cardiac troponins I and T in patients with suspected acute coronary syndrome: A comparative study in a routine setting. Clin Chem. 1998;44(7):1430-6. [pmid: 9665420].
Hlatky MA. Evaluation of chest pain in the emergency department. N Engl J Med. 1997;337(23):1687-9. [pmid: 9385131].
Hoekstra JW, Gibler WB. Chest pain evaluation units: An idea whose time has come. JAMA. 1997;278(20):1701-2. [pmid: 9388093].
Hoekstra JW, Gibler WB, Levy RC, et al. Emergency-department diagnosis of acute myocardial infarction and ischemia: A cost analysis of two diagnostic protocols. Acad Emerg Med. 1994;1(2):103-10. [pmid: 7621160].
Hoekstra JW, Hedges JR, Gibler WB, et al. Emergency department CK-MB: A predictor of ischemic complications. National Cooperative CK-MB project group. Acad Emerg Med. 1994;1(1):17-27. [pmid: 7621148].
Holmvang L, Luscher MS, Clemmensen P, et al. Very early risk stratification using combined ECG and biochemical assessment in patients with unstable coronary artery disease (A thrombin inhibition in myocardial ischemia [TRIM] substudy). Circulation. 1998;98(19):2004-9. [pmid: 9808597].
Johnson PA, Goldman L, Sacks DB, et al. Cardiac troponin T as a marker for myocardial ischemia in patients seen at the emergency department for acute chest pain. Am Heart J. 1999;137(6):1137-44. [pmid: 10347343].
Karlson BW, Herlitz J, Pettersson P, et al. One-year prognosis in patients hospitalized with a history of unstable angina pectoris. Clin Cardiol. 1993;16(5):397-402. [pmid: 8504573].
Katus HA, Remppis A, Neumann FJ, et al. Diagnostic efficiency of troponin T measurements in acute myocardial infarction. Circulation. 1991;83(3):902-12. [pmid: 1999039].
Kaul S, Abbott RD. Evaluation of chest pain in the emergency department. Ann Intern Med. 1994;121(12):976-8. [pmid: 7661916].
Kereiakes DJ, Weaver WD, Anderson JL, et al. Time delays in the diagnosis and treatment of acute myocardial infarction: A tale of eight cities. Report from the Pre-hospital Study Group and the Cincinnati Heart Project. Am Heart J. 1990;120(4):773-80. [pmid: 2220531].
Kirk JD, Turnipseed S, Lewis WR, et al. Evaluation of chest pain in low-risk patients presenting to the emergency department: The role of immediate exercise testing. Ann Emerg Med. 1998;32(1):1-7. [pmid: 9656941].
Klootwijk P, Hamm C. Acute coronary syndromes: Diagnosis. Lancet. 1999;353(Suppl 2):SII10-SII15. [pmid: 10374760].
Kontos MC, Jesse RL, Schmidt KL, et al. Value of acute rest sestamibi perfusion imaging for evaluation of patients admitted to the emergency department with chest pain. J Am Coll Cardiol. 1997;30(4):976-82. [pmid: 9316527].
Kost GJ, Kirk JD, Omand K. A strategy for the use of cardiac injury markers (troponin I and T, creatine kinase-MB mass and isoforms, and myoglobin) in the diagnosis of acute myocardial infarction. Arch Pathol Lab Med. 1998;122(3):245-51. [pmid: 9823862].
Koukkunen H, Penttila K, Kemppainen A, et al. Troponin T and creatinine kinase isoenzyme MB mass in the diagnosis of myocardial infarction. Ann Med. 1998;30(5):488-96. [pmid: 9814836].
Kowalenko T, Kereiakes DJ, Gibler WB. Prehospital diagnosis and treatment of acute myocardial infarction: A critical review. Am Heart J. 1992;123(1):181-90. [pmid: 1729824].
Kudenchuk PJ, Maynard C, Cobb LA, et al Utility of the prehospital electrocardiogram in diagnosing acute coronary syndromes: The Myocardial Infarction Triage and Intervention (MITI) Project J Am Coll Cardiol 1998 32(1) 17 27View this and related citations using 9669244
Langer A, Freeman MR, Armstrong PW ST segment shift in unstable angina: Pathophysiology and association with coronary anatomy and hospital outcome J Am Coll Cardiol 1989 13(7) 1495 502View this and related citations using 2786015
Larsen GC, Griffith JL, Beshansky JR, et al. Electrocardiographic left ventricular hypertrophy in patients with suspected acute cardiac ischemia-its influence on diagnosis, triage, and short-term prognosis: A multicenter study. J Gen Intern Med. 1994;9(12):666-73. [pmid: 7876948].
Laurino JP, Pelletier TE, Eadry R, et al. Thrombus precursor protein and the measurement of thrombosis in patients with acute chest pain syndrome. Ann Clin Lab Sci. 1997;27(5):338-45. [pmid: 9303172].
Lee HS, Cross SJ, Rawles JM, et al. Patients with suspected myocardial infarction who present with ST depression. Lancet. 1993;342(8881):1204-7. [pmid: 7901530].
Lee TH, Cook EF, Weisberg M, et al. Acute chest pain in the emergency room. Identification and examination of low-risk patients. Arch Intern Med. 1985;145(1):65-9. [pmid: 3970650].
Lee TH, Cook EF, Weisberg MC, et al. Impact of the availability of a prior electrocardiogram on the triage of the patient with acute chest pain. J Gen Intern Med. 1990;5(5):381-8. [pmid: 2231032].
Lee TH, Juarez G, Cook EF, et al. Ruling out acute myocardial infarction. A prospective multicenter validation of a 12-hour strategy for patients at low risk. N Engl J Med. 1991;324(18):1239-46. [pmid: 2014037].
Lee TH, Rouan GW, Weisberg MC, et al. Sensitivity of routine clinical criteria for diagnosing myocardial infarction within 24 hours of hospitalization. Ann Intern Med. 1987;106(2):181-6. [pmid: 3800180].
Lee TH, Ting HH, Shammash JB, et al. Long-term survival of emergency department patients with acute chest pain. Am J Cardiol. 1992;69(3):145-51. [pmid: 1731449].
Lewis WR, Amsterdam EA. Evaluation of the patient with "rule out myocardial infarction.". Arch Intern Med. 1996;156(1):41-5. [pmid: 8526695].
Lindahl B, Venge P, Wallentin L. Relation between troponin T and the risk of subsequent cardiac events in unstable coronary artery disease. The FRISC Study Group. Circulation. 1996;93(9):1651-7. [pmid: 8653870].
Lloyd-Jones DM, Camargo CA Jr, Lapuerta P, et al. Electrocardiographic and clinical predictors of acute myocardial infarction in patients with unstable angina pectoris. Am J Cardiol. 1998;81(10):1182-6. [pmid: 9604942].
Lundin P, Eriksson SV, Fredrikson M, et al. Prognostic information from on-line vectorcardiography in unstable angina pectoris. Cardiology. 1995;86(1):60-6. [pmid: 7728790].
Luscher MS, Ravkilde J, Thygesen K. Clinical application of two novel rapid bedside tests for the detection of cardiac troponin T and creatine kinase-MB mass/myoglobin in whole blood in acute myocardial infarction. Cardiology. 1998;89(3):222-8. [pmid: 9570438].
Luscher MS, Thygesen K, Ravkilde J, et al. Applicability of cardiac troponin T and I for early risk stratification in unstable coronary artery disease. TRIM Study Group. Thrombin Inhibition in Myocardial Ischemia. Circulation. 1997;96(8):2578-85. [pmid: 9355897].
Mair J, Smidt J, Lechleitner P, et al. A decision tree for the early diagnosis of acute myocardial infarction in nontraumatic chest pain patients at hospital admission. Chest. 1995;108(6):1502-9. [pmid: 7497751].
Mark DB, Califf RM, Morris KG, et al. Clinical characteristics and long-term survival of patients with variant angina. Circulation. 1984;69(5):880-8. [pmid: 6705163].
Marmur JD, Freeman MR, Langer A, et al. Prognosis in medically stabilized unstable angina: Early Holter ST-segment monitoring compared with predischarge exercise thallium tomography. Ann Intern Med. 1990;113(8):575-9. [pmid: 2400166].
Maseri A, Crea F, Kaski JC, et al. Mechanisms and significance of cardiac ischemic pain. Prog Cardiovasc Dis. 1992;35(1):1-18. [pmid: 1529095].
McNutt RA, Selker HP. How did the acute ischemic heart disease predictive instrument reduce unnecessary coronary care unit admissions?. Med Decis Making. 1988;8(2):90-4. [pmid: 3283495].
Miller DH, Kligfield P, Schreiber TL, et al. Relationship of prior myocardial infarction to false-positive electrocardiographic diagnosis of acute injury in patients with chest pain. Arch Intern Med. 1987;147(2):257-61. [pmid: 3813742].
Mockel M, Stork T, Heller G Jr, et al. Troponin T in patients with low grade or atypical angina. Identification of a high risk group for short- and long-term cardiovascular events. Eur Heart J. 1998;19(12):1802-7. [pmid: 9886722].
Mohler ER 3d, Ryan T, Segar DS, et al. Clinical utility of troponin T levels and echocardiography in the emergency department. Am Heart J. 1998;135(2 Pt 1):253-60. [pmid: 9489973].
Mulcahy R, Daly L, Graham I, et al. Unstable angina: Natural history and determinants of prognosis. Am J Cardiol. 1981;48(3):525-8. [pmid: 6115581].
Mulrow C, Langhorne P, Grimshaw J. Integrating heterogeneous pieces of evidence in systematic reviews. Ann Intern Med. 1997;127(11):989-95. [pmid: 9412305].
Murabito JM, Anderson KM, Kannel WB, et al. Risk of coronary heart disease in subjects with chest discomfort: The Framingham Heart Study. Am J Med. 1990;89(3):297-302. [pmid: 2393034].
Newby LK, Gibler WB, Ohman EM, et al. Biochemical markers in suspected acute myocardial infarction: The need for early assessment. Clin Chem. 1995;41(9):1263-5. [pmid: 7656436].
Nichol G, Walls R, Goldman L, et al. A critical pathway for management of patients with acute chest pain who are at low risk for myocardial ischemia: Recommendations and potential impact. Ann Intern Med. 1997;127(11):996-1005. [pmid: 9412306].
Nyman I, Areskog M, Areskog NH, et al. Very early risk stratification by electrocardiogram at rest in men with suspected unstable coronary heart disease. The RISC Study Group. J Intern Med. 1993;234(3):293-301. [pmid: 8354980].
Ohman EM, Armstrong PW, Christenson RH, et al. Cardiac troponin T levels for risk stratification in acute myocardial ischemia. GUSTO IIA Investigators. N Engl J Med. 1996;335(18):1333-41. [pmid: 8857016].
Olatidoye AG, Wu AH, Feng YJ, et al. Prognostic role of troponin T versus troponin I in unstable angina pectoris for cardiac events with meta-analysis comparing published studies. Am J Cardiol. 1998;81(12):1405-10. [pmid: 9645888].
Olson HG, Lyons KP, Aronow WS, et al. The high-risk angina patient. Identification by clinical features, hospital course, electrocardiography and technetium-99m stannous pyrophosphate scintigraphy. Circulation. 1981;64(4):674-84. [pmid: 6456087].
Ouyang P, Brinker JA, Mellits ED, et al. Variables predictive of successful medical therapy in patients with unstable angina: Selection by multivariate analysis from clinical, electrocardiographic, and angiographic evaluations. Circulation. 1984;70(3):367-76. [pmid: 6378422].
Patel DJ, Knight CJ, Holdright DR, et al. Long-term prognosis in unstable angina. The importance of early risk stratification using continuous ST segment monitoring. Eur Heart J. 1998;19(2):240-9. [pmid: 9519317].
Petitti D. Statistical methods in meta-analysis. In: Meta-analysis, decision analysis and cost-effectiveness analysis. New York: Oxford University Press; 1994. p. 90-114.
Pettijohn TL, Doyle T, Spiekerman AM, et al. Usefulness of positive troponin-T and negative creatine kinase levels in identifying high-risk patients with unstable angina pectoris. Am J Cardiol. 1997;80(4):510-1. [pmid: 9285668].
Polanczyk CA, Lee TH, Cook EF, et al Cardiac troponin I as a predictor of major cardiac events in emergency department patients with acute chest pain J Am Coll Cardiol 1998 32(1) 8 14View this and related citations using 9669242
Pozen MW, D'Agostino RB, Mitchell JB, et al. The usefulness of a predictive instrument to reduce inappropriate admissions to the coronary care unit. Ann Intern Med. 1980;92(2 Pt 1):238-42. [pmid: 6986111].
Pozen MW, D'Agostino RB, Selker HP, et al. A predictive instrument to improve coronary-care-unit admission practices in acute ischemic heart disease. A prospective multicenter clinical trial. N Engl J Med. 1984;310(20):1273-8. [pmid: 6371525].
Pryor DB, Harrell FE Jr, Lee KL, et al. Estimating the likelihood of significant coronary artery disease. Am J Med. 1983;75(5):771-80. [pmid: 6638047].
Randolph AG, Guyatt GH, Calvin JE, et al. Understanding articles describing clinical prediction tools. Evidence Based Medicine in Critical Care Group. Crit Care Med. 1998;26(9):1603-12. [pmid: 9751601].
Ravkilde J. Creatine kinase isoenzyme MB mass, cardiac troponin T, and myosin light chain isotype 1 as serological markers of myocardial injury and their prognostic importance in acute coronary syndrome. Dan Med Bull. 1998;45(1):34-50. [pmid: 9504265].
Ravkilde J, Horder M, Gerhardt W, et al. Diagnostic performance and prognostic value of serum troponin T in suspected acute myocardial infarction. Scand J Clin Lab Invest. 1993;53(7):677-85. [pmid: 8272756].
Ravkilde J, Nissen H, Horder M, et al. Independent prognostic value of serum creatine kinase isoenzyme MB mass, cardiac troponin T and myosin light chain levels in suspected acute myocardial infarction. Analysis of 28 months of followup in 196 patients. J Am Coll Cardiol. 1995;25(3):574-81. [pmid: 7860899].
REACTT Study. Heart and Stroke Facts: 1996 Statistical Supplement. American Heart Association, 1996. Evaluation of a bedside whole-blood rapid troponin T assay in the emergency department. Rapid Evaluation by Assay of Cardiac Troponin T (REACTT) Investigators Study Group. Acad Emerg Med. 1997;4(11):1018-24. [pmid: 9383485].
Rebuzzi AG, Quaranta G, Liuzzo G, et al. Incremental prognostic value of serum levels of troponin T and C-reactive protein on admission in patients with unstable angina pectoris. Am J Cardiol. 1998;82(6):715-9. [pmid: 9761079].
Roberts RR, Zalenski RJ, Mensah EK, et al. Costs of an emergency department-based accelerated diagnostic protocol vs. hospitalization in patients with chest pain: A randomized controlled trial. JAMA. 1997;278(20):1670-6. [pmid: 9388086].
Robinson K, Conroy RM, Mulcahy R, et al. Risk factors and in-hospital course of first episode of myocardial infarction or acute coronary insufficiency in women. J Am Coll Cardiol. 1988;11(5):932-6. [pmid: 3356838].
Rottbauer W, Greten T, Muller-Bardorff M, et al. Troponin T: A diagnostic marker for myocardial infarction and minor cardiac cell damage. Eur Heart J. 1996;17(Suppl F):3-8.
Rude RE, Poole WK, Muller JE, et al. Electrocardiographic and clinical criteria for recognition of acute myocardial infarction based on analysis of 3,697 patients. Am J Cardiol. 1983;52(8):936-42. [pmid: 6356862].
Ryan TJ. Refining the classification of chest pain: A logical next step in the evaluation of patients for acute cardiac ischemia in the emergency department. Ann Emerg Med. 1997;29(1):166-8. [pmid: 8998099].
Ryan TJ, Anderson JL, Antman EM, et al ACC/AHA guidelines for the management of patients with acute myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Management of Acute Myocardial Infarction) J Am Coll Cardiol 1996 28(5) 1328 428View this and related citations using 8890834
Rydman RJ, Zalenski RJ, Roberts RR, et al. Patient satisfaction with an emergency department chest pain observation unit. Ann Emerg Med. 1997;29(1):109-15. [pmid: 8998089].
Sarasin FP, Reymond JM, Griffith JL, et al. Impact of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) on the speed of triage decision making for emergency department patients presenting with chest pain: A controlled clinical trial. J Gen Intern Med. 1994;9(4):187-94. [pmid: 8014723].
Savonitto S, Ardissino D, Granger CB, et al. Prognostic value of the admission electrocardiogram in acute coronary syndromes. JAMA. 1999;281(8):707-13. [pmid: 10052440].
Sayre MR, Gibler WB. New approaches to ruling out acute ischemic coronary syndrome in the emergency department. Ann Emerg Med. 1996;27(1):75-8. [pmid: 8572453].
Sayre MR, Kaufmann KH, Chen IW, et al. Measurement of cardiac troponin T is an effective method for predicting complications among emergency department patients with chest pain. Ann Emerg Med. 1998;31(5):539-49. [pmid: 9581136].
Schechtman KB, Capone RJ, Kleiger RE, et al. Risk stratification of patients with non-Q wave myocardial infarction. The critical role of ST segment depression. The Diltiazem Reinfarction Study Research Group. Circulation. 1989;80(5):1148-58. [pmid: 2805257].
Sclarovsky S, Rechavia E, Strasberg B, et al. Unstable angina: ST segment depression with positive versus negative T wave deflections-clinical course, ECG evolution, and angiographic correlation. Am Heart J. 1988;116(4):933-41. [pmid: 3177193].
Seino Y, Tomita Y, Hoshino K, et al. Pathophysiological analysis of serum troponin T release kinetics in evolving ischemic myocardial injury. Jpn Circ J. 1996;60(5):265-76. [pmid: 8803720].
Seino Y, Tomita Y, Takano T, et al. Early identification of cardiac events with serum troponin T in patients with unstable angina. Lancet. 1993;342(8881):1236-7.
Selker HP, Beshansky JR, Griffith JL, et al. Use of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) to assist with triage of patients with chest pain or other symptoms suggestive of acute cardiac ischemia. A multicenter, controlled clinical trial. Ann Intern Med. 1998;129(11):845-55. [pmid: 9867725].
Selker HP, Griffith JL, Patil S, et al. A comparison of performance of mathematical predictive methods for medical diagnosis: Identifying acute cardiac ischemia among emergency department patients. J Investig Med. 1995;43(5):468-76.
Selker HP, Zalenski RJ, Antman EM, et al. An evaluation of technologies for identifying acute cardiac ischemia in the emergency department: Executive summary of a National Heart Attack Alert Program Working Group Report. Ann Emerg Med. 1997;29(1):1-12. [pmid: 8998085].
Sharma GV, Deupree RH, Luchi RJ, et al. Identification of unstable angina patients who have favorable outcome with medical or surgical therapy (eight-year follow-up of the Veterans Administration Cooperative Study). Am J Cardiol. 1994;74(5):454-8. [pmid: 8059725].
Shesser R, Smith M. The chest pain emergency department and the outpatient chest pain evaluation center: Revolution or evolution?. Ann Emerg Med. 1994;23(2):334-41. [pmid: 8304615].
Sox HC Jr, Hickam DH, Marton KI, et al. Using the patient's history to estimate the probability of coronary artery disease: A comparison of primary care and referral practices [published erratum appears in Am J Med 1990 Oct;89(4):550]. Am J Med. 1990;89(1):7-14. [pmid: 2242131].
Stokke M, Gronvold T, Siebke AM, et al. Serial measurements of cardiac markers to rule in or out acute myocardial damage less than 3 h after admission in acute chest pain patients without ECG-signs of acute myocardial infarction. Scand J Clin Lab Invest. 1998;58(4):331-8. [pmid: 9741821].
Stork T, Mockel M, Gareis R, et al. Laboratory-based diagnosis of acute coronary syndromes: Results of the NOWIS pilot study. Clin Lab. 1997;43(12):1091-102.
Stubbs P, Collinson P, Moseley D, et al. Prospective study of the role of cardiac troponin T in patients admitted with unstable angina. Br Med J. 1996;313(7052):262-4. [pmid: 8704534].
Stussman BJ. National Hospital Ambulatory Medical Care Survey: 1995 emergency department summary. Adv Data. 1997;285:1-19. [pmid: 10166890].
Sullivan AK, Holdright DR, Wright CA, et al. Chest pain in women: Clinical, investigative, and prognostic features. Br Med J. 1994;308(6933):883-6. [pmid: 8173366].
Sweeney J, Goldschlager N. Evaluating patients with chest pain. West J Med. 1994;161(5):511-2. [pmid: 7810134].
Tanasijevic MJ, Cannon CP, Antman EM. The role of cardiac troponin-I (cTnI) in risk stratification of patients with unstable coronary artery disease. Clin Cardiol. 1999;22(1):13-6. [pmid: 9929748].
Tatum JL, Jesse RL, Kontos MC, et al. Comprehensive strategy for the evaluation and triage of the chest pain patient. Ann Emerg Med. 1997;29(1):116-25. [pmid: 8998090].
Tierney WM, Roth BJ, Psaty B, et al. Predictors of myocardial infarction in emergency room patients. Crit Care Med. 1985;13(7):526-31. [pmid: 4006491].
Tucker JF, Collins RA, Anderson AJ, et al. Early diagnostic efficiency of cardiac troponin I and Troponin T for acute myocardial infarction. Acad Emerg Med. 1997;4(1):13-21. [pmid: 9110006].
van Miltenburg-van Zijl AJ, Simoons ML, Veerhoek RJ, et al Incidence and follow-up of Braunwald subgroups in unstable angina pectoris J Am Coll Cardiol 1995 25(6) 1286 92View this and related citations using 7722122
Victor MF, Likoff MJ, Mintz GS, et al. Unstable angina pectoris of new onset: A prospective clinical and arteriographic study of 75 patients. Am J Cardiol. 1981;47(2):228-32. [pmid: 7468471].
Villanueva FS, Sabia PJ, Afrookteh A, et al. Value and limitations of current methods of evaluating patients presenting to the emergency room with cardiac-related symptoms for determining long-term prognosis. Am J Cardiol. 1992;69(8):746-50. [pmid: 1546648].
Waters DD, Miller DD, Szlachcic J, et al. Factors influencing the long-term prognosis of treated patients with variant angina. Circulation. 1983;68(2):258-65. [pmid: 6602668].
Waters DD, Szlachcic J, Miller D, et al. Clinical characteristics of patients with variant angina complicated by myocardial infarction or death within 1 month. Am J Cardiol. 1982;49(4):658-64. [pmid: 7064815].
White LD, Lee TH, Cook EF, et al Comparison of the natural history of new onset and exacerbated chronic ischemic heart disease. The Chest Pain Study Group J Am Coll Cardiol 1990 16(2) 304 10View this and related citations using 2373809
Wilcox I, Freedman SB, Allman KC, et al Prognostic significance of a predischarge exercise test in risk stratification after unstable angina pectoris J Am Coll Cardiol 1991 18(3) 677 83View this and related citations using 1869731
Wilcox I, Freedman SB, McCredie RJ, et al. Risk of adverse outcome in patients admitted to the coronary care unit with suspected unstable angina pectoris. Am J Cardiol. 1989;64(14):845-8. [pmid: 2801551].
Wu AH, Abbas SA, Green S, et al. Prognostic value of cardiac troponin T in unstable angina pectoris. Am J Cardiol. 1995;76(12):970-2. [pmid: 7484843].
Wuerz RC, Meador SA. Evaluation of a pre-hospital chest pain protocol. Ann Emerg Med. 1995;26(5):595-7. [pmid: 7486368].
Yang Z, Zhang W, Liu Y. Prognostic efficacy of troponin T measurement in angina pectoris. Chin Med J (Eng). 1995;108(8):626-30.
Young GP, Gibler WB, Hedges JR, et al. Serial creatine kinase-MB results are a sensitive indicator of acute myocardial infarction in chest pain patients with nondiagnostic electrocardiograms: The second Emergency Medicine Cardiac Research Group Study. Acad Emerg Med. 1997;4(9):869-77. [pmid: 9305428].
Young GP, Hedges JR, Gibler WB, et al. Do CK-MB results affect chest pain decision making in the emergency department?. Ann Emerg Med. 1991;20(11):1220-8. [pmid: 1952309].
Yusuf S, Pearson M, Sterry H, et al. The entry ECG in the early diagnosis and prognostic stratification of patients with suspected acute myocardial infarction. Eur Heart J. 1984;5(9):690-6. [pmid: 6389136].
Zalenski RJ, Rydman RJ, Ting S, et al. A national survey of emergency department chest pain centers in the United States. Am J Cardiol. 1998;81(11):1305-9. [pmid: 9631967].
Zalenski RJ, Sloan EP, Chen EH, et al. The emergency department ECG and immediately life-threatening complications in initially uncomplicated suspected myocardial ischemia. Ann Emerg Med. 1988;17(3):221-6. [pmid: 3345014].
Zucker DR, Griffith JL, Beshansky JR, et al. Presentations of acute myocardial infarction in men and women. J Gen Intern Med. 1997;12(2):79-87. [pmid: 9051556].