# References

Alonsozana GL, Christenson RH. The case for cardiac troponin T: Marker for effective risk stratification of patients with acute cardiac ischemia. Clin Chem. 1996;42(5):803-8. [pmid: 8653918].
Adams JE 3rd, Schechtman KB, Landt Y, et al. Comparable detection of acute myocardial infarction by creatine kinase MB isoenzyme and cardiac troponin I. Clin Chem. 1994;40(7 Pt 1):1291-5. [pmid: 8013101].
Antman EM, Grudzien C, Sacks DB. Evaluation of a rapid bedside assay for detection of serum cardiac troponin T. JAMA. 1995;273(16):1279-82. [pmid: 7715040].
Antman EM, Sacks DB, Rifai N, et al. Time to positivity of a rapid bedside assay for cardiac-specific troponin T predicts prognosis in acute coronary syndromes: A Thrombolysis in Myocardial Infarction (TIMI) 11A substudy. J Am Coll Cardiol. 1998;31(2):326-30. [pmid: 9462575].
Antman EM, Tanasijevic MJ, Thompson B, et al. Cardiac-specific troponin I levels to predict the risk of mortality in patients with acute coronary syndromes. N Engl J Med. 1996;335(18):1342-9. [pmid: 8857017].
Apple FS, Voss E, Lund L, et al. Cardiac troponin, CK-MB and myoglobin for the early detection of acute myocardial infarction and monitoring of reperfusion following thrombolytic therapy. Clin Chim Acta. 1995;237(1-2):59-66. [pmid: 7664479].
Armstrong PW, Fu Y, Chang WC, et al. Acute coronary syndromes in the GUSTO-IIb trial: Prognostic insights and impact of recurrent ischemia. The GUSTO-IIb Investigators. Circulation. 1998;98(18):1860-8.
Bakker AJ, Gorgels JP, van Vlies B, et al. The mass concentrations of serum troponin T and creatine kinase-MB are elevated before creatine kinase and creatine kinase-MB activities in acute myocardial infarction. Eur J Clin Chem Clin Biochem. 1993a;31(11):715-24.
Bakker AJ, Koelemay MJ, Gorgels JP, et al. Failure of new biochemical markers to exclude acute myocardial infarction at admission. Lancet. 1993b;342(8881):1220-2.
Bakker AJ, Koelemay MJ, Gorgels JP, et al. Troponin T and myoglobin at admission: Value of early diagnosis of acute myocardial infarction. Eur Heart J. 1994;15(1):45-53.
Barish RA, Doherty RJ, Browne BJ. Reengineering the emergency evaluation of chest pain. J Healthc Qual. 1997;19(5):6-12; quiz 60.
Benamer H, Steg PG, Benessiano J, et al. Comparison of the prognostic value of C-reactive protein and troponin I in patients with unstable angina pectoris. Am J Cardiol. 1998;82(7):845-50. [pmid: 9781965].
Braunwald E, Jones RH, Mark DB, et al. Diagnosing and managing unstable angina. Agency for Health Care Policy and Research. Circulation. 1994;90(1):613-22. [pmid: 8026048].
Brscic E, Chiappino I, Bergerone S, et al. Prognostic implications of detection of troponin I in patients with unstable angina pectoris. Am J Cardiol. 1998;82(8):971-3. [pmid: 9794354].
Calvin JE, Klein LW, VandenBerg BJ, et al. Risk stratification in unstable angina. Prospective validation of the Braunwald classification. JAMA. 1995;273(2):136-41. [pmid: 7799494].
Cannon CP, McCabe CH, Stone PH, et al The electrocardiogram predicts one-year outcome of patients with unstable angina and non-Q wave myocardial infarction: Results of the TIMI III Registry ECG Ancillary Study. Thrombolysis in Myocardial Ischemia J Am Coll Cardiol 1997 30(1) 133 40View this and related citations using 9207634
Castaner A, Roig E, Serra A, et al. Risk stratification and prognosis of patients with recent onset angina. Eur Heart J. 1990;11(10):868-75. [pmid: 2265639].
Chang CC, Ip MP, Hsu RM, et al. Evaluation of a proposed panel of cardiac markers for the diagnosis of acute myocardial infarction in patients with atraumatic chest pain. Arch Pathol Lab Med. 1998;122(4):320-4. [pmid: 9648898].
Chin MH, Cook EF, Lee TH, et al. Correlates of major complications and mortality in patients presenting to the emergency department with chest pain and more than bibasilar rales. J Gen Intern Med. 1994;9(12):659-65. [pmid: 7876947].
Christenson RH, Duh SH, Newby LK, et al. Cardiac troponin T and cardiac troponin I: Relative values in short-term risk stratification of patients with acute coronary syndromes. GUSTO-IIa Investigators. Clin Chem. 1998;44(3):494-501. [pmid: 9510853].
Coronado BE, Griffith JL, Beshansky JR, et al. Hospital mortality in women and men with acute cardiac ischemia: A prospective multicenter study. J Am Coll Cardiol. 1997;29(7):1490-6. [pmid: 9180109].
Cunningham MA, Lee TH, Cook EF, et al. The effect of gender on the probability of myocardial infarction among emergency department patients with acute chest pain: A report from the Multicenter Chest Pain Study Group. J Gen Intern Med. 1989;4(5):392-8. [pmid: 2677270].
D'Costa M, Fleming E, Patterson MC. Cardiac troponin I for the diagnosis of acute myocardial infarction in the emergency department. Am J Clin Pathol. 1997;108(5):550-5. [pmid: 9353094].
deFilippi CR, Parmar RJ, Potter MA, et al. Diagnostic accuracy, angiographic correlates and long-term risk stratification with the troponin T ultra sensitive Rapid Assay in chest pain patients at low risk for acute myocardial infarction. Eur Heart J. 1998;19(Suppl N):N42-N47. [pmid: 9857939].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
de Winter RJ, Koster RW, Schotveld JH, et al. Prognostic value of troponin T, myoglobin, and CK-MB mass in patients presenting with chest pain without acute myocardial infarction. Heart. 1996;75(3):235-9. [pmid: 8800984].
Diamond GA, Forrester JS. Analysis of probability as an aid in the clinical diagnosis of coronary-artery disease. N Engl J Med. 1979;300(24):1350-8. [pmid: 440357].
Farkouh ME, Smars PA, Reeder GS, et al. A clinical trial of a chest-pain observation unit for patients with unstable angina. Chest Pain Evaluation in the Emergency Room (CHEER) Investigators. N Engl J Med. 1998;339(26):1882-8. [pmid: 9862943].
Galvani M, Ottani F, Ferrini D, et al. Prognostic influence of elevated values of cardiac troponin I in patients with unstable angina. Circulation. 1997;95(8):2053-9. [pmid: 9133515].
Gerhardt W, Katus H, Ravkilde J, et al. S-troponin T in suspected ischemic myocardial injury compared with mass and catalytic concentrations of S-creatine kinase isoenzyme MB. Clin Chem. 1991;37(8):1405-11. [pmid: 1868602].
Gerhardt W, Ljungdahl L. Detection of myocardial damage by serial measurements of cardiac troponin T, CK MBmass, and TROPT rapid test. Cardiovasc Drugs Ther. 1997;11(Suppl 1):227-40. [pmid: 9211015].
Gerhardt W, Ljungdahl L, Collinson PO, et al. An improved rapid troponin T test with a decreased detection limit: A multicentre study of the analytical and clinical performance in suspected myocardial damage. Scand J Clin Lab Invest. 1997;57(6):549-57. [pmid: 9350075].
Gerhardt W, Ljungdahl L, Herbert AK. Troponin-T and CK MB (mass) in early diagnosis of ischemic myocardial injury. The Helsingborg Study, 1992. Clin Biochem. 1993;26(4):231-40. [pmid: 8242886].
Gibler WB, Lewis LM, Erb RE, et al. Early detection of acute myocardial infarction in patients presenting with chest pain and nondiagnostic ECGs: Serial CK-MB sampling in the emergency department [published erratum appears in Ann Emerg Med 1991 Apr;20(4):420]. Ann Emerg Med. 1990;19(12):1359-66. [pmid: 2240745].
Gibler WB, Runyon JP, Levy RC, et al. A rapid diagnostic and treatment center for patients with chest pain in the emergency department. Ann Emerg Med. 1995;25(1):1-8. [pmid: 7802357].
Gokhan Cin V, Gok H, Kaptanoglu B. The prognostic value of serum troponin T in unstable angina. Int J Cardiol. 1996;53(3):237-44. [pmid: 8793576].
Goldman L, Cook EF, Brand DA, et al. A computer protocol to predict myocardial infarction in emergency department patients with chest pain. N Engl J Med. 1988;318(13):797-803. [pmid: 3280998].
Goldman L, Weinberg M, Weisberg M, et al. A computer-derived protocol to aid in the diagnosis of emergency room patients with acute chest pain. N Engl J Med. 1982;307(10):588-96. [pmid: 7110205].
Gomez MA, Anderson JL, Karagounis LA, et al An emergency department-based protocol for rapidly ruling out myocardial ischemia reduces hospital time and expense: Results of a randomized study (ROMIO) J Am Coll Cardiol 1996 28(1) 25 33View this and related citations using 8752791
Graff LG, Dallara J, Ross MA, et al. Impact on the care of the emergency department chest pain patient from the chest pain evaluation registry (CHEPER) study. Am J Cardiol. 1997;80(5):563-8. [pmid: 9294982].
Green GB, Beaudreau RW, Chan DW, et al. Use of troponin T and creatine kinase-MB subunit levels for risk stratification of emergency department patients with possible myocardial ischemia. Ann Emerg Med. 1998;31(1):19-29. [pmid: 9437337].
Gust R, Gust A, Bottiger BW, et al. Bedside troponin T testing is not useful for early out-of-hospital diagnosis of myocardial infarction. Acta Anaesthesiol Scand. 1998;42(4):414-7. [pmid: 9563859].
Hamm CW, Goldmann BU, Heeschen C, et al. Emergency room triage of patients with acute chest pain by means of rapid testing for cardiac troponin T or troponin I. N Engl J Med. 1997;337(23):1648-53. [pmid: 9385123].
Hamm CW, Ravkilde J, Gerhardt W, et al. The prognostic value of serum troponin T in unstable angina. N Engl J Med. 1992;327(3):146-50. [pmid: 1290492].
Hedges L. Fixed effects models. In: Cooper H, Hedges L, editors. The handbook of research synthesis. New York: Russel Sage Foundation; 1994. p. 307-35.
Heeschen C, Goldmann BU, Moeller RH, et al. Analytical performance and clinical application of a new rapid bedside assay for the detection of serum cardiac troponin I. Clin Chem. 1998;44(9):1925-30. [pmid: 9732978].
Herlitz J, Karlson BW, Sjolin M, et al. Predictors of death and mode of death among patients with acute chest pain in various age groups. Coron Artery Dis. 1997;8(11-12):719-26. [pmid: 9472462].
Hetland O, Dickstein K. Cardiac markers in the early hours of acute myocardial infarction: Clinical performance of creatine kinase, creatine kinase MB isoenzyme (activity and mass concentration), creatine kinase MM and MB subform ratios, myoglobin and cardiac troponin T. Scand J Clin Lab Invest. 1996;56(8):701-13. [pmid: 9034351].
Hetland O, Dickstein K. Cardiac troponins I and T in patients with suspected acute coronary syndrome: A comparative study in a routine setting. Clin Chem. 1998;44(7):1430-6. [pmid: 9665420].
Johnson PA, Goldman L, Sacks DB, et al. Cardiac troponin T as a marker for myocardial ischemia in patients seen at the emergency department for acute chest pain. Am Heart J. 1999;137(6):1137-44. [pmid: 10347343].
Katus HA, Remppis A, Neumann FJ, et al. Diagnostic efficiency of troponin T measurements in acute myocardial infarction. Circulation. 1991;83(3):902-12. [pmid: 1999039].
Kontos MC, Jesse RL, Schmidt KL, et al. Value of acute rest sestamibi perfusion imaging for evaluation of patients admitted to the emergency department with chest pain. J Am Coll Cardiol. 1997;30(4):976-82. [pmid: 9316527].
Kost GJ, Kirk JD, Omand K. A strategy for the use of cardiac injury markers (troponin I and T, creatine kinase-MB mass and isoforms, and myoglobin) in the diagnosis of acute myocardial infarction. Arch Pathol Lab Med. 1998;122(3):245-51. [pmid: 9823862].
Koukkunen H, Penttila K, Kemppainen A, et al. Troponin T and creatinine kinase isoenzyme MB mass in the diagnosis of myocardial infarction. Ann Med. 1998;30(5):488-96. [pmid: 9814836].
Laurino JP, Pelletier TE, Eadry R, et al. Thrombus precursor protein and the measurement of thrombosis in patients with acute chest pain syndrome. Ann Clin Lab Sci. 1997;27(5):338-45. [pmid: 9303172].
Lee TH, Ting HH, Shammash JB, et al. Long-term survival of emergency department patients with acute chest pain. Am J Cardiol. 1992;69(3):145-51. [pmid: 1731449].
Lindahl B, Venge P, Wallentin L. Relation between troponin T and the risk of subsequent cardiac events in unstable coronary artery disease. The FRISC study group. Circulation. 1996;93(9):1651-7. [pmid: 8653870].
Lloyd-Jones DM, Camargo CA Jr, Lapuerta P, et al. Electrocardiographic and clinical predictors of acute myocardial infarction in patients with unstable angina pectoris. Am J Cardiol. 1998;81(10):1182-6. [pmid: 9604942].
Lundin P, Eriksson SV, Fredrikson M, et al. Prognostic information from on-line vectorcardiography in unstable angina pectoris. Cardiology. 1995;86(1):60-6. [pmid: 7728790].
Luscher MS, Ravkilde J, Thygesen K. Clinical application of two novel rapid bedside tests for the detection of cardiac troponin T and creatine kinase-MB mass/myoglobin in whole blood in acute myocardial infarction. Cardiology. 1998;89(3):222-8. [pmid: 9570438].
Luscher MS, Thygesen K, Ravkilde J, et al. Applicability of cardiac troponin T and I for early risk stratification in unstable coronary artery disease. TRIM Study Group. Thrombin Inhibition in Myocardial Ischemia. Circulation. 1997;96(8):2578-85. [pmid: 9355897].
Mockel M, Stork T, Heller G Jr, et al. Troponin T in patients with low grade or atypical angina. Identification of a high risk group for short- and long-term cardiovascular events. Eur Heart J. 1998;19(12):1802-7. [pmid: 9886722].
Mohler ER 3rd, Ryan T, Segar DS, et al. Clinical utility of troponin T levels and echocardiography in the emergency department. Am Heart J. 1998;135(2 Pt 1):253-60. [pmid: 9489973].
Mulrow C, Langhorne P, Grimshaw J. Integrating heterogeneous pieces of evidence in systematic reviews. Ann Intern Med. 1997;127(11):989-95. [pmid: 9412305].
Ohman EM, Armstrong PW, Christenson RH, et al. Cardiac troponin T levels for risk stratification in acute myocardial ischemia. GUSTO IIA Investigators. N Engl J Med. 1996;335(18):1333-41. [pmid: 8857016].
Olatidoye AG, Wu AH, Feng YJ, et al. Prognostic role of troponin T versus troponin I in unstable angina pectoris for cardiac events with meta-analysis comparing published studies. Am J Cardiol. 1998;81(12):1405-10. [pmid: 9645888].
Patel DJ, Knight CJ, Holdright DR, et al. Long-term prognosis in unstable angina. The importance of early risk stratification using continuous ST segment monitoring. Eur Heart J. 1998;19(2):240-9. [pmid: 9519317].
Petitti D. Statistical methods in meta-analysis. In: Meta-analysis, decision analysis and cost-effectiveness analysis. New York: Oxford University Press; 1994. p. 90-114.
Pettijohn TL, Doyle T, Spiekerman AM, et al. Usefulness of positive troponin-T and negative creatine kinase levels in identifying high-risk patients with unstable angina pectoris. Am J Cardiol. 1997;80(4):510-1. [pmid: 9285668].
Polanczyk CA, Lee TH, Cook EF, et al Cardiac troponin I as a predictor of major cardiac events in emergency department patients with acute chest pain J Am Coll Cardiol 1998 32(1) 8 14View this and related citations using 9669242
Pryor DB, Harrell FE Jr, Lee KL, et al. Estimating the likelihood of significant coronary artery disease. Am J Med. 1983;75(5):771-80. [pmid: 6638047].
Ravkilde J. Creatine kinase isoenzyme MB mass, cardiac troponin T, and myosin light chain isotype 1 as serological markers of myocardial injury and their prognostic importance in acute coronary syndrome. Dan Med Bull. 1998;45(1):34-50. [pmid: 9504265].
Ravkilde J, Horder M, Gerhardt W, et al. Diagnostic performance and prognostic value of serum troponin T in suspected acute myocardial infarction. Scand J Clin Lab Invest. 1993;53(7):677-85. [pmid: 8272756].
Ravkilde J, Nissen H, Horder M, et al Independent prognostic value of serum creatine kinase isoenzyme MB mass, cardiac troponin T and myosin light chain levels in suspected acute myocardial infarction. Analysis of 28 months of follow-up in 196 patients J Am Coll Cardiol 1995 25(3) 574 81View this and related citations using 7860899
REACTT Study. Heart and Stroke Facts: 1996 Statistical Supplement. American Heart Association, 1996. Evaluation of a bedside whole-blood rapid troponin T assay in the emergency department. Rapid Evaluation by Assay of Cardiac Troponin T (REACTT) Investigators Study Group. Acad Emerg Med. 1997;4(11):1018-24. [pmid: 9383485].
Rebuzzi AG, Quaranta G, Liuzzo G, et al. Incremental prognostic value of serum levels of troponin T and C-reactive protein on admission in patients with unstable angina pectoris. Am J Cardiol. 1998;82(6):715-9. [pmid: 9761079].
Roberts RR, Zalenski RJ, Mensah EK, et al. Costs of an emergency department-based accelerated diagnostic protocol vs. hospitalization in patients with chest pain: A randomized controlled trial. JAMA. 1997;278(20):1670-6. [pmid: 9388086].
Rude RE, Poole WK, Muller JE, et al. Electrocardiographic and clinical criteria for recognition of acute myocardial infarction based on analysis of 3,697 patients. Am J Cardiol. 1983;52(8):936-42. [pmid: 6356862].
Ryan TJ, Anderson JL, Antman EM, et al ACC/AHA guidelines for the management of patients with acute myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Management of Acute Myocardial Infarction) J Am Coll Cardiol 1996 28(5) 1328 428View this and related citations using 8890834
Rydman RJ, Zalenski RJ, Roberts RR, et al. Patient satisfaction with an emergency department chest pain observation unit. Ann Emerg Med. 1997;29(1):109-15. [pmid: 8998089].
Sarasin FP, Reymond JM, Griffith JL, et al. Impact of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) on the speed of triage decision making for emergency department patients presenting with chest pain: A controlled clinical trial. J Gen Intern Med. 1994;9(4):187-94. [pmid: 8014723].
Sayre MR, Kaufmann KH, Chen IW, et al. Measurement of cardiac troponin T is an effective method for predicting complications among emergency department patients with chest pain. Ann Emerg Med. 1998;31(5):539-49. [pmid: 9581136].
Seino Y, Tomita Y, Hoshino K, et al. Pathophysiological analysis of serum troponin T release kinetics in evolving ischemic myocardial injury. Jpn Circ J. 1996;60(5):265-76. [pmid: 8803720].
Seino Y, Tomita Y, Takano T, et al. Early identification of cardiac events with serum troponin T in patients with unstable angina. Lancet. 1993;342(8881):1236-7.
Selker HP, Beshansky JR, Griffith JL, et al. Use of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) to assist with triage of patients with chest pain or other symptoms suggestive of acute cardiac ischemia. A multicenter, controlled clinical trial. Ann Intern Med. 1998;129(11):845-55. [pmid: 9867725].
Stokke M, Gronvold T, Siebke AM, et al. Serial measurements of cardiac markers to rule in or out acute myocardial damage less than 3 h after admission in acute chest pain patients without ECG-signs of acute myocardial infarction. Scand J Clin Lab Invest. 1998;58(4):331-8. [pmid: 9741821].
Stork T, Mockel M, Gareis R, et al. Laboratory-based diagnosis of acute coronary syndromes: Results of the NOWIS pilot study. Clin Lab. 1997;43(12):1091-102.
Stubbs P, Collinson P, Moseley D, et al. Prospective study of the role of cardiac troponin T in patients admitted with unstable angina. Br Med J. 1996;313(7052):262-4. [pmid: 8704534].
Tanasijevic MJ, Cannon CP, Antman EM. The role of cardiac troponin-I (cTnI) in risk stratification of patients with unstable coronary artery disease. Clin Cardiol. 1999;22(1):13-6. [pmid: 9929748].
Tierney WM, Roth BJ, Psaty B, et al. Predictors of myocardial infarction in emergency room patients. Crit Care Med. 1985;13(7):526-31. [pmid: 4006491].
Tucker JF, Collins RA, Anderson AJ, et al. Early diagnostic efficiency of cardiac troponin I and Troponin T for acute myocardial infarction. Acad Emerg Med. 1997;4(1):13-21. [pmid: 9110006].
van Miltenburg-van Zijl AJ, Simoons ML, Veerhoek RJ, et al Incidence and follow-up of Braunwald subgroups in unstable angina pectoris J Am Coll Cardiol 1995 25(6) 1286 92View this and related citations using 7722122
Villanueva FS, Sabia PJ, Afrookteh A, et al. Value and limitations of current methods of evaluating patients presenting to the emergency room with cardiac-related symptoms for determining long-term prognosis. Am J Cardiol. 1992;69(8):746-50. [pmid: 1546648].
Wilcox I, Freedman SB, Allman KC, et al Prognostic significance of a predischarge exercise test in risk stratification after unstable angina pectoris J Am Coll Cardiol 1991 18(3) 677 83View this and related citations using 1869731
Wu AH, Abbas SA, Green S, et al. Prognostic value of cardiac troponin T in unstable angina pectoris. Am J Cardiol. 1995;76(12):970-2. [pmid: 7484843].
Yang Z, Zhang W, Liu Y. Prognostic efficacy of troponin T measurement in angina pectoris. Chin Med J (Eng). 1995;108(8):626-30.