# Future Research

Although numerous studies have examined the impact of patient characteristics, electrocardiographic findings, and serum marker levels on prognosis, more data are needed to allow the clinician to combine all of this information into an overall prognosis score. Our qualitative review of clinical and electrocardiographic predictors of prognosis suggests that future studies should include the following variables in a multivariate prediction model: age, male sex, prior MI, diabetes, heart failure on presentation, ST depression, and ST elevation. Future prognostic studies in these patient groups should at least account for the identified risk factors and should strive towards standardized data collection of initially available clinical and electrocardiographic information. Furthermore, uniform collection of race or ethnic and gender data, particularly as it relates to presenting symptoms, will provide the basis for determining if predictors of risk differ between ethnic groups or genders. Future studies should also include either troponin T or I as a variable in any multivariate analysis.

To directly address the actual impact of these variables, future efforts are needed to develop standard variable definitions and data collection across studies to allow for combination of study results for pooled analysis or meta-analytic techniques similar to that used by the American College of Cardiology National Cardiovascular Data Registry for cardiac catheterization procedures. If accomplished, this might provide clinicians a more refined ability to immediately and accurately risk stratify patients with suspected or confirmed unstable angina. It would also provide a precise baseline for which the incremental cost-effectiveness of new diagnostic tests in this patient population could be evaluated.

Further comparative studies are needed between different cardiac markers to determine the optimal combination for prognosis. Additional studies are needed to determine if a positive troponin T or I should be used to guide early therapy, such as early revascularization. The marginal cost-effectiveness of testing with troponin compared with relying on older estimates of risk should be examined. If troponin testing is found to be cost-effective, then additional studies can examine the marginal cost-effectiveness of also performing stress testing or coronary angiography. Standardization of troponin I assays is needed in order to investigate the effect of the threshold level on prognosis.

More information is needed regarding certain subgroups of patients with unstable angina. In particular, the prognostic value of troponin testing in patients with renal dysfunction and in the elderly needs clarification.

More randomized trials of chest pain units or chest pain protocols are needed to determine their health and economic benefits. Whether chest pain units are a safe alternative to routine evaluation of patients presenting with chest pain will be better determined when larger study populations including older, low- and intermediate-risk patients are evaluated. Similarly, longer term patient outcome measures (2 or 3 years of followup) are required to better determine effectiveness, safety, and long-term cost-effectiveness of chest pain units relative to routine care.