# Conclusions

In patients with chest pain raising suspicion of acute ischemia or diagnosed unstable angina, we found both common positive predictors of outcomes, as well as several variables that were consistently not associated with adverse events (Evidence Tables 15 and 16). Common positive independent predictors included increasing age, male sex (more consistently in the undiagnosed unstable angina cohorts), prior myocardial infarction, diabetes mellitus, hypertension, congestive heart failure or cardiogenic shock on admission, and ST-segment depression. Interestingly, several variables that were consistently found not to be significantly associated with outcomes included race/ethnicity, prior stable angina, and isolated T-wave inversions. However, given the methodologic limitations and relatively small number of studies evaluating these characteristics, the latter results should be interpreted cautiously. Furthermore, several of the potentially important clinical and electrocardiographic variables were not specifically evaluated as independent predictors in any of the reviewed studies (e.g., prior stroke or transient ST elevation).

Tests of troponin T or I were predictive of cardiac events including death and myocardial infarction. Patients with elevated troponin levels were also more likely to undergo coronary revascularization. The increased risk appears to be independent of history and electrocardiographic findings and is proportional to the overall risk of cardiac death or myocardial infarction.

Chest pain units or protocols that use history, physical electrocardiographic, cardiac marker, and selective stress-testing data to determine the degree and location of care demonstrated reduced costs with no obvious increase in risk to the patient, but sample sizes were small and statistical power to detect increased risk was limited in studies to date. Although the ED protocol studies described did not evaluate costs, it is assumed that an increase in the number of patients discharged home and a decrease in CCU admissions would lower cost.

All information presented in this evidence report applies to adult men and women.

## Limitations

One focus of this report was to identify independent predictors of cardiac outcomes in suspected or confirmed unstable angina based on results from multivariate analyses that attempted to control for potential confounding in these observational studies. Therefore, we did not include studies that involved decision support tools previously shown to be helpful in clinical decisionmaking for patients with chest pain or other symptoms suggestive of acute ischemia or infarction. Examples include decision trees based on recursive partitioning (Goldman, Cook, Brand, et al., 1988; Goldman, Weinberg, Weisberg, et al., 1982). These models are recognized as valuable and clinically useful decision support tools for patients presenting with chest pain or suspected cardiac ischemia but did not meet the necessary inclusion criteria for our analysis. Other caveats of our review are that many studies did not specifically address all of the available clinical and electrocardiographic predictor variables and there was substantial heterogeneity in all other aspects of the reviewed prognostic studies including study design, enrollment criteria, predictor variables, outcomes of interest, duration of followup, and methods of analysis. Finally, we were only able to provide semiquantitative estimates for individual predictors based on limitations in the available data across studies. In multivariate prognostic studies, the method of totaling the number of times variables were found to be significant needs to be interpreted cautiously because many studies were small and lacked power to find clinically important differences.

Studies of troponin T and I rarely reported long-term followup (longer than 6 months); thus, the implications for long-term survival with an abnormal troponin result are unclear. There is no standard troponin I assay; thus, we could not compare threshold values across studies. In addition, we cannot determine which assay is most predictive of outcome. The limitations may make it difficult to observe the true magnitude of risk associated with a symptom or marker. In contrast, if studies included ST-elevation patients, the prognostic value of troponin will likely be greater than that of non-ST-elevation patients and mixing the two will lead to an intermediate risk value. The definition of unstable angina varied across studies, which limits the ability to compare results. Underreporting of negative studies may have increased the strength of the relationship between elevated troponin levels and outcome.