# Results

## Prognostic Value of the History, Physical Examination, and Electrocardiogram

### Identified Articles

A total of 18 studies were identified from MEDLINE searches and citation review that met all of the criteria and underwent complete data extraction. Eight studies examined patients with chest pain suggestive of ischemia, and 10 studies examined patients with a diagnosis of unstable angina.

### Chest Pain Suggestive of Acute Ischemia

Eight studies met criteria and had adequate data on multivariate predictors of clinical outcomes in patients with chest pain that could indicate acute ischemia (Evidence Table 1). All studies enrolled patients seen in the emergency department, and one study enrolled only patients requiring admission to the cardiac care unit (Rude, Poole, Muller, et al., 1983) (Evidence Table 1). Consistent with the substantial heterogeneity observed across studies in the study design, type of enrolled patients, and chosen outcomes, there was a relatively wide range of observed cardiac event rates across studies (6 percent to 22 percent).

Despite these differences, certain clinical and electrocardiographic information fairly consistently predicted an increased risk of adverse outcomes. Demographic characteristics associated with worse outcomes included increasing age and male sex (Evidence Table 2). Prior medical conditions that consistently predicted poor outcomes included prior myocardial infarction (MI) and diabetes (Evidence Table 3). Prior congestive heart failure, hypertension, and smoking were less consistently significant predictors of outcome but were positive in some studies (Evidence Table 3). Symptom characteristics were surprisingly unhelpful once the pain was judged an indication of cardiac ischemia (Evidence Table 4). Regarding the initial vital signs and physical examination, only low blood pressure, congestive heart failure, or cardiogenic shock on admission portended a poor prognosis (Evidence Table 5). ST-segment depression >0.1 millivolt (mV) was the strongest electrocardiographic predictor of adverse outcomes, whereas a completely normal electrocardiogram (ECG) was a strong negative predictor of outcomes (Evidence Tables 6 and 7).

### Diagnosed Unstable Angina

Ten studies met criteria and had adequate data on multivariate predictors of clinical outcomes in patients with diagnosed unstable angina (Evidence Table 8). All studies involved patients who had suspected or confirmed unstable angina; all but one (Coronado, Griffith, Beshansky, et al., 1997) also required admission to the hospital, typically the cardiac care unit or stepdown unit. A variety of criteria were used for defining unstable angina; two studies also specifically excluded patients with non-Q-wave myocardial infarction (Calvin, Klein, VandenBerg, et al., 1995; van Miltenburg-van Zijl, Simoons, Veerhoek, et al., 1995). As with studies of patients with chest pain described above, there was substantial heterogeneity across studies in study design, predictors evaluated, and types and timing of outcomes assessed (Evidence Table 8). The observed cardiac event rate ranged from 4 percent to 35 percent across studies, depending on the outcome chosen and duration of followup.

As in patients with troubling chest pain, certain clinical and electrocardiographic variables were consistently associated with an increased risk for poor outcomes in patients with diagnosed unstable angina. Important demographic characteristics included increasing age and probably male sex (Evidence Table 9). Previous medical conditions associated with adverse outcomes included prior myocardial infarction, diabetes, and possibly hypertension (Evidence Table 10). Regarding symptom characteristics, the presence of pain at rest or postinfarction angina was an indicator of poor prognosis (Evidence Table 11), and low blood pressure and moderate to severe congestive heart failure on presentation also were markers of increased risk of cardiac events (Evidence Table 12). The only consistent electrocardiographic predictor of adverse outcomes was ST-segment depression of >0.05-0.1 mV (Evidence Table 13). Finally, evidence of recurrent chest pain or ischemia, the need for maximal antianginal therapy, and recent thrombolysis also seemed to be indicators of poor prognosis (Evidence Table 14).

A summary of the independent clinical and ECG predictors of adverse outcomes is listed for patients with chest pain suggestive of cardiac ischemia (Summary Table 1) and for patients with unstable angina (Summary Table 2). Several factors were consistent markers of increased risk in both populations: increased age, prior MI, diabetes, and ST changes on the ECG.

## Prognostic Value of Troponin

### Identified Articles

A total of 501 articles were identified with the MEDLINE and EMBASE searches and citation review.

### Excluded Studies

We excluded articles using a hierarchical method beginning with 171 studies that were not articles about troponin in suspected unstable angina based on their title (Figure 1). Of the remaining 330 articles, 185 were excluded based on the abstract because they were not studies of troponin in patients with suspected or proven unstable angina. The remaining 145 articles were reviewed, and 93 were excluded for the following reasons: 33 studies were review articles and did not provide new data, 5 studies did not evaluate troponin, 17 studies were not cohort evaluations of patients with suspected ischemia, 6 studies only included patients with myocardial infarction, 1 study included only postoperative patients, 24 studies were excluded because they did not report the outcomes of interest (death or myocardial infarction), and 7 studies were excluded because they provided duplicate information included in other studies. The remaining 52 articles (from 51 studies: one study reported troponin T and I in separate manuscripts) were abstracted (Evidence Tables 15 to 35). The MEDLINE search identified 47 (90 percent) articles; EMBASE but not MEDLINE identified 5; and the citation search identified no additional articles beyond those found in our MEDLINE or EMBASE searches.

Figure 1. Reasons for study exclusion

### Patient Characteristics

The mean age of enrolled patients was 61 years; 64 percent were male, 37 percent had a history of myocardial infarction, and 52 percent had a history of coronary artery disease (CAD). A history of hypertension was noted in 44 percent of the patients, diabetes in 19 percent, and smoking in 40 percent (Evidence Tables 15 to 25). The included studies had a median followup of 4 weeks (mean 12 weeks, maximum 147 weeks).

### Quality of Study Reports

Of the 51 included studies (52 reports), 17 (33 percent) did not report patient exclusion criteria (Evidence Table 19). In 15 (29 percent) studies, there was no statement noting whether health care providers were blinded to the troponin results (Evidence Table 21). Three (6 percent) studies did not report whether study deaths referred to total or cardiac deaths. Three (6 percent) studies did not indicate how myocardial infarction was defined. Overall, 26 (51 percent) studies did not report one of these measures of report quality. Troponin methodology studies varied in the precise assay used for both troponin T and troponin I. Also, the definition of "elevated level" varied among studies. Studies did not generally report results using different definitions of a positive test, so this report is limited to assessing the prognostic value of the test based only on authors' definition. There is evidence that, using a single assay system, higher values of troponin are associated with higher event rates (Ohman, Armstrong, Christenson, et al., 1996)

### Myocardial Infarction During Admission

There were 3,2 myocardial infarctions in 11,477 patients in 38 trials reporting data (Evidence Table 26). There were 1,995 infarctions in studies of troponin T and 1,658 in studies of troponin I (several studies reported both troponin T and I data). For patients with a diagnosis of myocardial infarction, the troponin T was positive in 1,498 (sensitivity 75 percent, 1,498/1,995). Troponin I was positive in 1,098 patients with a myocardial infarction (sensitivity 66 percent, 1,098/1,658). For troponin T, the specificity was 94 percent, the negative predictive value was 91 percent, and the positive predictive value was 83 percent. For troponin I, the specificity was 92 percent, the negative predictive value was 88 percent, and the positive predictive value was 75 percent.

### Death During Admission

There were 38 in-hospital deaths in 1,918 patients in 7 trials with at least 1 in-hospital death reported (Evidence Table 27). Death was reported as all-cause mortality in five of seven studies (71 percent) and as cardiac death in two studies (29 percent). There were 35 deaths in studies of troponin T and 14 in studies of troponin I with some studies examining both markers. The troponin T was positive in 24 of 35 inpatient deaths (sensitivity 69 percent). Troponin I was positive in 14 of 14 patients who died during hospitalization (sensitivity 1 percent). For troponin T, the specificity was 85 percent, the negative predictive value was 99 percent, and the positive predictive value was 8 percent. For troponin I, the specificity was 87 percent, the negative predictive value was 1 percent, and the positive predictive value was 6 percent.

### Composite Endpoints During Admission

There were 344 composite endpoints reached during admission in 2,979 patients in 10 trials reporting data (Evidence Table 28). One-half of the trials (6/12) reported the combination of death and myocardial infarction. Another six included additional cardiac events or procedures as endpoints. A composite endpoint was reported in 227 patients in studies of troponin T compared with 137 in studies of troponin I (data on both were reported for 20 patients). The troponin T was positive in 107 patients with a composite endpoint (sensitivity 47 percent). Troponin I was positive in 78 patients with a composite endpoint (sensitivity 57 percent). For troponin T, the specificity was 89 percent, the negative predictive value was 95 percent, and the positive predictive value was 26 percent. For troponin I, the specificity was 86 percent, the negative predictive value was 98 percent, and the positive predictive value was 17 percent.

### Angioplasty During Admission

There were 133 percutaneous transluminal coronary angioplasties (PTCAs) with or without stenting during admission in 366 patients in 5 trials reporting data (Evidence Table 29). There were 65 PTCAs in studies of troponin T and 68 in studies of troponin I. For patients undergoing PTCA during admission, the troponin T was positive in 32 (49 percent, 32/65). Troponin I was positive in 25 patients undergoing PTCA during admission (37 percent, 25/68). For a positive troponin T result, the specificity was 83 percent, the negative predictive value was 88 percent, and the positive predictive value was 39 percent. For troponin I, the specificity was 88 percent, the negative predictive value was 86 percent, and the positive predictive value was 42 percent. Physicians may have been more likely to refer to revascularization if they believed that troponin-positive patients would benefit. However, there were no obvious differences in PTCA use during admission between studies that did and did not state that providers were blinded to troponin results.

### Bypass Surgery During Admission

There were 56 coronary artery bypass grafting (CABG) operations performed during the initial hospitalization in 366 patients in 5 trials reporting data (Evidence Table 30). There were 45 bypass operations during admission in studies of troponin T and 11 in studies of troponin I. In patients undergoing bypass grafting, troponin T was positive in 14 (31 percent, 14/45). Troponin I was positive in 6 patients undergoing bypass grafting (55 percent, 6/11). For troponin T, the specificity was 79 percent, the negative predictive value was 89 percent, and the positive predictive value was 17 percent. For troponin I, the specificity was 85 percent, the negative predictive value was 98 percent, and the positive predictive value was 10 percent. There were no obvious differences in CABG use during admission between studies that did and did not state that providers were blinded to troponin results.

### Myocardial Infarction During Followup

There were 147 myocardial infarctions following discharge in 3,338 patients in 15 trials reporting data over a mean followup of 15±15 weeks (Evidence Table 31). There were 138 infarctions in studies of troponin T and 56 in studies of troponin I. In patients with a myocardial infarction following discharge, troponin T was positive in 80 (sensitivity 58 percent). Troponin I was positive in 32 patients with a subsequent infarction (sensitivity 57 percent). For troponin T, the specificity was 79 percent, the negative predictive value was 98 percent, and the positive predictive value was 11 percent. For troponin I, the specificity was 88 percent, the negative predictive value was 99 percent, and the positive predictive value was 7 percent.

### Death During Followup

There were 167 deaths during 15±15 weeks of followup in 5,667 patients in 18 trials reporting data (Evidence Table 32). There were 131 deaths in studies of troponin T and 65 in studies of troponin I. The troponin T was positive in 89 of the patients that died (68 percent), and troponin I was positive in 52 patients that died (80 percent). For troponin T, the specificity was 78 percent, the negative predictive value was 99 percent, and the positive predictive value was 7 percent. For troponin I, the specificity was 82 percent, the negative predictive value was 99 percent, and the positive predictive value was 5 percent. The relative risk of death for patients with a positive troponin test decreased with increasing followup, suggesting that early adverse outcomes are most strongly associated with the troponin level.

### Composite Endpoints During Followup

There were 1,465 composite endpoints reached during a mean 18±35 weeks of followup in 7,189 patients in 26 trials reporting data (Evidence Table 33). Approximately one-half of the trials (14/26) reported the combination of death and myocardial infarction. The remainder (12/26) included additional cardiac events or procedures as endpoints. A composite endpoint was reached in 1,292 patients in studies of troponin T, compared with 882 in studies of troponin I. The troponin T was positive in 568 patients with a composite endpoint (sensitivity 44 percent). Troponin I was positive in 325 patients with a composite endpoint (sensitivity 37 percent). For troponin T, the specificity was 90 percent, the negative predictive value was 85 percent, and the positive predictive value was 57 percent. For troponin I, the specificity was 97 percent, the negative predictive value was 83 percent, and the positive predictive value was 82 percent.

### Angioplasty During Followup

There were 182 PTCAs with or without stenting during a mean followup of 41±60 weeks of followup in 1,316 patients in 5 trials reporting data (Evidence Table 34). There were 182 PTCAs in studies of troponin T and 51 in studies of troponin I. For patients undergoing PTCA during followup, the troponin T was initially positive in 79 (43 percent). The troponin I was positive in 22 undergoing PTCA during followup (43 percent). For troponin T, the specificity was 62 percent, the negative predictive value was 87 percent, and the positive predictive value was 15 percent. For troponin I, the specificity was 85 percent, the negative predictive value was 97 percent, and the positive predictive value was 10 percent.

### Bypass Grafting During Followup

There were 233 bypass graft surgeries performed during a mean followup of 38±54 weeks of followup in 1,445 patients in 6 trials reporting data (Evidence Table 35). Bypass surgeries were performed in 169 patients in studies of troponin T compared with 51 patients in studies of troponin I. For patients undergoing bypass grafting during followup, the troponin T was initially positive in 78 (46 percent). The troponin I was positive in 22 undergoing bypass grafting during followup (43 percent). For troponin T, the specificity was 63 percent, the negative predictive value was 90 percent, and the positive predictive value was 14 percent. For troponin I, the specificity was 86 percent, the negative predictive value was 98 percent, and the positive predictive value was 10 percent.

### Subgroup Comparisons: Risk of Death

The relative risk of death and the combination of death or myocardial infarction for a patient with a positive troponin T or I test for each trial is displayed in Figures 2 and 3 and Summary Tables 3 to 6. An elevated troponin value was associated with an increased risk of death regardless of whether total death or only cardiac death was reported (Figures 4 and 5). Similarly, an elevated troponin level indicated a poor prognosis in unstable angina patients and in chest pain patients for whom myocardial infarction had been excluded (Figures 6 and 7). There were few studies of rapid bedside tests, but these showed a similar likelihood of a positive study when compared with studies of nonbedside methods of testing (Figures 8 and 9).

Figure 2. Risk of death: Troponin T

Figure 3. Risk of death: Troponin I

Figure 4. Risk of total death

Figure 5. Risk of cardiac death

Figure 6. Risk of death: Unstable angina patients

Figure 7. Risk of death: Chest pain patients

Figure 8. Risk of death: Rapid bedside testing

Figure 9. Risk of death: Non-bedside testing

The absolute increased risk of death with a positive troponin test varied with time of followup. When followup was limited to fewer than 2 weeks, the mean increase in risk of death was 9 percent. For studies with longer followup, the absolute increased risk of death was 5 percent. This finding is consistent with the hypothesis that an elevated troponin level indicates risk of ischemic death that decreases over time following the initial event and the risk of other causes of death remains constant.

The absolute risk of death was also associated with the baseline risk of death (relative risk [RR]=0.36, p=0.01, Figure 10). An increase in the overall mortality rate of 1 percent was associated with a 0.6 percent additional increase in the risk of death in troponin-positive patients.

Figure 10. Correlation between mortality and troponin positive risk

### Meta-Analysis of the Relative Risk of Death

When studies of troponin T were pooled, the relative risk for an increased risk of death was 3.1 (95 percent CI: 2.0-4.9) for total death, and 3.8 (95 percent CI: 2.4-6.0) for cardiac death (Summary Tables 3 and 7). Similar risks were observed when trials of unstable angina or chest pain patients (unstable angina and MI) were examined separately.

For studies of troponin I, the pooled relative risk for an increased risk of death was 3.9 (95 percent CI: 2.9-5.3) for total death, and 25 (95 percent CI: 11-56) for cardiac death (Summary Tables 4 and 7). As with troponin T, similar risks were observed when trials of unstable angina or chest pain patients (unstable angina and MI) were examined separately.

When all troponin studies were combined, the pooled relative risk for increased risk of death was 3.9 (95 percent CI: 3.0-5.3). The absolute increase in mortality was 3.9 percent (95 percent CI: 3.0-4.4) for patients with a positive troponin level.

The majority of studies used a threshold for a positive troponin between 0.1 and 0.2 ng/ml. The relative risk for increased risk of death was 4.0 (95 percent CI: 2.9-5.5) for the 10 trials of troponin T that used a cutoff of between 0.1 and 0.2 ng/ml. This result was not obviously different from those in the two trials that used a higher cutoff (relative risk 3.7, 95 percent CI: 1.9-7.5).

We evaluated the effect of followup time on the relative risk for increased risk of death by grouping trials into those with short-term followup (1-4 weeks, N=7), and long-term followup (greater than 4 weeks, N=7). There was a clear trend toward decreasing relative risk with increasing followup time. At 1-4 weeks, the relative risk was 5.3 (95 percent CI: 3.6-7.9). For longer term studies, the relative risk was 2.7 (95 percent CI: 1.8-4.2).

### Meta-Analysis of the Relative Risk of Death or Myocardial Infarction

We examined the risk of death or subsequent myocardial infarction in the six trials of unstable angina that reported this data (Summary Tables 5 and 8). When all troponin studies were combined, the pooled odds ratio for increased risk of death or myocardial infarction was 3.8 (95 percent CI: 2.6-5.5). The weighted average for risk of death or subsequent MI in patients with a negative troponin was 6.4 percent (median followup: 4 weeks). For patients with a positive troponin test result, 20.8 percent had died or had a nonfatal myocardial infarction during the same period. The absolute increase in the rate of death or MI was 14 percent (95 percent CI: 10-18).

For studies of troponin T, the pooled relative risk for an increased risk of death or myocardial infarction was 3.8 (95 percent CI: 2.6-5.5) for patients with unstable angina (Summary Tables 5 and 8).

For studies of troponin I, the pooled relative risk for an increased risk of death or myocardial infarction was 5.7 (95 percent CI: 1.8--19) for patients with unstable angina (Summary Tables 6 and 8).

We evaluated the effect of followup time on the relative risk for increased risk of death by grouping trials into those with short-term followup (1--4 weeks, N=4), and long-term followup (greater than 4 weeks, N=2). The relative risk decreased with increasing followup time. At 1 to 4 weeks, the relative risk was 12.3 (95 percent CI: 6.4-23.8). For longer term studies, the relative risk was 2.0 (95 percent CI: 1.3-3.2).

## Evaluation of Chest Pain Units and Emergency Department Protocols

### Randomized Trials of Chest Pain Units

Three randomized trials assessing chest pain units or accelerated diagnostic protocols in the ED were published (Evidence Table 36). Patients presenting to the ED who were determined to be at low risk for infarction or intermediate risk for unstable angina were randomized to a specified ED-based or chest pain unit protocol (intervention) or to routine hospital or telemetry unit care (control) (Evidence Table 36). Patient baseline characteristics were not significantly different between intervention and control groups for all three studies (Evidence Table 37). Patients randomized to the intervention group in all three studies were administered aspirin, monitored for ECG changes during varying observation periods, and assessed for CK-MB enzyme levels at varying time points (Evidence Table 38). Patients with positive enzyme tests, recurrent chest pain, or ECG changes indicative of ischemia during observation were admitted (Evidence Tables 39 and 40). Patients with negative enzyme and ECG results underwent cardiac stress testing (Evidence Table 41). In two studies, patients who were unable to perform treadmill exercise stress tests were administered pharmacologic stress tests (Evidence Table 41). Nuclear imaging or echocardiography was also conducted in two of the studies. Positive or indeterminate stress test or imaging results also led to admission of intervention patients (Evidence Tables 39 and 40).

Deaths or myocardial infarctions that occurred during the hospital stay or within 30-day followup were considered "early events" (Evidence Table 42). There were no statistically significant differences in the number of early events between intervention and control groups in all studies (Evidence Table 42). Similarly, there were no statistically significant differences for subsequent events between intervention and control groups in all studies (Evidence Table 43). Each study assessed the number of patients returning to the ED or hospital after initial hospital stay (Evidence Table 44). There were no significant differences between intervention or control groups for ED or hospital returns in all studies. Survival analysis performed in one study (data not shown) (Farkouh, Smars, Reeder, et al., 1998) determined that there were no significant differences between the intervention and control groups for survival free of a primary event (nonfatal myocardial infarction, death, acute congestive heart failure, stroke, or out-of-hospital cardiac arrest) during 6 months of followup. All events that occurred in the intervention group were in patients who met criteria for hospital admission, and most events occurred within the first month after randomization (Farkouh, Smars, Reeder, et al., 1998).

All studies assessed length of stay and cost for intervention and control groups (Evidence Tables 45 and 46). In two studies, the length of stay for controls was significantly longer than for intervention patients (Evidence Table 45). Cost analysis showed that, in general, patients initially admitted to the hospital incur significantly higher costs for cardiac care (Evidence Table 46). One study used resource-based relative-value unit analysis and determined that costs were approximately 61 percent higher for in-hospital care compared with chest pain unit care costs (Evidence Table 46). In addition, this study indicated that use of cardiac tests and procedures during 6 months of followup was significantly greater in the hospital care group (Farkouh, Smars, Reeder, et al., 1998). One study, using charge data as a proxy for cost, showed that initial stay and 30-day followup costs were significantly higher in the routine care group (Evidence Table 46). Routine care protocols were typically less consistent and often involved more expensive testing such as thallium scans and coronary arteriography compared with graded exercise or dobutamine stress testing that was used routinely in chest pain unit protocols. The impact of these cardiac tests and interventional therapies on length of stay and cost outcomes is significant.

### Emergency Department Protocols

Two controlled clinical trials evaluating an acute cardiac ischemia predictability triage protocol were published. The acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) was used in multicenter and single-center settings (Evidence Table 47) and provides ED physicians with a 0 to 1 percent probability of ACI to incorporate into triage decisionmaking. The variables used to calculate the probability by logistic regression modeling include the following: (1) age, (2) gender, (3) presence or absence of chest pain or pressure or left arm pain, (4) whether chest pain or pressure was the patient's most important presenting symptom, (5) the presence or absence of ECG Q waves, (6) the presence and degree of ECG ST-segment elevation or depression, and (7) the presence and degree of ECG T-wave elevation or inversion. Using an alternating 7-month study design, two investigative groups assessed triage accuracy, time to triage, 30-day mortality, and rehospitalization rates during months when ACI-TIPI results were printed on initial ECG readings (intervention), and during months when ACI-TIPI results were not printed on initial ECG readings (control). Baseline patient characteristics were not significantly different between intervention and control groups in both studies (Evidence Table 48). Patient diagnostic characteristics were similar between intervention and control groups in both studies (Evidence Table 49).

The use of ACI-TIPI at hospitals with high-capacity cardiac care units (CCUs) reduced admissions to the CCU for patients without cardiac ischemia and increased discharges to home (Evidence Table 50). These results were considered of borderline significance (p=0.09). Patients who were identified as having a lower predictive probability of acute cardiac ischemia (<10 percent) experienced greater reductions in admission rates (odds ratio, 0.51 [95 percent CI: 0.28-0.91]) than patients in higher risk groups (odds ratio, 0.74 [95 percent CI: 0.52-1.05], data not shown) (Selker, Beshansky, Griffith, et al., 1998). There were no significant differences in admissions to the CCU or non-CCU wards or discharges home between intervention and control groups of patients without cardiac ischemia at hospitals with low-capacity CCUs (Evidence Table 51).

There were significant reductions in CCU admissions in high-capacity CCU hospitals for patients diagnosed with stable angina pectoris when ACI-TIPI was used (Evidence Table 52). Admissions to non-CCU wards and discharges home increased with ACI-TIPI (overall p=0.02) (Evidence Table 52). In low-capacity CCU hospitals, use of ACI-TIPI improved triage by decreasing non-CCU admissions and increasing discharges home (overall p=0.02) (Evidence Table 53). Patients identified as having a low or low-mid predictive probability of acute cardiac ischemia (< 25 percent) experienced greater reductions in admission rates (odds ratio, 0.36 [95 percent CI: 0.13-0.999]) than patients in high-mid or high probability groups (>25 percent) (odds ratio, 0.73 [95 percent CI: 0.34-1.58], data not shown) (Selker, Beshansky, Griffith, et al., 1998). For patients diagnosed with acute myocardial infarction or unstable angina, the use of ACI-TIPI had no effect on triage in all hospitals (Evidence Tables 54 and 55).

There were no significant differences in 30-day mortality or 30-day rehospitalization for patients during ACI-TIPI intervention or ACI-TIPI control months in either study (Evidence Tables 56 and 57). No significant reductions in time to triage were seen when ACI-TIPI was used (Evidence Table 58). However, when novice clinicians (physicians in their first emergency department rotation) used ACI-TIPI and patients were diagnosed with acute cardiac ischemia, the time of triage from ED presentation to ED release decreased by 0.7 hours (p=0.7) (data not shown) (Sarasin, Reymond, Griffith, et al., 1994).

### Chest Pain Unit Safety

To address chest pain unit safety, two nonrandomized, noncontrolled studies with large population numbers are discussed. First, the Heart Emergency Room (ER) program enrolled 1,010 patients with possible acute ischemic coronary syndrome to assess a comprehensive diagnostic 9-hour evaluation (Gibler, Runyon, Levy, et al., 1995). This study has the highest cohort number of any studies evaluating chest pain unit protocol efficacy for low- to moderate-risk patients to date (data not shown). After the standard 9-hour observation period, 829 (82.1 percent) patients were released home. Positive serial CK-MB assay results, ECG results, or echocardiography results consistent with MI or evolving MI led to 153 patient admissions (15.1 percent). Fifty-two patients (34 percent) were diagnosed with cardiac disease; of those, 12 (23 percent) had a diagnosis of MI and 31 (59.6 percent) were diagnosed with angina or unstable angina. During 1 month of followup, one patient (0.12 percent) was rehospitalized for AMI 3 days after discharge home with negative heart ED evaluation. Another patient with negative heart ED evaluation died 3 weeks later of unknown cause. The mean age of the study population was 45.0 years. The incidence of MI in the heart ER population was 1.2 percent, a low-risk population.

Second, a multiple-site registry study of eight established chest pain units evaluated a total of 23,407 patients presenting to study hospitals' emergency departments with chest pain (Graff, Dallara, Ross, et al., 1997). A comparison population was used from five previous studies involving a total of 12,405 patients. The study measured the proportion of ED patients who underwent "rule-out MI" evaluation and the rate of "missed MIs" who returned to the ED. A higher proportion of the chest pain unit population, relative to the comparison population, underwent a rule-out MI evaluation (67 percent versus 57 percent, p<0.1). Consequently, fewer MIs were missed during the initial ED visit (0.4 percent versus 4.5 percent, p<0.1). A lower proportion of chest pain unit patients were admitted after the initial ED evaluation (41 percent versus 57 percent, p<0.1). Costs were lower for patients evaluated in chest pain units than for patients evaluated by routine hospital care. Followup mortality data were not reported by these authors.

### Chest Pain Units and Patient Satisfaction

One randomized trial retrieved from our search criteria assessed patient satisfaction with care in an emergency chest pain observation unit (CPOU) (data not shown) (Rydman, Zalenski, Roberts, et al., 1997). Evaluation of 104 patients randomized to the CPOU or to inpatient care found that scores on global satisfaction indicators-quality of service, receipt of desired service, fulfillment of hospital needs, recommendation of service, satisfaction with service, effective handling of problem, overall satisfaction-were consistently higher for the CPOU. Higher scores for quality of service, recommendation of service, effective treatment of health problem, and overall satisfaction were statistically significant. Patients reported fewer total problems related to CPOU service than inpatient service (p=0.02), including areas of patient communication, fulfillment of special needs or preferences, and physical comfort. Patients' perceived length of stay did not differ significantly between CPOU or inpatient service (data not shown).

Investigators in this study compared their findings with national reference data and found that overall satisfaction with care was most strongly correlated with fewer problems in the areas of communication, total number of problems, special needs or preferences, emotional support, physical comfort, patient education, and discharge preparation (data not shown). The authors do not mention the impact of the "Hawthorne effect" (greater effort and enthusiasm put forth by staff in a newer unit and their effect on patients relative to staff in an established CCU or telemetry unit) on their data. However, the authors also do not indicate the "age" of the CPOU evaluated.