# Methodology

## Prognostic Value of the History, Physical Examination, and Electrocardiogram

### Data Sources

We conducted a systematic literature search of MEDLINE from 1966 to 1998 and hand searched references of retrieved articles to identify additional relevant published studies. Our search criteria included MEDLINE exact subject and keyword searches for (1) chest pain, angina pectoris, unstable angina, variant angina, vasospastic angina, or acute coronary syndrome combined with (2) the terms risk, stratification, prognosis, outcome, and multivariate analysis.

### Study Selection

Our goal was to identify the factors in the clinical evaluation that identified higher risk patients. This evaluation is a continuing process in the care of the patient and is initiated in the emergency department (i.e., at the point of initial contact) for all patients with chest pain, and it continues after the initial triage and identification of patients with unstable angina. The literature contains studies conducted at both points in this process. We reviewed each separately, since risk factors may differ at various stages of evaluation. We also compared the high-risk features in each setting, as consistency across studies and through the evaluation process might reveal particularly valuable risk markers. We restricted our review to only those studies that performed a multivariate analysis of the clinical and/or electrocardiographic predictors of adverse clinical events in patients with either chest pain suggestive of ischemia or diagnosed unstable angina in the emergency department or hospital. We wished to determine those variables that provided independent risk prediction. Therefore, studies were excluded if they performed a multivariate analysis but did not provide the quantitative results with measures of significance (e.g., p value, standard error) in the form of regression estimates, relative risks, odds ratios, or rate ratios. A p value of <0.05 was considered statistically significant. Studies were also excluded if they did not evaluate clinical and electrocardiographic variables assessed on initial presentation in the emergency department or within the first 24 hours of admission to the hospital. Finally, studies only determining the importance of ST elevation on outcomes or characteristics about only patients with ST elevation were excluded, since this is a subgroup that should be considered for immediate reperfusion therapy (Ryan, Anderson, Antman, et al., 1996) and is not the population of interest for this report. We also excluded non-English language studies.

### Predictor Variables

Predictor variables of interest included clinical and electrocardiographic information readily available at the time of initial presentation and diagnostic evaluation. These included demographic characteristics (age, sex, race/ethnicity), medical history (prior myocardial infarction, unstable or stable angina, revascularization, congestive heart failure, cerebrovascular disease, hypertension, diabetes, and smoking history), symptom characteristics (frequency, duration, and pattern of chest pain), initial physical examination findings (blood pressure, heart rate, and pulmonary rales or other evidence of congestive heart failure), and initial electrocardiographic features (ST-segment depression, transient ST-segment elevation, isolated T-wave inversions, other findings, or a normal electrocardiogram).

### Outcome Measures

We included studies that measured at least one of the following outcomes: cardiac death (death due to cardiac causes), myocardial infarction, urgent revascularization, other major cardiac complication (congestive heart failure, nonfatal ventricular arrhythmia, high-degree heart block, atrioventricular dissociation, cardiogenic shock, cardiac arrest, emergent intubation, or insertion of an intra-aortic balloon pump). For the topic of chest pain, we also included a confirmed diagnosis of unstable angina as an additional outcome. For the topic of diagnosed unstable angina, we also included readmission for unstable angina as an additional outcome.

### Data Extraction

Drs. Go and Heidenreich reviewed titles of identified articles. Candidate abstracts were then reviewed, and appropriate studies were selected for data extraction. Drs. Go and Heidenreich extracted relevant data from each article. One reviewer (Dr. Heidenreich) was a cardiologist; both reviewers had training in epidemiology and health services research.

### Statistical Analysis and Reporting

Substantial differences existed across the included studies in the populations evaluated, predictor variables and outcomes assessed, and analysis techniques employed. This marked heterogeneity in the reviewed studies precluded use of quantitative pooled analysis or meta-analytic techniques to determine summary estimates for significant risk factors (Mulrow, Langhorne, and Grimshaw, 1997). Therefore, studies were stratified by type of patients evaluated (chest pain or diagnosed unstable angina), and multivariate results were grouped into categories of demographic characteristics, medical history features, symptom characteristics, initial physical findings, and electrocardiographic features. Several reports from the Multicenter Chest Pain Study provided overlapping data. To avoid duplicate information, we used data from the study by Lee (Lee, Ting, Shammash, et al., 1992). Risk factors were classified as possible independent risk factors or not significantly associated risk factors. Risk factors were included as possible independent risk factors if they were found to be statistically significant in a multivariate analysis in at least one study.

To provide consistency of interpretation across studies that used different analytic techniques, we reported the estimates for statistically significant variables using a semiquantitative scale, as shown in Table 1.

Table 1. Semiquantitative grading of the relative risk, odds ratio, or rate ratio ^1^

Reported Relative Risk, Odds Ratio, or Rate Ratio | Estimate
<0.50 | --
0.50-0.99 | -
1.0 or not statistically significant | NS
1.1-2.0 | +
2.1-3.0 | ++
>3.0 | +++

1 Values <1 indicate decreased risk; values >1 indicate increased risk.

## Prognostic Value of Troponin

### Data Sources

We searched MEDLINE (1966-98) and EMBASE (1974-98) and reviewed cited references of retrieved articles to identify published studies. Our search criteria were (1) the text word troponin, and (2) the text words angina or unstable or myocardial infarction or ischemia, and (3) language English, excluding (4) the MeSH heading animal. Using this criteria set, we searched MEDLINE, using PubMed from the National Library of Medicine. A similar search strategy was performed using EMBASE, except that step 3 (language limitation) was not performed. Finally, we reviewed the bibliographies of identified trials to locate other relevant studies. We attempted to identify large unpublished cohort studies by contacting experts in the field of cardiac markers. No additional studies were identified for the time period of the study.

### Study Selection

We restricted our review to cohort studies that evaluated patient cohorts with suspected ischemia. We excluded studies that only included patients with myocardial infarction. We also excluded case-control studies and studies that did not report the outcome of myocardial infarction or death. We excluded studies that included patients with ST-elevation MI unless they gave separate data on the non-ST-elevation MI patients.

### Data Extraction

Study selection was performed initially by title review (Dr. Heidenreich). Candidate abstracts were then reviewed and selected for data retrieval. Two independent reviewers abstracted data for each article on standardized electronic data forms. A third reviewer compared their results and settled any differences. In general, at least one reviewer of the pair had clinical cardiology expertise.

### Outcome Measures

We recorded the outcomes of myocardial infarction, death, or revascularization. A secondary analysis was performed for myocardial infarctions occurring at least 48 hours after presentation. If outcomes at more than one time period were reported, we used the value closest to 30 days following presentation.

### Subgroup Comparisons

The prespecified subgroup comparisons of interest were studies of all patients with suspected ischemia versus patients in whom myocardial infarction had already been excluded. The former patients were those recruited from emergency departments, whereas the latter patients were those recruited from inpatient services. Reported p values are two-tailed with statistical significance at p<0.05.

### Statistical Analysis

We used standard methods of meta-analysis to combine outcomes data across trials. We used the Peto (fixed-effects) and DerSimonian-Laird (random-effects) methods to estimate summary odds ratios for the outcomes of death and myocardial infarction (DerSimonian and Laird, 1986; Petitti, 1994). Fixed-effects results are presented unless otherwise stated. For studies that reported no events, we substituted 0.1 in place of 0 for the random-effects calculation. (Because events were rare, we chose a value below the more commonly used 0.5.) We tested homogeneity of study effect size using the Q statistic (Petitti, 1994). A summary rate difference was calculated for trials with one or more adverse events (Petitti, 1994). This measure complements the odds ratio by providing an absolute difference in the adverse event rate. We examined differences between study subgroups of trials using analysis of variance (Hedges, 1994). Data are presented as summary odds ratio with 95 percent confidence interval. Reported p values are two-tailed with statistical significance at p<0.05.

## Evaluation of Chest Pain Units and Emergency Department Protocols

### Data Sources

We conducted a systematic literature search of MEDLINE between 1966 and 1998. The first search strategy included the following search terms: (random* [All Fields] AND (chest pain [MeSH Terms] OR chest pain [Text Word]) AND (emergencies [MeSH Terms] OR emergency [Text Word]). The second search strategy included the following terms: ( controlled clinical trial [All Fields] AND (chest pain [MeSH Terms] OR chest pain [Text Word]) AND (emergencies [MeSH Terms] OR emergency [Text Word]). Abstracts and titles from both searches were reviewed for appropriate studies. References of selected articles were reviewed by hand to identify additional relevant published studies.

### Study Selection

Randomized trials or controlled clinical trials were identified. Studies that assessed chest pain units, accelerated or rapid diagnostic protocols, or emergency department triage protocols were reviewed. Noncontrolled studies were also reviewed if they reported outcomes for at least 1,000 patients with suspected acute coronary syndromes.

### Outcome Measures

We recorded the outcomes of hospital admission rate, cost of care, and myocardial infarction and death when available. Other outcomes reported by the trial were recorded if comparisons were made between control and intervention groups.

## Key Questions

1 What are the immediate clinical and electrocardiographic characteristics that are independently associated with an increased risk of adverse outcomes in patients with either chest pain that raises suspicion of cardiac ischemia or diagnosed unstable angina?
2 What is the prognostic value of a positive or negative troponin test in patients with proven or suspected unstable angina?
3 Are chest pain units and ED protocols effective, cost-saving, and safe for triaging patients with suspected unstable angina or myocardial infarction?

## Quality Control

In addition to performing the double abstraction method described above, we examined a random sample of 10 studies to determine errors in abstraction or database entry. Few errors were found in abstraction of primary outcomes.

## Peer Review

Selected independent experts in fields of systematic review, emergency medicine, internal medicine, family practice, cardiology, epidemiology, pathology, and laboratory medicine reviewed the draft manuscript of the evidence report. In addition, the following organizations were invited to nominate individuals to review the manuscript: American College of Cardiology, American College of Chest Physicians, American College of Emergency Physicians, American College of Physicians, American Heart Association, American Hospital Association, National Association of State Emergency Medical Services Directors, National Association of EMS Educators, Society for Academic Emergency Medicine, Emergency Nurses Association, Society of Emergency Medicine Physician Assistants, American College of Clinical Pharmacology, American Society of Health-System Pharmacists, American Association of Pharmaceutical Scientists, and Roche Diagnostics.

The peer reviewers followed a format developed by Dr. Lisa Bero and Dr. Drummond Rennie from the San Francisco Cochrane Center. The reviews were sent to a criticism editor for synthesis and commentary. The authors responded to the editor's commentary and revised the document accordingly (Appendixes C and D).