# Introduction

Unstable angina comprises a broad spectrum of patients with varying levels of risk for suffering unfavorable outcomes such as death, myocardial infarction (MI), or other major cardiac complications. Despite development of various diagnostic approaches, the evaluation of patients with chest pain suggestive of acute ischemia or infarction remains a common, costly problem, with approximately 5 million people undergoing evaluation in emergency departments (EDs) annually at an estimated cost of over $6 billion (Barish, Doherty, and Browne, 1997). Patients with chest pain and ST-segment elevation on a standard electrocardiogram (ECG) are at substantially increased risk for myocardial infarction and cardiac complications, and current guidelines strongly recommend immediate reperfusion therapy (Ryan, Anderson, Antman, et al., 1996). The difficulty lies in predicting who will suffer an adverse event in those patients without ECG evidence of ST elevation or new, pathologic Q waves. This situation leads to many unnecessary hospital admissions (often for intensive monitoring) and to sending home a small proportion of patients who may incur infarction or death outside the hospital. Furthermore, of patients diagnosed with unstable angina, only 6 to 15 percent meet existing criteria for short-term risk of cardiac events low enough to be discharged home safely, based on guidelines from the Agency for Health Care Policy and Research (now the Agency for Healthcare Research and Quality [AHRQ]) (Braunwald, Jones, Mark, et al., 1994; Calvin, Klein, VandenBerg, et al., 1995)

Previous studies have concentrated on finding predictors of significant anatomic coronary artery disease (CAD) (Diamond and Forrester, 1979; Pryor, Harrell, Lee, et al., 1983), but estimating the probability of coronary artery disease in patients with chest pain does not necessarily address the short-term risk of an adverse event.

Although emerging diagnostic tests may assist the clinician in improving identification of higher or lower risk patients, their cost-effectiveness is measured by comparison with the basic evaluation using clinical history, vital signs, physical examination, and initial 12-lead electrocardiogram. Furthermore, many of these newer tests may not be widely available, may not yield timely diagnostic results for efficient triage and management, or may require specialized skills, technological capability, or facilities. Prior studies have tried to assess the utility of presenting clinical and electrocardiographic information in the initial diagnostic evaluation of unstable angina, but often did not determine whether these patient features were independent prognostic factors for clinical outcomes.

The American College of Cardiology and the American Heart Association established a committee to update guidelines on the initial evaluation and risk assessment of patients with unstable angina. At the request of the AHRQ and the Unstable Angina Committee, which had as its overall goal the accurate risk assessment of patients with unstable angina, we performed a literature review. Following preliminary review of the literature, the committee identified two related and relevant patient populations to study: patients with chest pain suspicious for cardiac ischemia in the emergency department setting and those with diagnosed unstable angina. To maximize generalizability, we concentrated on tools readily available to all clinicians at the time of initial evaluation: clinical history, comorbid conditions, vital signs, physical examination, and a standard 12-lead electrocardiogram. We prioritized our in-depth review to focus on information that would be readily available to all providers caring for patients with suspected unstable angina. Other risk factors that also may be important include stress testing, echocardiography, and nuclear scintigraphy. The first key question we sought to answer was the following:

1. What are the immediate clinical and electrocardiographic characteristics that are independently associated with an increased risk of adverse outcomes in patients with either chest pain that raises suspicion of cardiac ischemia or diagnosed unstable angina?

Serum markers of myocardial necrosis have been used in conjunction with the clinical and electrocardiographic characteristics to identify more accurately patients with acute myocardial infarction (AMI) and to predict risk for short- and long-term major adverse cardiac outcomes. The use of biochemical markers for cardiac ischemia has evolved over the last 35 years from aspartate aminotransferase (AST) in 1954 and lactate dehydrogenase (LDH) in 1955 to creatine phosphokinase (CK) in 1960 and the CK-myoglobin (MB) mass immunoassay developed in the 1980s (Gibler, Lewis, Erb, et al., 1990). Each new marker improved accuracy in the diagnosis of cardiac ischemia, and a protocol measuring CK-MB every 8 hours for 24 hours has long been considered the reference standard for biochemical diagnosis of AMI. Nevertheless, serial measurements of CK-MB outside a window of from 4 hours to 3 days after the onset of chest pain have a limited ability to detect myocardial ischemia or to risk stratify patients, and those drawn within the diagnostic window may be elevated because of noncardiac causes such as skeletal muscle injury. Immunoassay for myoglobin, a small molecular mass protein in both cardiac and skeletal tissue, has moderate sensitivity for diagnosis of AMI within the first 4 hours of myocyte injury, but its poor specificity and relatively rapid washout limit its usefulness in the majority of patients with acute coronary syndromes (Bakker, Koelemay, Gorgels, et al., 1994).

Immunoassays for cardiac troponin T (cTnT) and cardiac troponin I (cTnI) were approved by the Food and Drug Administration in 1994 and offer another biochemical marker for diagnosis of AMI and for risk stratification. The myofibrillar troponin complex, comprising three proteins (I, T, and C), regulates contraction of striated muscle. Troponin I inhibits actomyosin adenosine triphosphatase (ATPase), troponin T binds the troponin complex to the tropomyosin strand, and troponin C binds to calcium and regulates contraction. Troponin I and T have different amino acid sequences in adult skeletal and cardiac muscle; antibodies developed to recognize cardiac-specific sequences form the basis of cTnT and cTnI immunoassays. Troponin C has identical amino acid sequence in skeletal and cardiac muscle, so it has no role as a cardiac-specific marker of cell injury (Alonsozana and Christenson, 1996). Because of the small molecular mass of troponins I and T (24kDa and 36kDa, respectively), these markers are released rapidly from injured myocardium. The initial time course of troponin release parallels that of CK-MB, with initial detection at 4 to 6 hours postinjury and peak levels obtained at 12 to 18 hours. Unlike CK-MB, the levels of cTnI and cTnT remain elevated for up to 8 to 14 days, respectively, after cell injury (Ravkilde, 1998; Tanasijevic, Cannon, and Antman, 1999).

Prospective studies of troponin assays in acute coronary syndromes have demonstrated that cTnT and cTnI have diagnostic accuracy comparable to, if not better than CK-MB (Gerhardt, Katus, Ravkilde, et al., 1991; Johnson, Goldman, Sacks, et al., 1999; Polanczyk, Lee, Cook, et al., 1998) and can better predict long-term risk for adverse cardiac events (Antman, Tanasijevic, Thompson, et al., 1996; Hamm, Goldmann, Heeschen, et al., 1997; Ohman, Armstrong, Christenson, et al., 1996; Ravkilde, Horder, Gerhardt, et al., 1993; Ravkilde, Nissen, Horder, et al., 1995). However, interpretation of the aggregate data to date is hampered by differences in cutoff values used to define positive tests, lack of assay standardization (troponin I), heterogeneity in patient populations to which the tests have been applied, and variations in statistical analysis and presentation of results. The appropriate criterion for diagnosis of acute MI based on CK-MB and troponin findings is still unsettled. Indeed, the definition of acute MI in the face of this information is not yet clear. In this regard, the prognostic value of troponin measurement is of particular importance. To provide a better overall assessment of the prognostic value of cTnT and cTnI, we conducted a systematic review of published studies. Thus, the second key question we addressed was the following:

2. What is the prognostic value of a positive or negative troponin test in patients with proven or suspected unstable angina?

The initial risk stratification of patients with suspected acute ischemic syndromes is usually performed in the emergency department or other urgent care setting. In an attempt to improve diagnostic accuracy and reduce costs, many medical centers have developed standardized protocols for evaluating patients with chest pain. Frequently these protocols are carried out in chest pain centers within or adjacent to the emergency department. Because chest pain units attempt to risk stratify patients based on readily available data, an assessment of their efficacy is significant to this report. To evaluate the costs and effectiveness of these standardized risk stratification methods, we also performed a systematic literature review of chest pain units or chest pain-specific protocols. Therefore, the third key question we addressed was the following:

3. Are chest pain units and ED protocols effective, cost-saving, and safe for triaging patients with suspected unstable angina or myocardial infarction?