# Appendix C. Acronyms

ACE: angiotensin-converting enzyme

ACI: acute cardiac ischemia

ACI-TIPI: acute cardiac ischemia time-insensitive predictive instrument

Adm: admission

ADP: accelerated diagnostic protocol

AHCPR: Agency for Health Care Policy and Research

AHRQ: Agency for Healthcare Research and Quality

AMI: acute myocardial infarction

ASA: aspirin

AST: aspartate aminotransferase

ATPase: adenosine triphosphatase

AV: atrioventricular

BP: blood pressure

bpm: beats per minute

CABG: coronary artery bypass graft

CAD: coronary artery disease

CCB: calcium channel blocker

CCSC: Canadian Cardiovascular Society Class

CCU: cardiac care unit

CE: composite endpoint

CHD: coronary heart disease

CHF: congestive heart failure

CI: confidence interval

CK :creatinine phosphokinase

CK-MB: creatinine phosphokinase, MB fraction

CPOU: chest pain observation unit

cTnI: cardiac troponin I

cTnT: cardiac troponin T

CV: cardiovascular

CVA: cerebrovascular accident

DBP: diastolic blood pressure

Def'n: definition

Dept: department

DM: diabetes mellitus

dx: diagnosis

ECG: electrocardiogram

ED: emergency department

EPC: evidence-based practice center

F: female

GUSTO: Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries

HD: heart disease

HR: heart rate

HTN: hypertension

hx: history

IABP:intra-aortic balloon pump

IV:intravenous

LBBB: left bundle branch block

LDH:lactate dehydrogenase

LOS:length of stay

LVEF: left ventricular ejection fraction

LVH: left ventricular hypertrophy

M: male

MB: myoglobin

MGH: Massachusetts General Hospital

MI: myocardial infarction

MILIS: Multicenter Investigation of the Limitation of Infarct Size

mmHg:millimeters of mercury

mV: millivolt

n/a: not available

NA: not available

NQWMI: non-Q-wave myocardial infarction

NS: nonsignificant

NTG: nitroglycerine

Pos: positive

Post-OP: postoperative

PTCA: percutaneous transluminal coronary angioplasty

PVC: premature ventricular contraction

RBBB: right bundle branch block

revasc: revascularization

RR: relative risk

S3: third heart sound

S4: fourth heart sound

SBP: systolic blood pressure

SD: standard deviation

STT: ST-segment or T-wave

TIA: transient ischemic attack

TIMI: Thromobolysis in Myocardial Infarction

TWI: T-wave inversion

VF: ventricular fibrillation

VT: ventricular tachycardia

W: white