# Appendix B. Research Team

The team was led by cardiologists Mark Hlatky and Paul Heidenreich. Further information about the UCSF-Stanford Evidence-based Practice Center can be found at:

http://www.stanford.edu/group/epc/

(alphabetical listing)

Thomas Alloggiamento, M.D. (Research Associate)

Alan Go, M.D., M.P.H. (Research Associate)

Vivian Hagan (Research Assistant)

Trevor Hastie, Ph.D. (Biostatistician)

Mark A. Hlatky, M.D. (Project Director)

Paul A. Heidenreich, M.D., M.S. (Assistant Director)

Kathryn M. McDonald, M.M. (Center Coordinator)

Kathryn A. Melsop, M.S. (Research Assistant)

Elaine Steel (Project Assistant)