# Appendix A. Acknowledgments

## Peer Reviewers

### At-large Reviewers

Ezra A. Amsterdam, MD Division of Cardiovascular Medicine 4150 "V" Street, Suite 3500 Sacramento, CA 95817

Dr. N. Curzen, Ph.D., MRCP Consultant Cardiologist Manchester Heart Centre Manchester Royal Infirmary Oxford Road Manchester M13 9WL

Andrew M. Hauser, MD Director, Cardiac Ultrasound Laboratory William Beaumont Hospital Royal Oak, MI

David Holmes, Jr., MD Cardiovascular Diseases & Internal Medicine Mayo Clinic 200 First Street SW Rochester, Minnesota 55905

Spencer B. King III, M.D. Professor of Medicine (Cardiology) Emory U. School of Medicine Director, Interventional Cardiology Emory U. Hospital 1364 Clifton Rd. NE, Suite F606 Atlanta, GA 30322

Michael C. Kontos, MD Associate Director, Acute Cardiac Care Assistant Professor, Cardiology and Emergency Medicine 1200 E Marshall St PO Box 980051 Richmond, VA 23298-0051

Thomas H. Lee, MD Associate Professor of Medicine Harvard Medical School Medical Director Partners Community HealthCare, Inc. Prudential Tower, 11^th^ floor 800 Boylston Street Boston, MA 02199

Wiliam C. Little, MD Professor of Medicine Chief, Cardiology Section Department of Internal Medicine Wake Forest School of Medicine The Bowman Gray Campus Medical Center Boulevard Winston-Salem, North Carolina 27157

David Malenka, MD Associate Professor of Medicine Section of Cardiology Darthmouth-Hitchcock Medical Center Lebanon, NH 03756

Emile R. Mohler III, MD Presbyterian Medical Center Philadelphia Heart Institute Building, Room 432-B 39th and Market Streets Philadelphia, PA 19104

John Sarko, MD Department of Emergency Medicine Maricopa Medical Center 2601 E. Roosevelt Phoeniz, AZ 85008

Alan H.B. Wu, MD Department of Pathology and Laboratory Medicine Hartford Hospital 80 Seymore Street Hartford, Connecticut 06102-5037 and Professor, Department of Laboratory Medicine University of Connecticut Health Center Farmington, CT 06030

Robert J. Zalenski, MD, MA Department of Emergency Medicine Wayne State University School of Medicine 4201 St Antoine Detroit, Michigan 48201

### Technical Reviewer

Magnus Ohman, MD, FACC Associate Professor of Medicine Division of Cardiology Co-Director, Clinical Trials Duke Clinical Research 2400 Pratt Street, Room 0311 Terrace Level Durham, NC 27705

## Nominated Reviewers

### American College of Physicians

Gottlieb C. Friesinger II, MD, MACP Professor of Medicine and the Betty and Jack Bailey Professor of Cardiology in the Department of Medicine Vanderbilt University Division of Cardiology 2220 Pierce Avenue Nashville, TN 37232

### American Society of Health-System Pharmacists

G. Dennis Clifton, PharmD College of Pharmacy Washington State University The Heart Institute of Spokane 122 W. 7^th^ Avenue, Suite 230 Spokane, WA 99204

Sarah A. Spinler, PharmD, FCCP Associate Professor of Clinical Pharmacy Philadelphia College of Pharmacy University of the Sciences in Philadelphia 600 South 43rd Street Philadelphia, PA 19104-9938

### American College of Emergency Physicians

Earl E. Smith III, MD, FACEP 1503 Blackbird Lane San Antonio, TX 78248

Francis M. Fesmire, MD, FACEP Director, Heart-Stroke Center Erlanger Medical Center Assistant Professor of Medicine University of Tennessee College of Medicine PO Box 4045 Chattanooga, TN 37405

### American Hospital Association

Donald M. Nielsen, MD Senior Vice President for Quality Leadership American Hospital Association 325 Seventh Street, NW Washington, DC 20004

### Society of Emergency Medicine Physician Assistants

Terry Mize, PA-C Past President, SEMPA Society of Emergency Medicine PAs 1564 S. Josephine Street Denver, CO 80210

### Emergency Nurses Association

Cindy Abel, RN, MSN, CEN President, Emergency Nurses Association Clinical Nurse Specialist Emergency Department Rush-Copley Medical Center Aurora, IL 60505

S. Kay Sedlak, RN, MS, CEN Saint Mary's Health Network 235 West 6^th^ Street Reno, Nevada 89520

Suzanne M. Wall, RN, MS CEN 54 Lackine Drive Rochester, NY 14618

### Roche Diagnostics

Christopher De Filippi, MD Assistant Professor of Medicine Department of Cardiology University of Texas Medical Branch at Galveston Director, Chest Pain Unit 5.106 John Sealy Annex 301 University Blvd. Galvaston, TX 77555-0553

Kristin Newby, MD, FACC Assistant Professor of Medicine Division of Cardiology Duke University Medical Center and Duke Clinical Research Institute PO Box 17969 Durham, NC 27715

## Criticism Editor

Patricia Huston, MD, MPH Scientific Communications International, Inc. 585 Island Park Crescent Ottawa, ON K1Y 3P3

## Data Abstractors

Dena Bravata, M.D. Bill Fearon, M.D. Byron K. Lee, M.D. Tina Lee, M.D., M.S. Lynnette Lissin, M.D. Eric Putz, M.D. Mark Schleinitz, M.D.

## Lane Medical Library, Stanford University

Christopher Stave, M.L.S. Staff, Document Delivery Services