# Appendixes

Appendix A. Acknowledgments

Appendix B. Research Team

Appendix C. Acronyms