# Evidence Tables

Evidence Table I-1. Study description

Study | Study Description | Disease(s) | Study Population | Patient Eligibility ^1^ | Definition of Complete Response | Definition of Partial Response | Transfusion Trigger (Hb g/dL)
Mean/Median Baseline Hb < 10 g/dL
Silvestris, Romito, Fanelli, et al., 1995 | Randomized; unblinded; concurrent controls | Category: multiple myeloma | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified. | Hb cutoff=8.1 g/dL; Karnofsky PS limit=50 | >/=2 g/dL increase in Hb level or transfusion independence | None
Oberhoff, Neri, Amadori, et al., 1998 | Randomized; unblinded; concurrent controls; multicenter | Category: multiple solid tumors; Tumor type: ovarian, beast, lung, GU, GI, other | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified. | Hb cutoff=11.0 g/dL | Hb increase >/= 2 g/dl in 4 weeks without transfusion in previous 4 weeks | None
Kurz, Marth, Windbichler, et al., 1997 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: multiple solid tumors; Tumor type: ovarian, uterine, cervical | Previous platinum-based chemotherapy; previous radiation therapy unspecified. | Hb cutoff=11.0 g/dL; minimum LE=3 months | Hb > 2 gd/L above baseline value and/or >12 g/dL at 4, 8, or 12 weeks | None | 8
Case, Bukowski, Carey, et al., 1993 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: mixed solid & nonmyeloid hematologic tumors; Tumor type: hemat, breast, gyn, GI, lung, prostate, head/neck, other | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=10.5 g/dL; ECOG PS limit=3; minimum LE=3 months | Increase in Hb of >/=2 g/dL (calc from Hct) unrelated to transfusion | None
Porter, Leahey, Polise, et al., 1996 | Randomized; double-blinded; concurrent controls; placebo | Category: multiple solid tumors; Tumor type: sarcoma | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=10.5 g/dL | None | None | 8
Henry, Brooks, Case, et al., 1995 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: mixed solid & nonmyeloid hematologic tumors; Tumor type: lung, hemat, gyn, BI, head/neck, breast, prostate, esoph | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=10.7 g/dL; ECOG PS limit=3; minimum LE=3 months | Increase in Hb of >/= 2 g/dL (calc from Hct) unrelated to transfusion | None
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Randomized; unblinded; concurrent controls | Category: mixed solid & hematologic tumors; Tumor type: lymphoma, CNS, rhabdo, Wilm's, neuroblastoma, liver | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=10.0 g/dL | None | None | 6
Littlewood, Bajetta and, Cella, 1999 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: mixed solid & nonmyeloid hematologic tumors; Tumor type: breast, non-Hodgkin's lymphoma, myeloma | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified. | Hb cutoff=10.5 g/dL | Hb increase of >/=2g/dL w/o transfusions | None
Leon, Jimenez, Barona, et al., 1998 | Unblinded; historical controls | Category: mixed solid & hematologic tumors; Tumor type: sarcoma, CNS, Hodgkin's lymphoma, other | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=10.5 g/dL; minimum LE=3 months | Hb increase of at least 2 g/dL without transfusion within 12 weeks | None | 9
Cascinu, Fedeli, Del Ferro, et al., 1994 | Randomized; double-blinded; concurrent controls; placebo | Category: multiple solid tumors; Tumor type: stomach, ovary, other | No previous chemotherapy; no previous platinum exposure; no previous radiation therapy. | Hb cutoff=9.0 g/dL | Increase in Hb to >10 g/dL | None | 8
Mean/Median Baseline Hb > 10 and < 12 g/dL
Markman, Reichman, Hakes, et al., 1993 | Unblinded; concurrent controls | Category: single solid tumor; Tumor type: ovarian | Previous platinum-based chemotherapy; previous radiation therapy unspecified. | Hb cutoff=7.7 g/dL (lower limit); Karnofsky PS limit=60; minimum LE=2 months | None | None | 8
Dusenbery, McGuire, Holt, et al., 1994 | Unblinded; historical controls | Category: single solid tumor; Tumor type: cervix | No previous chemotherapy; no previous platinum exposure; no previous radiation therapy. | Hb cutoff=12.0 g/dL | None | None | 9.5
Lavey and Dempsey, 1993 | Unblinded; concurrent controls | Category: mixed solid & hematologic tumors; Tumor type: head and neck, lung/trachea, other | Previous chemotherapy; previous platinum exposure unspecified, no previous radiation therapy. | Hb cutoff=13.5 g/dL | Hb >14 g/dL
Wurnig, Windhager, Schwameis, et al., 1996 | Randomized; double-blinded; concurrent controls; placebo | Category: single solid tumor; Tumor type: Ewing's or osteosarcoma | No previous chemotherapy, no previous platinum exposure, no previous radiation therapy. | Hb cutoff=11.0 g/dL; minimum LE=4.7 months | None | None | 8.5
Henke, Guttenberger, Barke, et al., 1999 | Randomized; unblinded; concurrent controls | Category: multiple solid tumors; Tumor type: head and neck, cervix, uterus, colorectum | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=13.0 g/dL; Karnofsky PS limit=60 | Hb increase of >2 g/dL | None
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Randomized; unblinded; concurrent controls; multicenter | Category: single solid tumor; Tumor type: stage IIb-IV ovarian carcinoma | Previous platinum-based chemotherapy; previous radiation therapy unspecified. | Hb cutoff=13.0 g/dL; WHO PS limit=2; minimum LE=2 months | None | None | 9.7
Quirt, Couture, Pichette, et al., 1996 | Randomized; single-blinded; concurrent controls; placebo; multicenter | Category: mixed solid & hematologic tumors; Tumor type: solid tumors, lymphoma | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified. | Hb cutoff=12.5 g/dL | None | None
Mean/Median Baseline Hb > 12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Randomized; unblinded; concurrent controls; multicenter | Category: multiple solid tumors; Tumor type: lung, uterine, cervix, prostate, breast | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=13.0 g/dL; Karnofsky PS limit=70; minimum LE=3 months | Achieving target Hb levels of 15 for males, 14 for females | None
Gamucci, Thorel, Frasca, et al., 1993 | Randomized; unblinded; concurrent controls | Category: multiple solid tumors; Tumor type: ovarian, NSCLC, SCLC, head/neck, testis, gastric, other | No previous chemotherapy, no previous platinum exposure, no previous radiation therapy. | Hb cutoff=10.0 g/dL (lower limit) | None | None
Del Mastro, Venturini, Lionetto, et al., 1997 | Randomized; unblinded; concurrent controls | Category: single solid tumor; Tumor type: Stage II breast cancer | No previous chemotherapy or previous platinum exposure; previous radiation therapy unspecified. | Hb cutoff=12.0 g/dL (lower limit) | None | None | 8
Thatcher, De Campos, Bell, et al., 1999 | Randomized; unblinded; concurrent controls; multicenter | Category: single solid tumor; Tumor type: small cell lung cancer | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified. | Hb cutoff=10.5 g/dL (lower limit); WHO PS limit=2 | Hb >/=10 | None
Welch, James, Wilkinson, et al., 1995 | Randomized; unblinded; concurrent controls | Category: single solid tumor; Tumor type: ovarian | No previous chemotherapy; no previous platinum exposure, no previous radiation therapy. | Hb cutoff= g/dL (lower limit); WHO PS limit=2 | None | None

1 Unless otherwise indicated, all hemoglobin (Hb) cutoff values represent an upper limit.

Evidence Table I-2. Baseline study characteristics

Citation | Study Arm | EPO Treatment | N Enrolled | N Evaluable | Age ^1^ +/−SD (range) | Baseline Hb (g/dL)+/−SD (range) | % Previously Transfused
Mean/Median Baseline Hb <10 g/dL
Silvestris, Romito, Fanelli, et al., 1995 | Control | | 24 | 22 | | 7.9 | 32.0
Silvestris, Romito, Fanelli, et al., 1995 | EPO | Escalating: 150 U/kg, 3x per week for 24 weeks; 300 U/kg final dose | 30 | 27 | | 7.9 | 44.0
Oberhoff, Neri, Amadori, et al., 1998 | Control | | 110 | 88 | 56 (median) (19-73) | 10.3 | 21.6
Oberhoff, Neri, Amadori, et al., 1998 | EPO | Fixed: 5000 U (total), 7x per week for 12 weeks | 117 | 101 | 53 (median) (20-77) | 9.6 | 22.8
Kurz, Marth, Windbichler, et al., 1997 | Placebo control | | 12 | 12 | 52.7 (mean) +/− 7.5 (43-63) | 9.85+/−0.6
Kurz, Marth, Windbichler, et al., 1997 | EPO | Escalating: 150 U/kg, 3x per week for 12 weeks; 300 U/kg final dose | 23 | 23 | 54.4 (mean) +/− 9.7 (32-68) | 9.88+/−0.8
Case, Bukowski, Carey, et al., 1993 | Placebo control | | 76 | 74 | 64 (median) (30-88) | 9.8 (7.7-13.3) | 67.1
Case, Bukowski, Carey, et al., 1993 | EPO | De-escalating: 150 U/kg, 3x per week for 12 weeks; discontinued when Hb=12.7 | 81 | 79 | 64 (median) (27-92) | 9.5 (6.0-13.3) | 66.7
Porter, Leahey, Polise, et al., 1996 | Placebo control | | 12 | 10 | 13 (median) (5-16) | 9.4 (8.2-10.1)
Porter, Leahey, Polise, et al., 1996 | EPO | Escalating: 150 U/kg, 3x per week for 16 weeks; discontinued when Hb=11.5; 300 U/kg final dose | 12 | 10 | 14 (median) (5-17) | 9.7 (7.7-10.8)
Henry, Brooks, Case, et al., 1995 | Placebo control | | 65 | 61 | 59 (mean) | 9.5+/−1.5
Henry, Brooks, Case, et al., 1995 | EPO | Start/stop: 150 U/kg, 3x per week for 12 weeks; discontinued when Hb=12.7 | 67 | 64 | 58 (mean) | 9.8+/−1.3
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Control | | 17 | 17 | 5 (median) (1-16) | 8.48+/−0.98 | 0.0
Varan, Buyukpamukcu, Kutluk, et al., 1999 | EPO | Fixed: 150 U/kg, 3x per week for 8 weeks | 17 | 17 | 5 (median) (1-16) | 8.5+/−0.85 | 0.0
Littlewood, Bajetta, Cella, et al., 1999 | Placebo control | | 124 | 115 | 59.6 (mean) +/− 13.7 (22.3-88.6) | 9.7+/−1.1 | 34.0
Littlewood, Bajetta, Cella, et al., 1999 | EPO | Escalating: 150 U/kg, 3x per week for 28 weeks; 300 U/kg final dose | 251 | 244 | 58.3 (mean) +/− 14.1 (18.7-84.9) | 9.9+/−1.14 | 29.0
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry </=10.5, Placebo control | | | 100
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry </=10.5, EPO | | | 203
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry >10.5, Placebo control | | | 15
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry >10.5, EPO | | | 41
Littlewood, Bajetta, Cella, et al., 1999 | Solid tumors, placebo control | | | 61
Littlewood, Bajetta, Cella, et al., 1999 | Solid tumors, EPO | | | 131
Littlewood, Bajetta, Cella, et al., 1999 | Hematologic tumors, placebo control | | | 54
Littlewood, Bajetta, Cella, et al., 1999 | Hematologic tumors, EPO | | | 113
Leon, Jimenez, Barona, et al., 1998 | Control | | 25 | 25 | 11.8 (mean) (5-17) | 9.5+/−0.7 | 84.0
Leon, Jimenez, Barona, et al., 1998 | EPO | Fixed: 150 U/kg, 5x per week for 12 weeks | 25 | 25 | 12.6 (mean) (6-17) | 9.8+/−0.6 | 80.0
Cascinu, Fedeli, Del Ferro, et al., 1994 | Placebo control | | 50 | 49 | 57 (median) (45-68) | 8.7+/−0.52
Cascinu, Fedeli, Del Ferro, et al., 1994 | EPO | Start/stop: 100 U/kg, 3x per week for 9 weeks; discontinued when Hb=12 | 50 | 50 | 58 (median) (44-72) | 8.6+/−0.62
Mean/Median Baseline Hb >10 and < 12 g/dL
Markman, Reichman, Hakes, et al., 1993 | Control EPO | Fixed: 100 U/kg, 3.5x per week for 24 weeks | 46 17 | 40 16 | 52 (median) (25-69) 57 (median) (25-73) | 11.1 (8.0-13.5) 11.5 (7.7-12.8)
Dusenbery, McGuire, Holt, et al., 1994 | Control (historical) | | 61 | 61 | 42 (median) (28-75) | 11.1
Dusenbery, McGuire, Holt, et al., 1994 | EPO | De-escalating: 200 U/kg, 5x per week for 6 weeks; discontinued when Hb=14; 100 U/kg final dose | 15 | 15 | 43 (median) (31-67) | 10.3
Lavey and Dempsey, 1993 | Control | | 20 | 20 | 62 (mean) +/− 16 | 11.8+/−1.1
Lavey and Dempsey, 1993 | EPO | De-escalating: 300 U/kg, 3x per week for 7 weeks; discontinued when Hb=15; 150 U/kg final dose | 20 | 20 | 58 (mean) +/− 15 | 11.9+/−1.3
Wurnig, Windhager, Schwameis, et al., 1996 | Placebo control | | 14 | 14 | 28.5 (Mn vs. Md not reported) | 10.5+/−0.75
Wurnig, Windhager, Schwameis, et al., 1996 | EPO | Start/stop: 600 U/kg, 2x per week for 20 weeks; discontinued when Hb=13.5 | 16 | 15 | 28.5 (Mn vs. Md not reported) | 11+/−1.5
Henke, Guttenberger, Barke, et al., 1999 | Control | | 11 | 11 | (18-75) | 12.3
Henke, Guttenberger, Barke, et al., 1999 | EPO | Start/stop: 150 U/kg, 3x per week for 8 weeks; discontinued when Hb=14.5 | 19 | 19 | (18-75) | 10.9
Henke, Guttenberger, Barke, et al., 1999 | EPO | Start/stop: 300 U/kg, 3x per week for 8 weeks; discontinued when Hb=14.5 | 14 | 14 | (18-75) | 11.4
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Control | | 34 | 33 | 58.8 (mean) | 11.8 (10.6-12.5) | 0.0
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO | De-escalating: 150 U/kg, 3x per week for 24 weeks; discontinued when Hb=15; 75 U/kg final dose | 46 | 45 | 58.8 (mean) | 12 (11.3-12.6) | 0.0
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO | De-escalating: 300 U/kg, 3x per week for 24 weeks; discontinued when Hb=15; 150 U/kg final dose | 42 | 42 | 61 (mean) | 11.6 (10.5-12.2) | 0.0
Quirt, Couture, Pichette, et al., 1996 | Placebo Control | | 28 | 27 | | 10.7
Quirt, Couture, Pichette, et al., 1996 | EPO | Escalating: 150 U/kg, 3x per week for 16 weeks; 300 U/kg final dose | 28 | 27 | | 10.9
Mean/Median Baseline Hb >12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Control | | 24 | 24 | 62.7 (Mn/Md not reported) | 10.7 | 12.5
Sweeney, Nicolae, Ignacio, et al., 1998 | EPO | De-escalating: 200 U/kg, 5x per week for 7 weeks; discontinued when Hb=14.5; 100 U/kg final dose | 24 | 22 | 62.3 (Mn/Md not reported) | 12.1 | 8.3
Gamucci, Thorel, Frasca, et al., 1993 | Control | | 17 | 17 | 54 (median) (21-74) | 12.7+/−2.06
Gamucci, Thorel, Frasca, et al., 1993 | EPO | Fixed: 150 U/kg, 3x per week for 12 weeks | 21 | 21 | 54 (median) (21-74) | 12.2+/−1.38
Del Mastro, Venturini, Lionetto, et al., 1997 | Control | | 31 | 31 | 56 (median) (29-68) | 13.1+/−0.6
Del Mastro, Venturini, Lionetto, et al., 1997 | EPO | Start/stop: 150 U/kg, 3x per week for 12 weeks; discontinued when Hb=15 | 31 | 31 | 54 (median) (31-68) | 13+/−0.7
Thatcher, De Campos, Bell, et al., 1999 | Control | | 44 | 44 | 60 (median) (39-74) | 13.4
Thatcher, De Campos, Bell, et al., 1999 | EPO | Start/stop: 150 U/kg, 3x per week for 26 weeks; discontinued when Hb=15; 75 U/kg final dose | 42 | 42 | 59 (median) (43-72) | 13.7
Thatcher, De Campos, Bell, et al., 1999 | EPO | Start/stop: 300 U/kg, 3x per week for 26 weeks; discontinued when Hb=15; 150 U/kg final dose | 44 | 44 | 58.5 (median) (30-72) | 13.6
Welch, James, Wilkinson, et al., 1995 | Control EPO | De-escalating: 300 U/kg, 3x per week for 24 weeks; discontinued when Hb=15; 150 U/kg final dose | 15 15 | 15 15 | | 12.8 13

1 Where age was reported only for the entire group of enrollees, these data are entered for all study arms.

Evidence Table I-3. Report for hematologic outcomes

Citation | Treatment Arm | N Eval | Overall Responses (partial + complete responses) % | p Value | Final Hb Levels (g/dL) | Hb Change (g/dL) | p Value
Mean/Median Baseline Hb <10 g/dL
Silvestris, Romito, Fanelli, et al., 1995 | Control | 22 | 0
Silvestris, Romito, Fanelli, et al., 1995 | EPO; 150 U/kg | 27 | 77.8
Oberhoff, Neri, Amadori, et al., 1998 | Control | 88 | 6.8
Oberhoff, Neri, Amadori, et al., 1998 | EPO; 5000 U (total) | 101 | 34.7 | 0.0001
Kurz, Marth, Windbichler, et al., 1997 | Placebo control | 12 | 0 | | 10.1 (mean) | 0.22
Kurz, Marth, Windbichler, et al., 1997 | EPO; 150 U/kg | 23 | 56.5 | 0.001 | 13.1 (mean) | 3.3
Case, Bukowski, Carey, et al., 1993 | Placebo control | 74 | 13.5 | | | 0.33
Case, Bukowski, Carey, et al., 1993 | EPO; 150 U/kg | 79 | 58.2 | | | 2.3 | 0.0001
Porter, Leahey, Polise, et al., 1996 | Placebo control | 10
Porter, Leahey, Polise, et al., 1996 | EPO; 150 U/kg | 10
Henry, Brooks, Case, et al., 1995 | Placebo control | 61 | 6.6 | | 9.9 ^1^ (mean) +/−1.5 | 0.4 ^1^ +/−1.7
Henry, Brooks, Case, et al., 1995 | EPO; 150 U/kg | 64 | 48.4 | <0.0001 | 11.8 ^1^ (mean) +/−2.3 | 2.0 ^1^ +/−2.3 | <0.0001
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Control | 17 | | | 8.4 (mean) +/−1.6 | −0.07
Varan, Buyukpamukcu, Kutluk, et al., 1999 | EPO; 150 U/kg | 17 | | | 10.2 (mean) +/−2.1 | 1.71
Littlewood, Bajetta, Cella, et al., 1999 | Placebo control | 115 | 19.1 | | 10.6 (mean) | 0.9
Littlewood, Bajetta, Cella, et al., 1999 | EPO; 150 U/kg | 244 | 70.5 | 0.001 | 12.4 (mean) | 2.5
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry </=10.5, placebo control | 100 | 22 | | | 0.6
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry </=10.5, EPO | 203 | 68.5 | | | 2.2
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry >10.5, placebo control | 15 | 0 | | | −0.4
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry >10.5, EPO | 41 | 80.5 | | | 2.3
Littlewood, Bajetta, Cella, et al., 1999 | Solid tumors, placebo control | 61 | 21.3 | | | 0.7
Littlewood, Bajetta, Cella, et al., 1999 | Solid tumors, EPO | 131 | 66.4 | | | 2.3
Littlewood, Bajetta, Cella, et al., 1999 | Hematologic tumors, placebo control | 54 | 16.7 | | | 0.3
Littlewood, Bajetta, Cella, et al., 1999 | Hematologic tumors, EPO | 113 | 75.2 | | | 2.2
Leon, Jimenez, Barona, et al., 1998 | Control | 25 | | | 9.6 (mean) +/−1.4 | 0.1
Leon, Jimenez, Barona, et al., 1998 | EPO; 150 U/kg | 25 | 72 | | 12.4 (mean) +/−1.7 | 2.6 | <0.001
Cascinu, Fedeli, Del Ferro, et al., 1994 | Placebo control | 49 | 2 | | 8.1 (mean) +/−1.1 | −0.6
| EPO; 100 U/kg | 50 | 82 | | 10.5 (mean) +/−0.9 | 1.9
Mean/Median Baseline Hb >10 and <12 g/dL
Markman, Reichman, Hakes, et al., 1993 | Control | 40 | 40
Markman, Reichman, Hakes, et al., 1993 | EPO; 100 U/kg | 16 | 87.5 | <0.005
Dusenbery, McGuire, Holt, et al., 1994 | Control (historical) | 61 | | | 10.3 (mean) | −0.8
Dusenbery, McGuire, Holt, et al., 1994 | EPO; 200 U/kg | 15 | | | 13.2 (mean) +/−1.3 | 2.9 | 0.001
Lavey and Dempsey, 1993 | Control | 20 | 5 | | 11.8 (mean) | 0.0 +/−0.7
Lavey and Dempsey, 1993 | EPO; 300 U/kg | 20 | 80 | <0.001 | 15.1 (mean) +/−2.2 | 3.2 +/−1.78 | <0.001
Wurnig, Windhager, Schwameis, et al., 1996 | Placebo control | 14
Wurnig, Windhager, Schwameis, et al., 1996 | EPO; 600 U/kg | 15
Henke, Guttenberger, Barke, et al., 1999 | Control | 11 | | | 12.9 (mean) | 0.6 +/−1.4
Henke, Guttenberger, Barke, et al., 1999 | EPO; 150 U/kg | 19 | | | 14.1 (mean) | 3.2 +/−1.6
Henke, Guttenberger, Barke, et al., 1999 | EPO; 300 U/kg | 14 | | | 15.0 (mean) | 3.5 +/−1.2 | <0.0001
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Control | 33
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 150 U/kg | 45
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 300 U/kg | 42
Quirt, Couture, Pichette, et al., 1996 | Placebo control | 27 | | | 10.1 () | 0.6
Quirt, Couture, Pichette, et al., 1996 | EPO; 150 U/kg | 27 | | | 12.5 () | 1.6
Mean/Median Baseline Hb >12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Control | 24 | 0 | | 11.0 (mean) | 0.29
Sweeney, Nicolae, Ignacio, et al., 1998 | EPO; 200 U/kg | 22 | 45.5 | | 13.6 (mean) | 1.55 | 0.0012
Gamucci, Thorel, Frasca, et al., 1993 | Control | 17 | | | 11.2 (mean) +/−2.3 | −1.5 +/−1.67
Gamucci, Thorel, Frasca, et al., 1993 | EPO; 150 U/kg | 21 | | | 13.1 (mean) +/−2.6 | 0.9 +/−1.32 | <0.005
Del Mastro, Venturini, Lionetto, et al., 1997 | Control | 31 | | | 10.0 (mean) +/−1.1 | −3.1 +/−1
Del Mastro, Venturini, Lionetto, et al., 1997 | EPO; 150 U/kg | 31 | | | 12.2 (mean) +/−1.2 | −0.8 +/−1.4 | <0.005
Thatcher, De Campos, Bell, et al., 1999 | Control | 44 | 34.1 | | 10.0 | −3.4
Thatcher, De Campos, Bell, et al., 1999 | EPO; 150 U/kg | 42 | 52.4 | <0.05 | 10.5 | −3.2
Thatcher, De Campos, Bell, et al., 1999 | EPO; 300 U/kg | 44 | 61.4 | 0.005 | 10.3 | −3.3
Welch, James, Wilkinson, et al., 1995 | Control | 15 | | | 10.7 (mean) | −2.1
Welch, James, Wilkinson, et al., 1995 | EPO; 300 U/kg | 15 | | | 11.7 (mean) | −1.3

1 Hb level calculated from Hct level

Evidence Table I-4. Report for RBC transfusion use

Study | Treatment Arm | N Eval | % Transfused | p Value | RBC Units Transfused/Patient | p Value | RBC Units/Patient/4 Wks
Mean/Median Baseline Hb <10 g/dL
Silvestris, Romito, Fanelli, et al., 1995 | Control | 22
Silvestris, Romito, Fanelli, et al., 1995 | EPO; 150 U/kg | 27
Oberhoff, Neri, Amadori, et al., 1998 | Control | 88 | 40.9 | | 0.6 (mean) | | 0.6
Oberhoff, Neri, Amadori, et al., 1998 | EPO; 5000 U (total) | 101 | 25.7 | | 0.5 (mean) | 0.044 | 0.5
Kurz, Marth, Windbichler, et al., 1997 | Placebo control | 12 | 66.7 (12 wks) | | 3.6 (mean) | | 1.2
Kurz, Marth, Windbichler, et al., 1997 | EPO; 150 U/kg | 23 | 21.7 (12 wks) | 0.009 | 1.4 (mean) | | 0.5
Case, Bukowski, Carey, et al., 1993 | Placebo control | 74 | 33.8 (8 wks) | | 1.6 (mean) +/−0.3 | | 0.8
Case, Bukowski, Carey, et al., 1993 | EPO; 150 U/kg | 79 | 25.3 (8 wks) | | 0.9 (mean) +/−0.3 | 0.056 | 0.5
Porter, Leahey, Polise, et al., 1996 | Placebo control | 10 | 100.0 (16 wks) | | 13.0 (median) | | 3.3
Porter, Leahey, Polise, et al., 1996 | EPO; 150 U/kg | 10 | 90.0 (16 wks) | NS | 4.5 (median) | 0.01 | 1.1
Henry, Brooks, Case, et al., 1995 | Placebo control | 61 | 68.9 (8 wks) | | 4.0 (mean) +/−0.8 | | 2
Henry, Brooks, Case, et al., 1995 | EPO; 150 U/kg | 64 | 53.1 (8 wks) | >0.05 | 4.0 (mean) +/−0.9 | >0.05 | 2
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Control | 17 | 47.1
Varan, Buyukpamukcu, Kutluk, et al., 1999 | EPO; 150 U/kg | 17 | 5.9 | 0.008
Littlewood, Bajetta Cella, et al., 1999 | Placebo control | 115 | 35.7 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | EPO; 150 U/kg | 244 | 23.0 (24 wks) | 0.0168
Littlewood, Bajetta Cella, et al., 1999 | Hb at entry </=10.5, placebo control | 100 | 38.0 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Hb at entry </=10.5, EPO | 203 | 26.6 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Hb at entry >10.5, placebo control | 15 | 20.0 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Hb at entry >10.5, EPO | 41 | 4.9 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Solid tumors, placebo control | 61 | 31.1 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Solid tumors, EPO | 131 | 21.4 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Hematologic tumors, placebo control | 54 | 40.7 (24 wks)
Littlewood, Bajetta Cella, et al., 1999 | Hematologic tumors, EPO | 113 | 24.8 (24 wks)
Leon, Jimenez, Barona, et al., 1998 | Control | 25 | 96.0 (12 wks) | | 3.6 (mean) | | 1.2
Leon, Jimenez, Barona, et al., 1998 | EPO; 150 U/kg | 25 | 16.0 (12 wks) | <0.001 | 0.3 (mean) | <0.001 | 0.1
Cascinu, Fedeli, Del Ferro, et al., 1994 | Placebo control | 49 | 57.1 (9 wks) | | 1.8 (mean) | | 0.8
Cascinu, Fedeli, Del Ferro, et al., 1994 | EPO; 100 U/kg | 50 | 20.0 (9 wks) | 0.01 | 0.3 (mean) | 0.01 | 0.1
Mean/Median Baseline Hb >10 and <12 g/dL
Markman, Reichman, Hakes, et al., 1993 | Control | 40 | 22.5
Markman, Reichman, Hakes, et al., 1993 | EPO; 100 U/kg | 16 | 6.3 | >0.10
Dusenbery, McGuire, Holt, et al., 1994 | Control (historical) | 61 | 6.6
Dusenbery, McGuire, Holt, et al., 1994 | EPO; 200 U/kg | 15 | 0
Lavey and Dempsey, 1993 | Control | 20
Lavey and Dempsey, 1993 | EPO; 300 U/kg | 20
Wurnig, Windhager, Schwameis, et al., 1996 | Placebo control | 14 | 100 | | 8.4 (mean) | | 1.7
Wurnig, Windhager, Schwameis, et al., 1996 | EPO; 600 U/kg | 15 | 53.3 | NS | 2.1 (mean) | <0.01 | 0.4
Henke, Guttenberger, Barke, et al., 1999 | Control | 11
Henke, Guttenberger, Barke, et al., 1999 | EPO; 150 U/kg | 19
Henke, Guttenberger, Barke, et al., 1999 | EPO; 300 U/kg | 14
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Control | 33 | 39.4 (24 wks) | | 1.2 (mean) | | 0.2
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 150 U/kg | 45 | 4.4 (24 wks) | | 0.3 (mean) | | 0.1
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 300 U/kg | 42 | 14.3 (24 wks) | | 0.4 (mean) | | 0.1
Quirt, Couture, Pichette, et al., 1996 | Placebo control | 27 | 29.6 | | 0.7 ()
| EPO; 150 U/kg | 27 | 14.8 | | 0.2 ()
Mean/Median Baseline Hb >12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Control | 24
Sweeney, Nicolae, Ignacio, et al., 1998 | EPO; 200 U/kg | 22
Gamucci, Thorel, Frasca, et al., 1993 | Control | 17
Gamucci, Thorel, Frasca, et al., 1993 | EPO; 150 U/kg | 21
Del Mastro, Venturini, Lionetto, et al., 1997 | Control | 31 | 6.5
Del Mastro, Venturini, Lionetto, et al., 1997 | EPO; 150 U/kg | 31 | 0
Thatcher, De Campos, Bell, et al., 1999 | Control | 44 | 59.1 (26 wks) | | 6.1 (mean) +/−7.1 | | 0.9
Thatcher, De Campos, Bell, et al., 1999 | EPO; 150 U/kg | 42 | 45.2 (26 wks) | <0.05 | 3.8 (mean) +/−5.6 | <0.01 | 0.6
Thatcher, De Campos, Bell, et al., 1999 | EPO; 300 U/kg | 44 | 20.5 (26 wks) | <0.001 | 2.1 (mean) +/−4.6 | <0.001 | 0.3
Welch, James, Wilkinson, et al., 1995 | Control | 15 | 53.3 | | 5.4 (mean)
Welch, James, Wilkinson, et al., 1995 | EPO; 300 U/kg | 15 | 26.7 | NS | 4.0 (mean) | NS

Evidence Table I-5. QoL and miscellaneous outcomes report

Citation | Treatment Arm | N Eval | Baseline Overall QoL Score | Change in Overall QoL | Baseline PS | Final PS | Days in Hospital
Mean/Median Baseline Hb </=10 g/dL
Silvestris, Romito, Fanelli, et al., 1995 | Control | 22
Silvestris, Romito, Fanelli, et al., 1995 | EPO; 150 U/kg | 27
Oberhoff, Neri, Amadori, et al., 1998 | Control | 88
Oberhoff, Neri, Amadori, et al., 1998 | EPO; 5000 U (total) | 101
Kurz, Marth, Windbichler, et al., 1997 | Placebo control | 12
Kurz, Marth, Windbichler, et al., 1997 | EPO; 150 U/kg | 23
Case, Bukowski, Carey, et al., 1993 | Placebo control | 74 | 52.5 (out of 100.0) | −1
Case, Bukowski, Carey, et al., 1993 | EPO; 150 U/kg | 79 | 52.3 (out of 100.0) | 5.6
Porter, Leahey, Polise, et al., 1996 | Placebo control | 10
Porter, Leahey, Polise, et al., 1996 | EPO; 150 U/kg | 10
Henry, Brooks, Case, et al., 1995 | Placebo control | 61 | | 0.2
Henry, Brooks, Case, et al., 1995 | EPO; 150 U/kg | 64 | | 11.0 (p=0.013)
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Control | 17
Varan, Buyukpamukcu, Kutluk, et al., 1999 | EPO; 150 U/kg | 17
Littlewood, Bajetta, Cella, et al., 1999 | Placebo control | 115 | | −6
Littlewood, Bajetta, Cella, et al., 1999 | EPO; 150 U/kg | 244 | | 4.6 (p<0.01)
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry </=10.5, placebo control | 100
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry </=10.5, EPO | 203
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry >10.5, placebo control | 15
Littlewood, Bajetta, Cella, et al., 1999 | Hb at entry >10.5, EPO | 41
Littlewood, Bajetta, Cella, et al., 1999 | Solid tumors, placebo control | 61
Littlewood, Bajetta, Cella, et al., 1999 | Solid tumors, EPO | 131
Littlewood, Bajetta, Cella, et al., 1999 | Hematologic tumors, placebo control | 54
Littlewood, Bajetta, Cella, et al., 1999 | Hematologic tumors, EPO | 113
Mean/Median Baseline Hb <10 g/dL
Leon, Jimenez, Barona, et al., 1998 | Control | 25
Leon, Jimenez, Barona, et al., 1998 | EPO; 150 U/kg | 25
Cascinu, Fedeli, Del Ferro, et al., 1994 | Placebo control | 49
Cascinu, Fedeli, Del Ferro, et al., 1994 | EPO; 100 U/kg | 50
Mean/Median Baseline Hb >10 and <12 g/dL
Markman, Reichman, Hakes, et al., 1993 | Control | 40
Markman, Reichman, Hakes, et al., 1993 | EPO; 100 U/kg | 16
Dusenbery, McGuire, Holt, et al., 1994 | Control (historical) | 61
Dusenbery, McGuire, Holt, et al., 1994 | EPO; 200 U/kg | 15
Lavey and Dempsey, 1993 | Control | 20
Lavey and Dempsey, 1993 | EPO; 300 U/kg | 20
Wurnig, Windhager, Schwameis, et al., 1996 | Placebo control | 14
Wurnig, Windhager, Schwameis, et al., 1996 | EPO; 600 U/kg | 15
Henke, Guttenberger, Barke, et al., 1999 | Control | 11
Henke, Guttenberger, Barke, et al., 1999 | EPO; 150 U/kg | 19
Henke, Guttenberger, Barke, et al., 1999 | EPO; 300 U/kg | 14
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Control | 33
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 150 U/kg | 45
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 300 U/kg | 42
Quirt, Couture, Pichette, et al., 1996 | Placebo control | 27
Quirt, Couture, Pichette, et al., 1996 | EPO; 150 U/kg | 27
Mean/Median Baseline Hb >12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Control | 24 | 50.0 (out of 100.0) | 6.3
Sweeney, Nicolae, Ignacio, et al., 1998 | EPO; 200 U/kg | 22 | 53.6 (out of 100.0) | 19.1 (p=0.15)
Gamucci, Thorel, Frasca, et al., 1993 | Control | 17
Gamucci, Thorel, Frasca, et al., 1993 | EPO; 150 U/kg | 21
Del Mastro, Venturini, Lionetto, et al., 1997 | Control | 31
Del Mastro, Venturini, Lionetto, et al., 1997 | EPO; 150 U/kg | 31
Thatcher, De Campos, Bell, et al., 1999 | Control | 44 | 47.9 (out of 100.0) | 7.5
Thatcher, De Campos, Bell, et al., 1999 | EPO; 150 U/kg | 42 | 49.0 (out of 100.0) | 11.7 (p<0.05)
Thatcher, De Campos, Bell, et al., 1999 | EPO; 300 U/kg | 44 | 53.9 (out of 100.0) | 6.0 (p>0.05)
Welch, James, Wilkinson, et al., 1995 | Control | 15
Welch, James, Wilkinson, et al., 1995 | EPO; 300 U/kg | 15

Evidence Table I-6. Adverse events report

Study | Treatment Arm | N Evaluable | Hypertension % | Rash/Irritation/Pruritus % | Mortality % | DVT/Thrombotic Event % | Hemorrhage/Thrombocytopenia % | Seizure % | Other Cardiovasc. % | Inject'n Site Pain % | Fatigue % | Withdrawals % | Any Adverse Event %
Mean/Median Baseline Hb<10 g/dL
Silvestris, Romito, Fanelli, et al., 1995 | Control
Silvestris, Romito, Fanelli, et al., 1995 | EPO; 150 U/kg
Oberhoff, Neri, Amadori, et al., 1998 | Control | 104 | | | 13.5 | | | | | | | 6.7 | 27.9
Oberhoff, Neri, Amadori, et al., 1998 | EPO; 5000 U (total) | 114 | | | 7 | | | | | | | 14.9 | 26.3
Kurz, Marth, Windbichler, et al., 1997 | Placebo control | 12 | | 0 | | | | | | 0 | | | 0
Kurz, Marth, Windbichler, et al., 1997 | EPO; 150 U/kg | 23 | | 0 | | | | | | 0 | | | 0
Case, Bukowski, Carey, et al., 1993 | Placebo control | 76 | 2.6 | | | 5.3 | | 2.6 | | | | 10.5
Case, Bukowski, Carey, et al., 1993 | EPO; 150 U/kg | 81 | 4.9 | | | 4.9 | | 2.5 | | | | 16
Porter, Leahey, Polise, et al., 1996 | Placebo control | 10 | 0 | | | | | 0
Porter, Leahey, Polise, et al., 1996 | EPO; 150 U/kg | 10 | 0 | | | | | 0 | | 20
Henry, Brooks, Case, et al., 1995 | Placebo control | 65 | 6.2 | 3.1 | | 3.1 | | 3.1 | | 6.2 | 18.5 | 35.4 | 89.2
Henry, Brooks, Case, et al., 1995 | EPO; 150 U/kg | 67 | 3 | 10.4 | | 9 | | 4.5 | | 10.4 | 16.4 | 29.9 | 86.6
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Control
Varan, Buyukpamukcu, Kutluk, et al., 1999 | EPO; 150 U/kg
Littlewood, Bajetta, Cella, et al., 1999 | Placebo control | 124 | | | | | | | | | 12.1 | | 80.6
Littlewood, Bajetta, Cella, et al., 1999 | EPO; 150 U/kg | 251 | | | | | | | | | 7.2 | | 86.1
Leon, Jimenez, Barona, et al., 1998 | Control | 25 | | | | | | | | | | 0 | 0
Leon, Jimenez, Barona, et al., 1998 | EPO; 150 U/kg | 25 | | | | | | | | | | 0 | 0
Cascinu, Fedeli, Del Ferro, et al., 1994 | Placebo control | 49 | 0 | | | 0 | 0 | 0 | | | | 0 | 0
Cascinu, Fedeli, Del Ferro, et al., 1994 | EPO; 100 U/kg | 50 | 0 | | | 0 | 0 | 0 | | | | 0 | 0
Mean/Median Baseline Hb >10 and <12 g/dL
Markman, Reichman, Hakes, et al., 1993 | Control
Markman, Reichman, Hakes, et al., 1993 | EPO; 100 U/kg
Dusenbery, McGuire, Holt, et al., 1994 | Control (historical)
Dusenbery, McGuire, Holt, et al., 1994 | EPO; 200 U/kg
Lavey and Dempsey, 1993 | Control | 20 | 0 | | | | | | | | | 0 | 0
Lavey and Dempsey, 1993 | EPO; 300 U/kg | 20 | 0 | 5 | | | | | | | | 5 | 5
Wurnig, Windhager, Schwameis, et al., 1996 | Placebo control
Wurnig, Windhager, Schwameis, et al., 1996 | EPO; 600 U/kg
Henke, Guttenberger, Barke, et al., 1999 | Control
Henke, Guttenberger, Barke, et al., 1999 | EPO; 150 U/kg
Henke, Guttenberger, Barke, et al., 1999 | EPO; 300 U/kg
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Control | 33 | 0 | | 6.1 | 0 | | | | | | 24.2 | 84.8
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 150 U/kg | 45 | 6.7 | | 2.2 | 4.4 | | | | | | 24.4 | 86.7
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | EPO; 300 U/kg | 42 | 9.5 | | 11.9 | 7.1 | | | | | | 40.5 | 85.7
Quirt, Couture, Pichette, et al., 1996 | Placebo control
Quirt, Couture, Pichette, et al., 1996 | EPO; 150 U/kg
Mean/Median Baseline Hb >12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Control | 24 | | | | | | | | | | | 8.3
Sweeney, Nicolae, Ignacio, et al., 1998 | EPO; 200 U/kg | 24 | | 4.2 | | | | | | | | | 16.7
Gamucci, Thorel, Frasca, et al., 1993 | Control | 17 | 0 | | | | | | | | | | 0
Gamucci, Thorel, Frasca, et al., 1993 | EPO; 150 U/kg | 21 | 0 | | | | | | | | | | 0
Del Mastro, Venturini, Lionetto, et al., 1997 | Control | 31 | | | | | 12.9 | | | | 64.5
Del Mastro, Venturini, Lionetto, et al., 1997 | EPO; 150 U/kg | 31 | | 6.5 | | | 12.9 | | | | 61.3
Thatcher, De Campos, Bell, et al., 1999 | Control | 44 | | 9.1 | | | | | | | 6.8
Thatcher, De Campos, Bell, et al., 1999 | EPO; 150 U/kg | 42 | 4.8 | 11.9 | | 0 | | | 0 | | 2.4
Thatcher, De Campos, Bell, et al., 1999 | EPO; 300 U/kg | 44 | 2.3 | 2.3 | | | | | | | 0
Welch, James, Wilkinson, et al., 1995 | Control | 15 | 0 | | | 0 | | | | | | 13.3
Welch, James, Wilkinson, et al., 1995 | EPO; 300 U/kg | 15 | 13.3 | | | 6.7 | | | | | | 20

Evidence Table II-1. Study description

Study | Study Description | Disease(s) | Study Population | Patient Eligibility ^1^ | Definition of Complete Response | Definition of Partial Response | Transfusion Trigger (Hb g/dL)
Unknown Baseline Hb
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: MDS | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified | Hb cutoff=9.0 g/dL; (Type not specified) PS limit=2; Minimum LE=6 months | Increase in Hb >/=2 g/dL or no transf >/=2 months | Increase in Hb 1-2 g/dL or 50% decrease in transf need for >/=2 months | 8
Mean/Median Baseline Hb <10 g/dL
Garton, Gertz, Witzig, et al., 1995 | Randomized; double-blinded; concurrent controls; placebo | Category: multiple myeloma | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified | Hb cutoff=10.0 g/dL; ECOG PS limit=3 | Hematocrit reached 38% (Hb 12.7) or greater w/o transfusion | Hematocrit increase of 6% points (Hb 2 g/dL) or greater w/o transfusion
Osterborg, Boogaerts, Cimino, et al., 1996 | Randomized; unblinded; concurrent controls; multicenter | Category: lymphoid malignancies; Tumor type: NHL, NHL+CLL, myeloma | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified | Hb cutoff=10.0 g/dL; WHO PS limit=2; Minimum LE=2 months | Hb increase of >2 g/dL w/o transfusion need for 8 weeks | None | 10
Cazzola, Messinger, Battistel, et al., 1995 | Randomized; unblinded; concurrent controls; multicenter | Category: lymphoid malignancies; Tumor type: multiple myeloma, non-Hodgkin's lymphoma | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified | Hb cutoff=11.0 g/dL; WHO PS limit=2; Minimum LE=3 months | Hb increase > or =2 g/dL at 2 consec. checkups & no transfusion prior 6 wk | None
Dammacco, Silvestris, Castoldi, et al., 1998 | Randomized; unblinded; concurrent controls; multicenter | Category: multiple myeloma | Previous chemotherapy; previous platinum exposure and previous radiation therapy unspecified | Hb cutoff=10.0 g/dL; Karnofsky PS limit=40 | Hb increase >/=2 g/dL (not pretransfused); no transfusion for 8 weeks | Hb increase <2 g/dL (not pretransfused); no transfusion for 4 weeks | 7
Rose, Rai, Revicki, et al., 1994 | Randomized; double-blinded; concurrent controls; placebo | Category: leukemia; Tumor type: Chronic lymphocytic leukemia | Previous chemotherapy, previous platinum exposure, and previous radiation therapy all unspecified | Hb cutoff=10.7 g/dL | Hb > or =2 g/dL increase over baseline without transfusion | None

1 Unless otherwise indicated, all hemoglobin (Hb) cutoff values represent an upper limit.

Evidence Table II-2. Baseline study characteristics

Citation | Study Arm | EPO Treatment | N Enrolled | N Evaluable | Age ^1^ +/−SD (range) | Baseline Hb (g/dL) +/−SD (range) | % Previously Transfused
Unknown Baseline Hb
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Placebo control | | 43 | 37 | 65 (mean) +/− 9.2 (43-78) | | 76.0
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | EPO | Fixed: 150 U/kg, 7x per week for 8 weeks | 44 | 38 | 65 (mean) +/− 12.8 | | 60.0
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, placebo control | | | 9 | | 8.47+/−0.66 | 0.0
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, EPO | | | 15 | | 8.35+/−0.73 | 0.0
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pretransfused, placebo control | | | 28 | | | 100.0
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pretransfused, EPO | | | 23 | | | 100.0
Mean/Median Baseline Hb <10 g/dL
Garton, Gertz, Witzig, et al., 1995 | Placebo control | | 13 | 10 | 69.2 (median) (50.8-86.9) | 8.7
Garton, Gertz, Witzig, et al., 1995 | EPO | Escalating: 150 U/kg, 3x per week for 12 weeks; 300 U/kg final dose | 11 | 10 | 69.2 (median) (50.8-86.9) | 8.7
Osterborg, Boogaerts, Cimino, et al., 1996 | Control | | 49 | 39 | 64 (median) (36-83) | 8.1 (5.2-9.8) | 100.0
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO | Start/stop: 10000 U (total), 7x per week for 24 weeks; discontinued when Hb=11 | 47 | 38 | 66 (median) (43-84) | 8 (6.2-10.1) | 100.0
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO | Escalating: 2000 U (total), 7x per week for 24 weeks; discontinued when Hb=11; 10000 U (total) final dose | 48 | 44 | 65 (median) (38-82) | 8 (5.5-10.3) | 100.0
Cazzola, Messinger, Battistel, et al., 1995 | Control | | 29 | 29 | 68 (median) (28-82) | 9.5+/−1.1 | 14.0
Cazzola, Messinger, Battistel, et al., 1995 | EPO | De-escalating: 1000 U (total), 7x per week for 8 weeks; discontinued when Hb=12.5 | 31 | 31 | 67 (median) (48-82) | 9.3+/−0.9 | 16.0
Cazzola, Messinger, Battistel, et al., 1995 | EPO | De-escalating: 2000 U (total), 7x per week for 8 weeks; discontinued when Hb=12.5 | 29 | 29 | 65 (median) (40-82) | 9.4+/−0.9 | 17.0
Cazzola, Messinger, Battistel, et al., 1995 | EPO | De-escalating: 5000 U (total), 7x per week for 8 weeks; discontinued when Hb=12.5 | 31 | 31 | 68 (median) (42-85) | 9.4+/−1.2 | 19.0
Cazzola, Messinger, Battistel, et al., 1995 | EPO | De-escalating: 10000 U (total), 7x per week for 8 weeks; discontinued when Hb=12.5 | 26 | 26 | 63 (median) (28-80) | 9.4+/−1 | 4.0
Dammacco, Silvestris, Castoldi, et al., 1998 | Control | | 31 | 29 | 65 (mean) +/− 8.8 (47-85) | 8.3 | 35.5
Dammacco, Silvestris, Castoldi, et al., 1998 | EPO | Escalating: 150 U/kg, 3x per week for 24 weeks; discontinued when Hb=12; 300 U/kg final dose | 40 | 36 | 60.6 (mean) +/− 8.3 (39-74) | 8.3 | 40.0
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, control | | 20 | 20 | | 8.3+/−1.4 | 0.0
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, EPO | 300 U/kg final dose | 24 | 24 | | 8.7+/−0.9 | 0.0
Dammacco, Silvestris, Castoldi, et al., 1998 | Pretransfused, control | | 11 | 11 | | 8.3 | 100.0
Dammacco, Silvestris, Castoldi, et al., 1998 | Pretransfused, EPO | 300 U/kg final dose | 16 | 16 | | 7.4 | 100.0
Rose, Rai, Revicki, et al., 1994 | Placebo control | | 80 | 80 | | 9.2
Rose, Rai, Revicki, et al., 1994 | EPO | Fixed: 150 U/kg, 3x per week for 12 weeks | 141 | 141 | | 9.2

1 Where age was reported only for the entire group of enrollees, these data are entered for all study arms.

Evidence Table II-3. Report for hematologic outcomes

Citation | Treatment Arm | N Eval | Overall Responses (partial + complete responses) % | p Value | Final Hb Levels (g/dL) | Hb Change (g/dL) | p Value
Unknown Baseline Hb
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Placebo control | 37 | 10.8 (10.8 + 0.0)
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | EPO; 150 U/kg | 38 | 36.8 (23.7 + 13.2) | 0.007
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, placebo control | 9 | 0 | | 8.2 (mean) +/− 0.9 | −0.28
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, EPO | 15 | 60 | | 10.1 (mean) +/− 1.9 | 1.72 | 0.0004
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pre-transfused, placebo control | 28 | 14.3
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pre-transfused, EPO | 23 | 21.7
Mean/Median Baseline Hb <10 g/dL
Garton, Gertz, Witzig, et al., 1995 | Placebo control | 10 | 0.0 (0.0 + 0.0)
Garton, Gertz, Witzig, et al., 1995 | EPO; 150 U/kg | 10 | 70.0 (10.0 + 60.0) | | | | 0.02
Osterborg, Boogaerts, Cimino, et al., 1996 | Control | 39 | 23.1 | | | 0.5
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO; 10000 U (total) | 38 | 60.5 | 0.01 | | 2.1 | NS
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO; 2000 U (total) | 44 | 59.1 | 0.02 | | 1.5 | NS
Cazzola, Messinger, Battistel, et al., 1995 | Control | 29 | 6.9 | | 9.6 (mean) | 0.15
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 1000 U (total) | 31 | 6.5 | | 9.7 (mean) | 0.4
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 2000 U (total) | 29 | 31 | | 11.2 (mean) | 1.8
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 5000 U (total) | 31 | 61.3 | | 11.4 (mean) | 2
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 10000 U (total) | 26 | 61.5 | | 11.0 | 1.6
Dammacco, Silvestris, Castoldi, et al., 1998 | Control | 29 | 20.7 (10.3 + 10.3)
Dammacco, Silvestris, Castoldi, et al., 1998 | EPO; 150 U/kg | 36 | 75.0 (30.6 + 44.4) | </=0.001
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, Control | 20 | | | 8.2 (mean) +/− 1.7 | −0.2 +/− 1.5
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, EPO | 24 | | | 10.8 (mean) +/− 2.0 | 2.1 +/− 1.7 | 0.0001
Dammacco, Silvestris, Castoldi, et al., 1998 | Pre-transfused, Control | 11
Dammacco, Silvestris, Castoldi, et al., 1998 | Pre-transfused, EPO | 16
Rose, Rai, Revicki, et al., 1994 | Placebo control | 80 | 15 | | 9.7 ^1^ (mean) | 0.5
Rose, Rai, Revicki, et al., 1994 | EPO; 150 U/kg | 141 | 49.6 | <0.0001 | 11.0 ^1^ (mean) | 1.9 | <0.0001

1 Hb level calculated from hematocrit level.

Evidence Table II-4. Report for RBC transfusion use

Study | Treatment Arm | N Eval | % Transfused | p Value | RBC units Transfused/Patient | p Value | RBC Units/Patient/4 Wks
Unknown Baseline Hb
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Placebo control | 37
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | EPO; 150 U/kg | 38
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, placebo control | 9
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, EPO | 15
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pretransfused, placebo control | 28
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pretransfused, EPO | 23
Mean/Median Baseline Hb >10 g/dL
Garton, Gertz, Witzig, et al., 1995 | Placebo control | 10
Garton, Gertz, Witzig, et al., 1995 | EPO; 150 U/kg | 10
Osterborg, Boogaerts, Cimino, et al., 1996 | Control | 39 | 82.1
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO; 10000 U (total) | 38 | 57.9 | <0.05 | | NS
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO; 2000 U (total) | 44 | 63.6 | <0.05 | | NS
Cazzola, Messinger, Battistel, et al., 1995 | Control | 29 | 27.6 (8 wks) | | 0.9 | | 0.4
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 1000 U (total) | 31 | 22.6 (8 wks) | | 0.7 | | 0.4
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 2000 U (total) | 29 | 17.2 (8 wks) | | 0.7 | | 0.3
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 5000 U (total) | 31 | 19.4 (8 wks) | | 0.5 | | 0.3
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 10000 U (total) | 26 | 15.4 (8 wks) | | 0.2 | | 0.1
Dammacco, Silvestris, Castoldi, et al., 1998 | Control | 29
Dammacco, Silvestris, Castoldi, et al., 1998 | EPO; 150 U/kg | 36
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, control | 20 | 45.0 (24 wks) | | 2.5 (mean) | | 0.4
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, EPO | 24 | 25.0 (24 wks) | 0.23 | 1.2 (mean) | 0.12 | 0.2
Dammacco, Silvestris, Castoldi, et al., 1998 | Pretransfused, control | 11 | | | 2.6 (mean) | | 0.4
Dammacco, Silvestris, Castoldi, et al., 1998 | Pretransfused, EPO | 16 | | | 0.6 (mean) | 0.013 | 0.1
Rose, Rai, Revicki, et al., 1994 | Placebo control | 80
Rose, Rai, Revicki, et al., 1994 | EPO; 150 U/kg | 141

Evidence Table II-5. QoL and miscellaneous outcomes report

Citation | Treatment Arm | N Eval | Baseline Overall QoL Score | Change in Overall QoL | Baseline PS | Final PS | Days in Hospital
Unknown Baseline Hb
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Placebo control | 37
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | EPO; 150 U/kg | 38
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, placebo control | 9
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Nonpretransfused, EPO | 15
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pretransfused, placebo control | 28
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Pretransfused, EPO | 23
Mean/Median Baseline Hb<10 g/dL
Garton, Gertz, Witzig, et al., 1995 | Placebo control | 10
Garton, Gertz, Witzig, et al., 1995 | EPO; 150 U/kg | 10
Osterborg, Boogaerts, Cimino, et al., 1996 | Control | 39
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO; 10000 U (total) | 38
Osterborg, Boogaerts, Cimino, et al., 1996 | EPO; 2000 U (total) | 44
Cazzola, Messinger, Battistel, et al., 1995 | Control | 29
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 1000 U (total) | 31
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 2000 U (total) | 29
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 5000 U (total) | 31
Cazzola, Messinger, Battistel, et al., 1995 | EPO; 10000 U (total) | 26
Dammacco, Silvestris, Castoldi, et al., 1998 | Control | 29
Dammacco, Silvestris, Castoldi, et al., 1998 | EPO; 150 U/kg | 36
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, control | 20
Dammacco, Silvestris, Castoldi, et al., 1998 | Nonpretransfused, EPO | 24
Dammacco, Silvestris, Castoldi, et al., 1998 | Pretransfused, control | 11
Dammacco, Silvestris, Castoldi, et al., 1998 | Pretransfused, EPO | 16
Rose, Rai, Revicki, et al., 1994 | Placebo control | 80
Rose, Rai, Revicki, et al., 1994 | EPO; 150 U/kg | 141

Evidence Table II-6. Adverse events report

Study | Treatment Arm | N Evaluable | Hypertension % | Rash/Irritation/Pruritus % | Mortality % | DVT/Thrombotic-Event % | Hemorrhage/Thrombocytopenia % | Seizure % | Other Cardiovasc. % | Inject'n Site Pain % | Fatigue % | With-drawals % | Any Adverse Event %
Unknown Baseline Hb
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Placebo control | 37 | | 0 | | | | | | | | 10.8 | 43.2
| EPO; 150 U/kg | 38 | | 2.6 | | | | | | | | 7.9 | 31.6
Mean/Median Baseline Hb<10 g/dL
Garton, Gertz, Witzig, et al., 1995 | Placebo control | 11 | 0 | | | | | | | | | 27.3
| EPO; 150 U/kg | 10 | 0 | | | | | | | | | 10
Osterborg, Boogaerts, Cimino, et al., 1996 | Control | 49 | 2 | 0 | 28.6 | 0 | | | | | | 20.4 | 44.9
| EPO; 10000 U (total) | 47 | 8.5 | 2.1 | 31.9 | 2.1 | | | | | | 19.1 | 63.8
| EPO; 2000 U (total) | 48 | 10.4 | 2.1 | 22.9 | 4.2 | | | | | | 8.3 | 50
Cazzola, Messinger, Battistel, et al., 1995 | Control | 29 | | | 10.3 | | | | | | | | 13.8
| EPO; 1000 U (total) | 117 | | | 3.4 | | | | | | | | 12.8
| EPO; 2000 U (total)
Dammacco, Silvestris, Castoldi, et al., 1998 | Control | 31 | 0 | 3.2 | 16.1 | | | | 12.9 | | | 6.5 | 25.8
| EPO; 150 U/kg | 40 | 12.5 | 0 | 22.5 | | | | 2.5 | | | 10 | 35
Rose, Rai, Revicki, et al., 1994 | Placebo control
| EPO; 150 U/kg

Evidence Table III-1. Study description

Study | Study Description | Disease(s) | Transplant Description | Target Hb for RBC Engraftment (g/dL) | Hb Trigger for Transfusion (g/dL)
Allogeneic Transplantation
Biggs, Atkinson, Booker, et al., 1995 | Randomized; double-blinded; Concurrent controls; placebo; multicenter | Category: mixed hematologic malignancies | Allogenic; bone marrow; TBI not specified; MTX prophylaxis | | 8.5
Klaesson, Ringden, Ljungman, et al., 1994 | Randomized; double-blinded; concurrent controls; placebo | Category: mixed hematologic malignancies | Allogenic; bone marrow; TBI - some patients; MTX prophylaxis | 7 | 7
Steegmann, Lopez, Otero, et al., 1992 | Randomized; unblinded; concurrent controls | Category: leukemia; Tumor type; CML, acute Leukemia | Allogenic; bone marrow; TBI - some patients; MTX prophylaxis | | 10
Vannucchi, Bosi, Linari, et al., 1997 | Randomized; single-blinded; concurrent controls; placebo | Category: mixed hematologic malignancies; Tumor type; AML, ALL, CML, MM | Allogenic; bone marrow; TBI - some patients; MTX prophylaxis | 10 | 8
Link, Brune, Hubner, et al., 1993 | Unblinded; historical controls | Category: mixed hematologic malignancies; Tumor type; CML, ALL, AML, lymphoma, AA, PNH | Allogenic; bone marrow; TBI - some patients; MTX not specified | 11.7 | 9
Link, Boogaerts, Fauser, et al., 1994 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: mixed hematologic malignancies; Tumor type: AML, ALL, NHL, Hodgkin's, CML | Autologous & allogenic; bone marrow; TBI - some patients; MTX not specified | 9 | 9
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Unblinded; historical controls | Category: leukemia; Tumor type: ALL, AML | Autologous & allogenic; bone marrow; TBI - some patients; no MTX prophylaxis | | 8

Evidence Table III-2. Baseline study characteristics

Citation | Study Arm | EPO Treatment Regimen | G- or GM-CSF Use? | N Enrolled | N Evaluable | Age ^1^ +/−SD (range)
Allogeneic
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | No | 43 | 39 | 36 (mean) +/− 10 (20-58)
Biggs, Atkinson, Booker, et al., 1995 | EPO | De-escalating: 300 U/kg, 3x per week for 6 weeks; discontinued when Hb=12 | No | 48 | 44 | 36 (mean) +/− 9 (17-56)
Klaesson, Ringden, Ljungman, et al., 1994a | Placebo control | | No | 25 | 23 | 34 (Mn/Md not reported) (10-53)
Klaesson, Ringden, Ljungman, et al., 1994a | EPO | De-escalating: 200 U/kg, 7x per week for 4 weeks, then 2 x per week for 4 weeks; discontinued when Hb=10; 100 U/kg final dose | No | 25 | 22 | 37 (Mn/Md not reported) (14-49)
Steegmann, Lopez, Otero, et al., 1992 | Control | | No | 11 | 11 | 27.5 (median) (14-42)
Steegmann, Lopez, Otero, et al., 1992 | EPO | Escalating: 100 U/kg, 7x per week for 4.3 weeks | No | 13 | 13 | 27.5 (median) (14-42)
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | No | 10 | 10 | 39 (median) (19-44)
Vannucchi, Bosi, Linari, et al., 1997 | EPO | Fixed: 500 U/kg, 7x per week for 4.3 weeks | No | 10 | 10 | 37 (median) (17-55)
Link, Brune, Hubner, et al., 1993 | Control | | No | 43 | 43 | 25 (median) (7-47)
Link, Brune, Hubner, et al., 1993 | EPO | Fixed: 150 U/kg, 7x per week for 7.9 weeks; discontinued when Hb=11.7 | No | 19 | 19 | 31 (median) (12-46)
Link, Boogaerts, Fauser, et al., 1994 | Allogeneic, Placebo control | | No | 109 | 109 | 31 (median) (1-55)
Link, Boogaerts, Fauser, et al., 1994 | Allogeneic BMT, EPO | Fixed: 150 U/kg, 7x per week for 6 weeks; discontinued when Hb=9 | No | 106 | 106 | 31 (median) (4-55)
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Allogeneic BMT, Control | | No | 17 | 15 | 9.7 (median) (2-18)
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Allogeneic BMT, EPO | Fixed: 75 U/kg, I7x per week for 4.3 weeks | No | 14 | 10 | 11.3 (median) (3-18)

1 Where age was reported only for the entire group of enrollees, these data are entered for all study arms.

Evidence Table III-3. Report for RBC transfusion use

Study | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable | RBC Units Transfused per Patient +/− SD | p Value | RBC Units/Patient/4 wks | Platelet Transfusions ^1^ or Units Transfused ^2^ Per Patient +/− SD | p Value | Days in Hospital +/− SD | p Value
Allogeneic
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | | 15 | 3.9 (mean) +/− 1.2 | | 3.6 | 7.3 (mean) +/− 5.2^1^
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO | 525 | 10 | 1.6 (mean) +/− 1.2 | <0.001 | 1.5 | 4.0 (mean) +/− 2.3^1^ | <0.05
Steegmann, Lopez, Otero, et al., 1992 | Control | | 11 | 12.0 (median) | | 11.2 | 138.5 (median)^2^
Steegmann, Lopez, Otero, et al., 1992 | EPO | 700 | 13 | 4.0 (median) | <0.05 | 3.7 | 36.0 (median)^2^ | <0.05
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | 39 | 7.0 (mean) +/− 5.0 | | 4.7 | 11.0 (mean) +/− 7.0^1^ | | 29 +/− 8
Biggs, Atkinson, Booker, et al., 1995 | EPO | 900 | 44 | 6.0 (mean) +/− 5.0 | NS | 4 | 11.0 (mean) +/− 9.0^1^ | NS | 28 +/− 8 | NS
Link, Brune, Hubner, et al., 1993 | Control | | 43 | 9.7 (mean) +/− 6.9 | | 9
Link, Brune, Hubner, et al., 1993 | EPO | 1050 | 19 | 7.1 (mean) +/− 3.7 | 0.1 | 6.6
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 109 | 8.7 (mean) +/− 6.6 | | 6
Link, Boogaerts, Fauser, et al., 1994 | EPO | 1050 | 106 | 8.0 (mean) +/− 6.1 | NS | 5.5 | | NS
Klaesson, Ringden, Ljungman, et al., 1994 | Placebo control | | 23 | 10.0 (mean) +/− 9.0 | | 5 | 17.0 (mean) +/− 15.0^2^ | | 37
Klaesson, Ringden, Ljungman, et al., 1994 | EPO | 1400 | 22 | 5.0 (mean) +/− 5.0 | 0.04 | 2.5 | 16.0 (mean) +/− 12.0^2^ | NS | 35 | NS
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | 10 | 4.2 (mean) +/− 2.7 | | 3.9 | 5.7 (mean) +/− 2.8^1^
Vannucchi, Bosi, Linari, et al., 1997 | EPO | 3500 | 10 | 2.2 (mean) +/− 2.5 | <0.05 | 2 | 4.5 (mean) +/− 1.8^1^ | NS

1 Platelet transfusions.

2 Units transfused.

Evidence Table III-4. Report for RBC engraftment

Study | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable | Percent of Patients Engrafted | p Value | Time to Engraftment (days) | p Value | Reticulocyte Measurement Reported | Reticulocyte Result | p Value
Allogeneic
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | | 15 | | | | | Reticulocyte count at day 30 after transplant | 107.2+/−63.4 x 10^9^
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO | 525 | 10 | | | | | Reticulocyte count at day 30 after transplant | 186.9+/−51.4 x 10^9^ | <0.05
Steegmann, Lopez, Otero, et al., 1992 | Control | | 11 | | | | | Days to reticulocytes >1% | 19.5 (13-38) days
Steegmann, Lopez, Otero, et al., 1992 | EPO | 700 | 13 | | | | | Days to reticulocytes >1% | 13 (10-24) days | <0.05
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | 39 | 1 | | 41 (median) | | Maximum reticulocyte count | 60 x 10^9^/L
Biggs, Atkinson, Booker, et al., 1995 | EPO | 900 | 44 | 1 | <0.0005 | 26 (median) | 0.002 | Maximum reticulocyte count | 130 x 10^9^/L | <0.0005
Link, Brune, Hubner, et al., 1993 | Control | | 43 | 0.949999988 | | 24 (median) | | Maximum reticulocyte count | 20 x 10^9^/L
Link, Brune, Hubner, et al., 1993 | EPO | 1050 | 19 | 1 | | 17 (median) | 0.015 | Maximum reticulocyte count | 92 x 10^9^/L | 0.065
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 109 | 0.560000002 | | 27 (median) | | Maximum reticulocyte count | 52 x 10^9^/L
Link, Boogaerts, Fauser, et al., 1994 | EPO | 1050 | 106 | 0.790000021 | | 19 (median) | 0.003 | Maximum reticulocyte count | 155 x 10^9^/L | <0.05
Klaesson, Ringden, Ljungman, et al., 1994 | Placebo control | | 23 | | | 24 (mean) | | Days to reticulocytes >0.2% | 17+/−5 days
Klaesson, Ringden, Ljungman, et al., 1994 | EPO | 1400 | 22 | | | 14 (mean) | 0.03 | Days to reticulocytes >0.2% | 15+/−5 days | NS
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | 10 | 1 | | 36.6 (mean) +/−18.1 | | Days to reticulocytes >30 x 10E9/L | 15.5+/−2.5 days
Vannucchi, Bosi, Linari, et al., 1997 | EPO | 3500 | 10 | 1 | | 25.6 (mean) +/−11.1 | NS | Days to reticulocytes >30 x 10E9/L | 11.6+/−1.6 days | <0.01

Evidence Table III-5. Adverse events report

Study | Treatment Arm; Dose | N Evaluable | Hypertension % | Rash/Irritation/Pruritus % | Mortality % | DVT/Thrombotic Event % | Hemorrhage/Thrombocytopenia % | Seizure % | Other Cardiovasc. % | Inject'n Site Pain % | Fatigue % | With-drawals % | Any Adverse Event
Allogeneic
Biggs, Atkinson, Booker, et al., 1995 | Placebo control
| EPO; 900 U/kg/wk
Klaesson, Ringden, Ljungman, et al., 1994 | Placebo control | 25 | 0 | | 20 | | 36 | | 8 | | | 0
| EPO; 1400 U/kg/wk | 25 | 0 | | 24 | | 36 | | 8 | | | 24
Steegmann, Lopez, Otero, et al., 1992 | Control | 11 | 0 | | | | | | | | | 0
| EPO; 700 U/kg/wk | 13 | 7.7 | | | | | | | | | 7.7
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | 10 | 0 | | | 0
| EPO; 3500 U/kg/wk | 10 | 0 | | | 0
Link, Brune, Hubner, et al., 1993 | Control
| EPO; 1050 U/kg/wk
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | 109 | 6.4
| EPO; 1050 U/kg/wk | 106 | 10.4
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | 15 | 0 | | | | | | | | | | 0
| EPO; 525 U/kg/wk | 10 | 0 | | | | | | | | | | 0

Evidence Table IV-1. Study description

Study | Study Description | Disease(s) | Transplant Description | Target Hb for RBC Engraftment (g/dL) | Hb Trigger for Transfusion (g/dL)
Autologous transplantation
Chao, Schriber, Long, et al., 1994 | Randomized; single-blinded; concurrent controls; placebo | Category: lymphoma; Tumor type: Hodgkin's and NHL | Autologous; combined PB and BM; TBI - some patients | | 10
Vannucchi, Bosi, Ieri, et al., 1996 | Randomized; unblinded; concurrent controls | Category: lymphoid malignancies; Tumor type: Hodgkin's, NHL, ALL | Autologous; bone marrow, TBI - some patients | 10 | 8
Pene, Appelbaum, Fisher, et al., 1993 | Unblinded, historical controls | Category: mixed solid & hematologic tumors; Tumor type: breast, neuroblastoma | Autologous; bone marrow; TBI - some patients | 12 | 10
Ayash, Elias, Hunt, et al., 1994 | Unblinded; historical controls; multicenter | Category: multiple solid tumors; Tumor type: Sarcoma, lung, breast, ovary | Autologous; bone marrow; TBI not specified | 10 | 8.3
Link, Boogaerts, Fauser, et al., 1994 | Randomized; double-blinded; concurrent controls; placebo; multicenter | Category: mixed hematologic malignancies; Tumor type: AML, ALL, NHL, Hodgkin's, CML | Autologous & allogenic; bone marrow; TBI - some patients; MTX not specified | 9 | 9
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Unblinded, historical controls | Category: leukemia; Tumor type: ALL, AML | Autologous & allogenic; bone marrow; TBI - some patients; no MTX prophylaxis | | 8

Evidence Table IV-2. Baseline study characteristics

Citation | Study Arm | EPO Treatment Regimen | G- or GM-CSF Use? | N Enrolled | N Evaluable | Age ^1^ +/−SD (range)
Autologous
Chao, Schriber, Long, et al., 1994 | Placebo control | | Yes | 17 | 17 | 40 (median) (22-51)
Chao, Schriber, Long, et al., 1994 | EPO | Start/stop: 600 U/kg, 3x per week for 4.3 weeks; discontinued when Hb=15.3 | Yes | 18 | 18 | 41 (median) (19-52)
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | Yes | 10 | 10
Vannucchi, Bosi, Ieri, et al., 1996 | EPO | Fixed: 150 U/kg, 7x per week for 3 weeks | Yes | 10 | 10
Pene, Appelbaum, Fisher, et al., 1993 | Control | | Yes | 65 | 65
Pene, Appelbaum, Fisher, et al., 1993 | EPO | Start/stop: 150 U/kg, 7x per week for 4.7 weeks; discontinued when Hb=12 | Yes | 18 | 18 | 34.9 (mean) (2-64)
Ayash, Elias, Hunt, et al., 1994 | Control | | No | 37 | 37 | 38 (median) (18-49)
Ayash, Elias, Hunt, et al., 1994 | EPO | Start/stop: 200 U/kg, 7x per week for 4 weeks; discontinued when Hb=11.7 | No | 11 | 10 | 41 (median) (36-55)
Link, Boogaerts, Fauser, et al., 1994 | Autologous placebo control | | No | 57 | 57 | 33 (median) (5-56)
Link, Boogaerts, Fauser, et al., 1994 | Autologous BMT, EPO | Fixed: 150 U/kg, 7x per week for 6 weeks; discontinued when Hb=9 | No | 57 | 57 | 35 (median) (3-55)
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Autologous BMT, Control | | No | 11 | 10 | 7.7 (median) (3-15)
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Autologous BMT, EPO | Fixed: 75 U/kg, I7x per week for 4.3 weeks | No | 10 | 10 | 9.8 (median) (3-15)

1 Where age was reported only for the entire group of enrollees, these data are entered for all Study arms.

Evidence Table IV-3. Report for RBC engraftment

Study | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable | Percent of Patients Engrafted | p Value | Time to Engraftment (days) | p Value | Reticulocyte Measurement Reported | Reticulocyte Result | p Value
Autologous
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | | 10 | | | | | Reticulocyte count at day 30 after transplant | 40.1+/−23.9 x 10^9^
| EPO | 525 | 10 | | | | | Reticulocyte count at day 30 after transplant | 42.0+/−26.5 x 10^9^ | NS
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | 10 | | | 28.8 (mean) +/−13.2 | | Days to reticulocytes > 30 x 10^9^/L | 26.4+/−9.9 days
| EPO | 1050 | 10 | | | 36.7 (mean) +/−20.8 | NS | Days to reticulocytes > 30 x 10^9^/L | 15.3+/−3.5 days | <0.05
Pene, Appelbaum, Fisher, et al., 1993 | Control | | 65
| EPO | 1050 | 18
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 57 | 0.660000026 | | 27 (median) | | Maximum reticulocyte count | 15 x 10^9^/L
| EPO | 1050 | 57 | 0.720000029 | | 24 (median) | 0.77 | Maximum reticulocyte count | 30 x 10^9^/L | NS
Ayash, Elias, Hunt, et al., 1994 | Control | | 37 | 0.620000005 | | 57 (median)
| EPO | 1400 | 10 | 0.899999976 | | 24 (median) | 0.001
Chao, Schriber, Long, et al., 1994 | Placebo control | | 17 | | | | | Maximum reticulocytes after engraftment | 13 (7-29) x 10^9^/L
| EPO | 1800 | 18 | | | | | Maximum reticulocytes after engraftment | 22 (3-83) x 10^9^/L | 0.48

Evidence Table IV-4. Report for RBC transfusion use

Study | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable | RBC Units transfused per Patient +/− SD | p Value | RBC Units/Patient/4 Wks | Platelet Transfusions ^1^ or Units Transfused ^2^ per Patient +/− SD | p Value | Days in Hospital +/− SD | p Value
Autologous
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | | 10 | 4.7 (mean) +/− 2.2 | | 4.4 | 9.6 (mean) +/− 6.2 ^1^
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO | 525 | 10 | 4.8 (mean) +/− 1.6 | NS | 4.5 | 7.5 (mean) +/− 4.0 ^1^ | NS
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | 10 | 4.1 (mean) +/− 2.0 | | | 7.2 (mean) +/− 3.0 ^1^
Vannucchi, Bosi, Ieri, et al., 1996 | EPO | 1050 | 10 | 3.5 (mean) +/− 2.2 | NS | | 6.1 (mean) +/− 2.0 ^1^ | NS
Pene, Appelbaum, Fisher, et al., 1993 | Control | | 65 | 8.0 (median) | | | | | 27
Pene, Appelbaum, Fisher, et al., 1993 | EPO | 1050 | 18 | 9.5 (median) | NS | | | | 30.5 | NS
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 57 | 7.2 (mean) +/− 5.3 | | 5
Link, Boogaerts, Fauser, et al., 1994 | EPO | 1050 | 57 | 7.6 (mean) +/− 6.2 | NS | 5.2 | | NS
Ayash, Elias, Hunt, et al., 1994 | Control | | 37 | 9.0 (median) | | | 83.0 (not specified) ^2^
Ayash, Elias, Hunt, et al., 1994 | EPO | 1400 | 10 | 7.0 (median) | NS | | 58.0 (not specified) ^2^ | 0.05
Chao, Schriber, Long, et al., 1994 | Placebo control | | 17 | 6.0 (median) | | 5.6 | 5.0 (median) ^1^
Chao, Schriber, Long, et al., 1994 | EPO | 1800 | 18 | 8.0 (median) | 0.22 | 7.4 | 10.0 (median) ^1^ | 0.14

1 Platelet transfusions

2 Units transfused

Evidence Table IV-5. Adverse events report

Study | Treatment Arm; Dose | N Evaluable | Hypertension % | Rash/Irritation/Pruritus % | Mortality % | DVT/Thrombotic Event % | Hemorrhage/Thrombocytopenia % | Seizure % | Other Cardiovasc. % | Inject'n Site Pain % | Fatigue % | Withdrawals % | Any Adverse Event
Autologous
Chao, Schriber, Long, et al., 1994 | Placebo control | 17 | | | 5.9 | 0 | 0 | | | | | 0 | 5.9
| EPO; 1,800 U/kg/wk | 18 | | | 11.1 | 5.6 | 5.6 | | | | | 5.6 | 22.2
Vannucchi, Bosi, Ieri, et al., 1996 | Control | 10
| EPO; 1,050 U/kg/wk | 10
Pene, Appelbaum, Fisher, et al., 1993 | Control
| EPO; 1,050 U/kg/wk
Ayash, Elias, Hunt, et al., 1994 | Control
| EPO; 1,400 U/kg/wk
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | 57 | 5.3
| EPO; 1,050 U/kg/wk | 57 | 0
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | 10 | 0 | | | | | | | | | | 0
| EPO; 525 U/kg/wk | 10 | 0 | | | | | | | | | | 0