# Bibliography

Aaronson NK, Ahmedzai S, Bergman B, et al The European Organization for Research and Treatment of Cancer QLQ-C30: A quality-of-life instrument for use in international clinical trials in oncology J Natl Cancer Inst 1993 Mar 3 85(5):365 76
Abels R Erythropoietin for anaemia in cancer patients Eur J Cancer 1993 29A(Suppl 2):S2 S8 8398361
Abels RI Recombinant human erythropoietin in the treatment of the anaemia of cancer Acta Haematol 1992 87(Suppl 1):4 11 1574966
Abels RI Recombinant human erythropoietin therapy for the anemia of cancer Leuk Lymphoma 1992 7(Suppl 2):94 6
Abels RI Use of recombinant human erythropoietin in the treatment of anemia in patients who have cancer Semin Oncol 1992 Jun 19(3 Suppl 8):29 35 1615337
Abels RI, Larholt KM, Krantz KD, et al. Recombinant human erythropoietin (r-HuEPO) for the treatment of the anemia of cancer. Blood cell growth factors: Their present and future use. Hematol Oncol. 1991:121-41.
Adam Z, Krahulova M, Spelda S, et al [Evaluation of treatment of anemia with erythropoietin in patients with multiple myeloma] Vnitr Lek 1995 Nov 41(11):767 72 8553596
Adam Z, Krahulova M, Spelda S, et al Therapy of anemia in patients with multiple myeloma Acta Med Austriaca 1995 22(4):59 64 8835422
Adam Z, Krejci M, Vorlicek J [Erythropoietin in hematology and oncology. I. Chronic anemia in malignant disease and the pharmacology of erythropoietin] Vnitr Lek 1996 Apr 42(4):285 9 8693717
Adam Z, Krejci M, Vorlicek J [Erythropoietin in oncology. II. Evaluation of the effectiveness of erythropoietin in hematologic and oncologic diseases] Vnitr Lek 1996 May 42(5):351 8 8768296
Adamson JW Epoetin alfa: Into the new millennium Semin Oncol 1998 Jun 25(3 Suppl 7):76 9 9671336
Adamson JW, Dicato MA Introduction Semin Oncol 1998 25(3 Suppl 7):
Adamson JW, Ludwig H Predicting the hematopoietic response to recombinant human erythropoietin (Epoetin alfa) in the treatment of the anemia of cancer Oncology 1999 56(1):46 53 9885377
Adamson JW, Schuster M, Allen S, et al Effectiveness of recombinant human erythropoietin therapy in myelodysplastic syndromes Acta Haematol 1992 87(Suppl 1):20 4 1574963
Adamson JW, Vapnek D. Recombinant erythropoietin to improve athletic performance. N Engl Med. 1991;324:698-9.
Aglietta M [Diagnostic approach to the anemic cancer patient] Tumori 1997 Jul-Aug 83(4 Suppl 2):S20 S25 9487380
Albitar S, Meulders Q, Hammond H, et al. Subcutaneous versus intravenous administration of erythropoietin improves its efficiency for the treatment of anaemia in haemodialysis patients. Nephrol Dial Transplant. 1995;10:40-3. [pmid: 8524493].
Aledort LM, Mohandas K Transfusion requirements in patients with malignancy Semin Hematol 1996 Jan 33(1 Suppl 1):6 9 8714609
Aloe Spiriti MA, Petti MC, Latagliata R, et al Is recombinant human erythropoietin treatment in myelodysplastic syndromes worthwhile? Leuk Lymphoma 1993 Jan 9(1-2):79 83 8477205
Aloe Spiriti MA, Petti MC, Latagliata R, et al Recombinant human erythropoietin in the treatment of myelodysplastic syndromes. An interim report Haematologica 1993 Mar-Apr 78(2):123 6 8349188
Alter BP Arms and the man or hands and the child: Congenital anomalies and hematologic syndromes J Pediatr Hematol Oncol 1997 19(4):287 91 9256825
Circular of information for the use of human blood and blood components. Brochure #ARC 1751-COI/7/98. July 1998.
Committee on Standards. Standards for blood banks and transfusion services. 19th ed. Washington, DC: American Association of Blood Banks; 1999. American Cancer Society. Cancer: Basic facts -- 1999 facts and figures. Available at: http://www.cancer.org/statistics/cff99/basicfacts.html#hadcancer. Accessed November 16, 1999.
Practice strategies for elective red blood cell transfusion Ann Intern Med 1992 116(5):403 6 1472172
Practice guidelines for blood component therapy Anesthesiology 1996 Mar 84(3):732 47 8659805
Amgen, Inc., Epogen® (epoetin alfa) prescribing information. In: Physicians' desk reference. 53rd ed. Montvale: Medical Economics Press; 1999.
Anand A, Anand A, Anand N Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy Cancer 1996 May 1 77(9):1960 1
Anon Anemia in chemotherapy: Erythropoietin improves the quality of life in ambulatory therapy also Dtsch Apoth Ztg 1997 137(28):46 7
Anon Cancer sensitivity to radiation therapy can be increased with erythropoietin Zeitschrift Fur Onkologie 1998 30(3):71 3
Anon EPO shown to improve cancer anemia Oncology (Huntingt) 1994 Jun 8(6):419372
Anon Epoietin beta in the treatment of anemia in cancer patients Dtsch Apoth Ztg 1996 136(38):
Anon Erythropoietin also effective in tumor anemia Munch Med Wochenschr 1996 138(38):
Anon Erythropoietin for anemia of cancer: Higher hematocrits, fewer transfusions Oncology (Huntingt) 1992 Sep 6(9):419372
Anon Erythropoietin prevents anemia in intensified chemotherapy of breast carcinoma Dtsch Apoth Ztg 1997 137(43):
Anon Focus on epoetin: Key findings of mini-sessions Semin Oncol 1998 Jun 25(3 Suppl 7):69 75 9671335
Anon Look beyond chronological age when considering cancer therapy Drugs Ther Perspect 1996 7(7):6 8
Anon Multiple myeloma difficult to treat Drugs Ther Perspect 1998 11(11):6 9
Anon New Approaches to the Treatment of Cancer-Related Anemia. Symposium proceedings. New York, October 23, 1993 Semin Oncol 1994 Apr 21(2 Suppl 3):1 41
Anon Treatment of anemia associated with multiple myeloma N Engl J Med 1991 Jul 4 325(1):62 3
Aoki S, Shibata A [Anemia and hemostatic abnormalities associated with multiple myeloma] Nippon Rinsho 1995 Mar 53(3):690 4
Apolone G, Filiberti A, Cifani S, et al. Evaluation of the EORTC QLQ-C3-questionnaire: A comparison with SF-36 Health Survey in a cohort of Italian long-survival cancer patients. Ann Oncol. 1998:549-57.
Arenas Gracia M, Abad Gosalvez A, Colomina Aviles J, et al [Recombinant human erythropoietin in the treatment of the anemia of multiple myeloma with kidney failure] An Med Interna 1995 Apr 12(4):187 8 7620064
Armitage JO Management of anemia in patients with cancer Clin Oncol Updates 1998 1(1):1 12
Aronson N, Seidenfeld J, Samson DJ, et al. Relative effectiveness and cost-effectiveness of methods of androgen suppression in the treatment of advanced prostatic cancer. Evidence Report/Technology Assessment No. 4. (Prepared by Blue Cross/Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-97-0015.) Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research. May 1999. AHCPR Publication No. 99-E0012.
Asbell SO, Tester WJ. The incidence of anemia in prostate cancer patients treated with androgen suppression and pelvic radiotherapy. Proc Annu Meet Am Soc Clin Oncol. 1994;13.
Aul C, Germing U Myelodysplastic syndrome Internist 1998 39(11):1168 80 9859051
Avvisati G, Petrucci MT, Mandelli F The role of biotherapies (interleukins, interferons and erythropoietin) in multiple myeloma Baillieres Clin Haematol 1995 Dec 8(4):815 29 8845574
Ayash LJ, Elias A, Hunt M, et al Recombinant human erythropoietin for the treatment of the anaemia associated with autologous bone marrow transplantation Br J Haematol 1994 May 87(1):153 61 7947240
Aymon P Blunting of the erythropoietin response and cancer anemia Cancer J 1990 3(4):
Balducci L, Hardy CL Anemia of aging: A model of erythropoiesis in cancer patients Cancer Control 1998 5(2 Suppl):17 21
Barlogie B Treatment of the anemia of multiple myeloma: The role of recombinant human erythropoietin Semin Hematol 1993 Oct 30(4 Suppl 6):25 7 8153675
Barlogie B, Beck T Recombinant human erythropoietin and the anemia of multiple myeloma Stem Cells (Dayt) 1993 Mar 11(2):88 94 86295
Barosi G, Marchetti M, Liberato NL Cost-effectiveness of recombinant human erythropoietin in the prevention of chemotherapy induced anaemia Br J Cancer 1998 78(6):781 7 9743301
Barsevick A, Langer C, Brunet D, et al. Correlation of quality of life (QOL) with survival, treatment response, and anemia in patients with advanced non-small cell lung cancer (NSCLC) treated with carboplatin and paclitaxel. Proc Annu Meet Am Soc Clin Oncol. 1997;16.
Bataille R, Harousseau JL Multiple myeloma N Engl J Med 1997 Jun 5 336(23):1657 64
Beck MN, Beck D Recombinant erythropoietin in acute chemotherapy-induced anemia of children with cancer Med Pediatr Oncol 1995 Jul 25(1):17 21 7752997
Begg C, Cho M, Eastwood S, et al Improving the quality of reporting of randomized trials: The CONSORT Statement JAMA 1996 Aug 28 276(8):637 9
Beguin Y A risk-benefit assessment of epoetin in the management of anaemia associated with cancer Drug Safety 1998b 19(4):269 82 9804442
Beguin Y Erythropoiesis and erythropoietin in multiple myeloma Leuk Lymphoma 1995 Aug 18(5-6):413 21 8528047
Beguin Y Erythropoietin and the anemia of cancer Acta Clin Belg 1996 51(1):36 52 8669161
Beguin Y Prediction of response to optimize outcome of treatment with erythropoietin Semin Oncol 1998a Jun 25(3 Suppl 7):27 34 9671327
Beguin Y, Lampertz S, Bron D, et al Serum erythropoietin in chronic lymphocytic leukaemia Br J Haematol 1996 Apr 93(1):154 6 8611451
Beguin Y, Yerna M, Loo M, et al Erythropoiesis in multiple myeloma: Defective red cell production due to inappropriate erythropoietin production Br J Haematol 1992 Dec 82(4):648 53 1482651
Beitz J Quality-of-life end points in oncology drug trials Oncology (Huntingt) 1999 Oct 13(10):1439 42 419372 10549568
Beitz J, Gnecco C, Justice R Quality-of-life end points in cancer clinical trials: The U.S. Food and Drug Administration perspective J Natl Cancer Inst Monogr 1996(20):7 9
Belanger C Hematopoietic growth factors in oncology. Therapeutic methods have been profoundly modified, but its cost justifies a thorough evaluation Rev Prat 1996 10(345):11 2, 14-6
Benedetti Panici P, Pierelli L, Scambia G, et al High-dose carboplatin, etoposide and melphalan (CEM) with peripheral blood progenitor cell support as late intensification for high-risk cancer: Non-haematological, haematological toxicities and role of growth factor administration Br J Cancer 1997 75(8):1205 12 9099971
Bennett JM, Kouides PA Diagnosis and management of anemia in patients with the myelodysplastic syndrome Cancer Control 1998 5(2 Suppl):41 5
Bennett TA, Wingert J Criteria for use of epoetin alfa in adult cancer and orthopedic-surgery patients Clin Pharm 1993 Dec 12(12):925 8 8137611
Bergsagel DE, Fitzgerald B, Quirt I, et al Treatment of anemia associated with multiple myeloma N Engl J Med 1991 Jan 3 324(1):59 60
Berlin JA, Rennie D Measuring the quality of trials: The quality of the quality scales JAMA 1999 Sep 15 282(11):1083 5
Bernell P, Stenke L, Wallvik J, et al A sequential erythropoietin and GM-CSF schedule offers clinical benefits in the treatment of anaemia in myelodysplastic syndromes Leuk Res 1996 Aug 20(8):693 9 8913323
Besa EC, Kunselman S, Nowell PC A pilot trial of 13-cis-retinoic acid and alpha-tocopherol with recombinant human erythropoietin in myelodysplastic syndrome patients with progressive or transfusion-dependent anemias. The Central Pennsylvania Oncology Group Leuk Res 1998 Aug 22(8):741 9 9680102
Besarab A, Flaherty KK, Erslev AJ, et al. Clinical pharmacology and economics of recombinant erythropoietin end-stage renal disease: The case for subcutaneous administration. J Am Soc Nephrol. 1992;3:1405-16.
Bessho M [Treatment with erythropoietin (EPO) of the anemia of patients with hematological diseases] Rinsho Ketsueki 1997 May 38(5):364 6 9194375
Bessho M, Jinnai I, Hirashima K, et al Trilineage recovery by combination therapy with recombinant human granulocyte colony-stimulating factor and erythropoietin in patients with aplastic anemia and refractory anemia Stem Cells (Dayt) 1994 Nov 12(6):604 15 86295 7533579
Betticher DC, Cerny T, Fey MF [Diagnosis and therapy of multiple myeloma: current aspects] Schweiz Med Wochenschr 1995 Mar 18 125(11):541 51
Biesma DH Erythropoietin treatment for non-uremic patients: A personal view Neth J Med 1999 Jan 54(1):10 5 10048290
Biggs JC, Atkinson KA, Booker V, et al Prospective randomised double-blind trial of the in vivo use of recombinant human erythropoietin in bone marrow transplantation from HLA-identical sibling donors. The Australian Bone Marrow Transplant Study Group Bone Marrow Transplant 1995 Jan 15(1):129 34 7742745
Birgegard G, Wide L, Simonsson B Marked erythropoietin increase before fall in Hb after treatment with cytostatic drugs suggests mechanism other than anaemia for stimulation Br J Haematol 1989 Jul 72(3):462 6 2669930
Blumberg N, Heal JM Immunomodulation by blood transfusion: An evolving scientific and clinical challenge Am J Med 1996 101(3):299 308 8873492
Bociek RG, Armitage JO Hematopoietic growth factors CA Cancer J Clin 1996 May-Jun 46(3):165 84 8646546
Bolonaki I, Stiakaki E, Lydaki E, et al Treatment with recombinant human erythropoietin in children with malignancies Pediatr Hematol Oncol 1996 Mar-Apr 13(2):111 21 8721025
Bondar GV, Dumanskii IuV, Iakovets IuI, et al. [Immediate results of surgical treatment of gastric cancer complicated by anemia]. Klin Khir. 1992;5:1-4. [pmid: 1380584].
Borsi JD, Ferencz T, Csaki C, et al Transfusion requirements of children with cancer and the use of human recombinant erythropoietin for the prevention and treatment of cytostatics induced anemia in children Can J Infect Dis 1995 6(Suppl C):
Bosi A, Vannucchi AM, Grossi A, et al Serum erythropoietin levels in patients undergoing autologous bone marrow transplantation Bone Marrow Transplant 1991 Jun 7(6):421 5 1873588
Bosze P, Mayer A, Thurzo L, et al [Recombinant human erythropoietin in the treatment of anemic patients undergoing chemotherapy for cancer] Orv Hetil 1995 Nov 19 136(47):2567 72
Bourantas K, Christou L, Tsiara S, et al Myelodysplastic syndromes: Erythropoietin level and treatment with recombinant human erythropoietin J Exp Clin Cancer Res 1995 14(2):205 10
Bourantas KL, Tsiara S, Makis A, et al Recombinant human erythropoietin for the treatment of anemia in chronic myelogenous leukemia Eur J Haematol 1997 Oct 59(4):263 5 9338625
Bowen DT, Culligan D, Beguin Y, et al Estimation of effective and total erythropoiesis in myelodysplasia using serum transferrin receptor and erythropoietin concentrations, with automated reticulocyte parameters Leukemia 1994 Jan 8(1):151 5 8289479
Bowen D, Culligan D, Jacobs A The treatment of anaemia in the myelodysplastic syndromes with recombinant human erythropoietin Br J Haematol 1991 Mar 77(3):419 23 2012769
Bowen DT, Janowska-Wieczorek A Serum erythropoietin following cytostatic therapy Br J Haematol 1990 Mar 74(3):372 3 2334647
Boyd HK, Lappin TR Erythropoietin deficiency in the anaemia of chronic disorders Eur J Haematol 1991 Apr 46(4):198 201 2015874
Braga M, Gianotti L, Gentilini O, et al Erythropoietic response induced by recombinant human erythropoietin in anemic cancer patients candidate to major abdominal surgery Hepatogastroenterology 1997 May-Jun 44(15):685 90 9222672
Braga M, Gianotti L, Vignali A, et al Evaluation of recombinant human erythropoietin to facilitate autologous blood donation before surgery in anaemic patients with cancer of the gastrointestinal tract Br J Surg 1995 Dec 82(12):1637 40 8548226
Brandberg Y Quality of life in clinical trials: Assessment and utility with special reference to rhuepo Med Oncol 1998 15(Suppl 1):S8 S12 9785331
Bucalossi A, Marotta G, Bigazzi C, et al Use of a functional classification of anemia in myelodysplastic syndromes to identify subgroups of patients responsive to recombinant human-erythropoietin therapy Eur J Haematol 1996 Jan-Feb 56(1-2):106 8 8599983
Buchbinder A, Adler H, Ballard H An unusual and unreported toxicity to erythropoietin (11) Am J Hematol 1993 42(4):412 3
Buemi M, Allegra A, Aloisi C, et al Hemodynamic effects of recombinant human erythropoietin [editorial] Nephron 1999 Jan 81(1):
Bukowski R, Glaspy J, Steinberg D, et al. Phase IV clinical evaluation of recombinant human erythropoietin (r-HuEPO) in anemic cancer patients receiving chemotherapy. Proc Annu Meet Am Soc Clin Oncol. 1994;13.
Bunn HF. Anemia associated with chronic disorders. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13^th^ ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994b. p. 1732-4.
Bunn HF. Pathophysiology of the anemias. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13^th^ ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994a. p. 1717-21.
Bunn HF Recombinant erythropoietin therapy in cancer patients J Clin Oncol 1990 Jun 8(6):949 51 2189955
Buntzel J, Kuttner K Cytokines in the treatment of head and neck cancer Z Onkol 1997 29(2):31 5
Bush RS The significance of anemia in clinical radiation therapy Int J Radiat Oncol Biol Phys 1986 Nov 12(11):2047 50 3771322
Caceres W, Baez L, Aponte I, et al Current role of chemotherapy protectors in cancer treatment Bol Asoc Med P R 1997 Oct-Dec 89(10-12):184 8 9577052
Calabresi F Papers based on oral presentations at the symposium: Applications of recombinant human erythropoietin in cancer patients Eur J Cancer 1993(Suppl 2):
Campistrus N, Gadola L, Gossio E, et al Acute leukemia and erythropoietin: Cause or casual relationship? Nephron 1995 69(1):
Canaud B, Bennhold I, Delons S, et al. What is the optimum frequency of administration of r-huepo for correcting anemia in hemodialysis patients?. Dial Transplant. 1995;24:306-9.
Casadevall N Treatment of anaemia with rHuEPO in patients with MDS Med Oncol 1998 15(Suppl 1):S35 S37 9785335
Casadevall N Update on the role of epoetin alfa in hematologic malignancies and myelodysplastic syndromes Semin Oncol 1998 Jun 25(3 Suppl 7):12 8 9671324
Casadevall N, Belanger C, Goy A, et al High-dose recombinant human erythropoietin administered intravenously for the treatment of anaemia in myelodysplastic syndromes Acta Haematol 1992 87(Suppl 1):25 7 1574964
Cascinu S, Catalano G, Cellerino R Recombinant human erythropoietin in chemotherapy-associated anemia Cancer Treatment Rev 1995 21(6):553 64
Cascinu S, Del Ferro E, Fedeli A, et al Recombinant human erythropoietin treatment in elderly cancer patients with cisplatin-associated anemia Oncology 1995 Sep-Oct 52(5):422 6 7637961
Cascinu S, Fedeli A, Del Ferro E, et al Recombinant human erythropoietin treatment in cisplatin-associated anemia: A randomized, double-blind trial with placebo J Clin Oncol 1994 12(5):1058 62 8164030
Cascinu S, Fedeli A, Luzi Fedeli S, et al Cisplatin-associated anaemia treated with subcutaneous erythropoietin: A pilot study Br J Cancer 1993 67(1):156 8 8427776
Case DC Jr, Bukowski RM, Carey RW, et al Recombinant human erythropoietin therapy for anemic cancer patients on combination chemotherapy J Natl Cancer Inst 1993 May 19 85(10):801 6
Catlin DH, Hatton CK. Use and abuse of anabolic and other drugs. Adv Intern Med. 1991;36:399-424. [pmid: 1673818].
Cazzola M Guidelines for the use of rHuEPO in anaemia of malignancy Med Oncol 1998 15(Suppl 1):
Cazzola M, Anderson JE, Ganser A, et al A patient-oriented approach to treatment of myelodysplastic syndromes Haematologica 1998 83(10):910 35 9830800
Cazzola M, Mercuriali F, Brugnara C Use of recombinant human erythropoietin outside the setting of uremia Blood 1997 Jun 15 89(12):4248 67
Cazzola M, Messinger D, Battistel V, et al Recombinant human erythropoietin in the anemia associated with multiple myeloma or non-Hodgkin's lymphoma: Dose finding and identification of predictors of response Blood 1995 Dec 15 86(12):4446 53
Cazzola M, Ponchio L, Beguin Y, et al Subcutaneous erythropoietin for treatment of refractory anemia in hematologic disorders. Results of a phase I/II clinical trial Blood 1992 Jan1 79(1):29 37
Cazzola M, Ponchio L, Pedrotti C, et al Prediction of response to recombinant human erythropoietin (rHuEpo) in anemia of malignancy Haematologica 1996 Sep-Oct 81(5):434 41 8952157
Cella D Factors influencing quality of life in cancer patients: Anemia and fatigue Semin Oncol 1998 25(3 Suppl 7):43 6 9671330
Cella D The Functional Assessment of Cancer Therapy-Anemia (FACT-An) Scale: A new tool for the assessment of outcomes in cancer anemia and fatigue Semin Hematol 1997 Jul 34(3 Suppl 2):13 9 9253779
Cella DF, Tulsky DS, Gray G, et al The Functional Assessment of Cancer Therapy Scale: Development and validation of the general measure J Clin Oncol 1993 Mar 11(3):570 9 8445433
Chalmers TC, Smith H Jr, Blackburn B, et al A method for assessing the quality of a randomized control trial Controlled Clin Trials 1981 May 2(1):31 49 7261638
Champlin RE Therapeutic use of hematopoietic growth factors for patients receiving high-dose chemotherapy and bone marrow transplantation Cancer Bull 1991 43(3):197 207
Chan AT, Johnson PJ. Erythropoietin for anemia in Chinese cancer patients on chemotherapy. 2nd EORTC International Hong Kong Symposium on Current Trends in Cancer Care; 1995. p. 51.
Chan AT, Leung WT, Lin J, et al Recombinant human erythropoietin for anaemia in Chinese cancer patients on chemotherapy Clin Oncol (R Coll Radiol) 1995 7(4):
Chao NJ, Schriber JR, Long GD, et al A randomized study of erythropoietin and granulocyte colony-stimulating factor (G-CSF) versus placebo and G-CSF for patients with Hodgkin's and non-Hodgkin's lymphoma undergoing autologous bone marrow transplantation Blood 1994 May 15 83(10):2823 8
Chatta GS, Dale DC Aging and haemopoiesis: Implications for treatment with haemopoietic growth factors Drugs Aging 1996 9(1):37 47 8818584
Chavin SI Erythropoietin therapy for anemia (1) J Am Geriatr Soc 1995 43(3):314 5 7884127
Cheson BD The myelodysplastic syndromes Oncologist 1997(1):28 39
Cheson BD, Feigal EG Clinical trials referral resource. AIDS-related non-Hodgkin's lymphomas Oncology (Huntingt) 1993 Apr 7(4):37 8 419372
Chevrel B The treatment of anemia in cancer patients and other indications for recombinant erythropoietin Med Chir Dig 1996 25(3):149 51
Chie WC, Huang CS, Chen JH, et al Measurement of the quality of life during different clinical phases of breast cancer J Formos Med Assoc 1999 98(4):254 60 10389369
Chiou T-J, Chim Y-S, Wei C-H, et al The effect of subcutaneous r-huepo in cancer patients receiving chemotherapy with anemia: A preliminary report Chin Med J (Taipei) 1997 60(5):229 35
Chow E, Danjoux CE, Pataki I, et al Effect of hemoglobin on radiotherapy response in children with medulloblastoma: Should patients with a low hemoglobin be transfused? Med Pediatr Oncol 1999 32(5):395 7 10219347
Chudek J, Wiecek A, Kokot F, et al [Serum erythropoietin concentration in women with uterine or ovarian tumors] Przegl Lek 1998 55(2):47 50
Ciotti R, Rosti V, Lucotti C, et al Treatment with retinoids and haemopoietic growth factors in myelodysplastic syndromes (1) Br J Haematol 1995 91(3):773 4 8555092
Cleeland CS, Demetri GD, Glaspy J, et al. Identifying hemoglobin level for optimal quality of life: Results of an incremental analysis. 1999 ASCO annual meeting. 18:2215.
Cohen J. Statistical power analysis for the behavioral sciences. New York: Academic Press, 1977. p. 8-17.
Corazza F, Beguin Y, Bergmann P, et al Anemia in children with cancer is associated with decreased erythropoietic activity and not with inadequate erythropoietin production Blood 1998 Sep1 92(5):1793 8
Coster JM, Gianfrancesco F, Chuldzinski P Paying for expensive new technologies: Medicare's experiences with recombinant erythropoietin Cancer Invest 1991 9(6):675 81 1747793
Cottu P-H, Cojean-Zelek I The role of recombinant human erythropoietin in cancerology Hematologie 1997 3(2 Suppl):81 4
Crawford J. Erythropoietin in the treatment and prevention of cancer and chemotherapy related anemia. In: 3rd International Conference Clinical Applications of Cytokines and Growth Factors in Hematology and Oncology; June 8-10, 1995; Atlanta, GA; 1995. p. 24-7.
Crawford J, Blackwell S Erythropoietin and the management of anemia in patients with lung cancer Cancer Control 1998 5(2 Suppl):26 32 10762464
Crawford J, Blackwell S, Shoemaker D, et al. The prophylactic role of recombinant human erythropoietin (rHuEPO) in reducing chemotherapy related anemia in patients with small cell lung cancer (SCLC) receiving cyclophosphamide, doxorubicin, and etoposide (CAE) chemotherapy with G-CSF support. Proc Annu Meet Am Soc Clin Oncol. 1994;13.
Cremieux P-Y, Finkelstein SN, Berndt ER, et al Cost effectiveness, quality-adjusted life-years and supportive care: Recombinant human erythropoietin as a treatment of cancer-associated anaemia Pharmacoeconomics 1999 16(5 Pt 1):459 72 10662393
Croockewit AJ, Bronchud MH, Aapro MS, et al A European perspective on haematopoietic growth factors in haemato-oncology: Report of an expert meeting of the EORTC Eur J Cancer 1997 Oct 33(11):1732 46 9470826
Csaki C, Ferencz T, Schuler D, et al Recombinant human erythropoietin in the prevention of chemotherapy-induced anaemia in children with malignant solid tumours Eur J Cancer 1998 34(3):364 7 9640223
Culine S [Haematopoietic growth factors and solid tumors] Rev Med Interne 1997 18(8):657 61 9365742
Dalton WS Anemia in multiple myeloma and its management Cancer Control 1998 5(2 Suppl):46 50 10762467
Dammacco F, Silvestris F, Castoldi GL, et al The effectiveness and tolerability of epoetin alfa in patients with multiple myeloma refractory to chemotherapy Int J Clin Lab Res 1998 28(2):127 34 9689556
Daniele E, Foti G [A peculiar form of anemia in patients operated on for cancer of the oral cavity] Minerva Stomatol 1997 Dec 46(12):665 9 9567616
Davis HP Erythropoietin for patient refusing blood transfusion Lancet 1990 336(8711):384 5 1975371
Davis HP, Brown H Epoetin alfa for anaemia of chronic leukaemia Lancet 1991 Jan 5 337(8732):
de Andrade JR, Frei D, Guilfoyle M Integrated analysis of thrombotic/vascular event occurrence in epoetin alfa-treated patients undergoing major, elective orthopedic surgery Orthopedics 1999 Jan 22(1 Suppl):S113 S118 9927111
de Campos E, Radford J, Steward W, et al Clinical and in vitro effects of recombinant human erythropoietin in patients receiving intensive chemotherapy for small-cell lung cancer J Clin Oncol 1995 Jul 13(7):1623 31 7602351
De Serdio JL, Villar A, Saavedra JA, et al About the need for transfusion owing to anemia in connexion with the prognosis of E.N.T.-Cancer treated according a schedule with concomitant hyperfractionation of carboplatin and irradiation An Otorrinolaringol Ibero Am 1998 25(3):233 46 9658662
De Vries EGE, Vellenga E, Willemse PHB Haematopoietic growth factors in oncology: Present and future Pharmaceutisch Weekblad 1995(28):751 5
DeCosse JJ, Cennerazzo WJ Quality-of-life management of patients with colorectal cancer CA Cancer J Clin 1997 47(4):198 206 9242168
Del Mastro L, Venturini M Strategies for the use of epoetin alfa in breast cancer patients Oncologist 1998 3(5):314 8 10388121
Del Mastro L, Venturini M, Garrone O, et al. Erythropoietin in the prevention of chemotherapy induced anemia: Results from a randomized trial in early breast cancer patients. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Del Mastro L, Venturini M, Lionetto R, et al Randomized phase III trial evaluating the role of erythropoietin in the prevention of chemotherapy-induced anemia J Clin Oncol 1997 Jul 15(7):2715 21 9215845
Demetri GD Hematopoietic growth factors: Defining the appropriate clinical role in multimodality cancer therapy Chest 1995 107(6 Suppl):255S 60S 7540124
Demetri GD, Clark PM, Shapiro CL, et al. Incidence of persistent hematopoietic compromise following repetitive cycles of dose-intensive chemotherapy and cytokines for breast cancer. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Demetri GD, Kris M, Wade J, et al Quality-of-life benefit in chemotherapy patients treated with epoetin alfa is independent of disease response or tumor type: Results from a prospective community oncology study. Procrit Study Group J Clin Oncol 1998 Oct 16(10):3412 25 9779721
Denton TA, Diamond GA, Matloff JM, et al Anemia therapy: Individual benefit and societal cost Semin Oncol 1994 Apr 21(2 Suppl 3):29 35
Depaoli L, Levis A, Isabella N, et al Serum erythropoietin level and marrow erythroid infiltration predict response to recombinant human erythropoietin in myelodysplastic syndromes Haematologica 1993 78(2):118 22 8349187
DerSimonian R, Laird N. Meta analysis in clinical trials. Controlled Clin Trials. 1986;7:177-88. [pmid: 3802833].
Di Raimondo F, Longo G, Cacciola E Jr, et al A good response rate to recombinant erythropoietin alone may be expected in selected myelodysplastic patients. A preliminary clinical study Eur J Haematol 1996 Jan-Feb 56(1-2):7 11 8599997
Dickerman RD, Pertusi R, Miller J, et al Androgen-induced erythrocytosis: Is it erythropoietin? Am J Hematol 1999 Jun 61(2):154 5
Dimeo FC, Stieglitz RD, Novelli-Fischer U, et al Effects of physical activity on the fatigue and psychologic status of cancer patients during chemotherapy Cancer 1999 May 15 85(10):2273 7
Dimeo FC, Tilmann MH, Bertz H, et al Aerobic exercise in the rehabilitation of cancer patients after high dose chemotherapy and autologous peripheral stem cell transplantation Cancer 1997 May 1 79(9):1717 22
Dische S Radiotherapy and anaemia -- the clinical experience Radiother Oncol 1991 20(Suppl 1):35 40 2020767
Domenech J, Linassier C, Gihana E, et al Prolonged impairment of hematopoiesis after high-dose therapy followed by autologous bone marrow transplantation Blood 1995 85(11):3320 7 7756665
Dornbusch P Clinical efficacy of r-HuEPO in the treatment of cancer-related anaemia in paediatric patients Erythropoiesis 1996 7(2):40 5
Dowlati A, R'Zik S, Fillet G, et al Anaemia of lung cancer is due to impaired erythroid marrow response to erythropoietin stimulation as well as relative inadequacy of erythropoietin production Br J Haematol 1997 May 97(2):297 9 9163591
Dubray B, Mosseri V, Brunin F, et al Anemia is associated with lower local-regional control and survival after radiation therapy for head and neck cancer: A prospective study Radiology 1996 201(2):553 8 8888257
Duggan DB, Williams WJ Anemia in the hospitalized patient Hosp Pract 1992 27(2):125 30, 132-6
Dunphy FR, Dunleavy TL, Harrison BR, et al Erythropoietin reduces anemia and transfusions after chemotherapy with paclitaxel and carboplatin Cancer 1997 Apr 15 79(8):1623 8
Dunphy FR, Harrison BR, Dunleavy TL, et al Erythropoietin reduces anemia and transfusions: A randomized trial with or without erythropoietin during chemotherapy Cancer 1999 Oct 1 86(7):1362 7
Dusenbery K, McGuire W, Carson L, et al. Recombinant human erythropoietin (r-HuEPO) increases hemoglobin during radiation therapy for cervix cancer. Proc Annu Meet Am Soc Clin Oncol. 1993;12.
Dusenbery KE, McGuire WA, Holt PJ, et al Erythropoietin increases hemoglobin during radiation therapy for cervical cancer Int J Radiat Oncol Biol Phys 1994 Jul 30 29(5):1079 84
Dusenbery KE, McGuire WA, Potish RA, et al. Erythropoietin increases hemoglobin during radiation therapy for cervix cancer. In: American Radium Society's 75th Annual Meeting; April 24-8, 1993; Aruba. 1993. p. 32-3.
Eddy DM, Hasselblad V. FAST*PRO Software for Meta-analysis by the Confidence Profile Method. Orlando: Academic Press; 1992.
Egret statistical software Seattle: Statistics in Epidemiology Research Corporation; 1996. Eguchi K. Management of chemotherapy-induced anemia Curr Opin Oncol 1995 Jul 7(4):316 9 7578378
Elghetany MT Myelodysplastic syndromes in children (2) Br J Haematol 1996 93(4):977 8 8703838
Erslev AJ, Caro J. Erythropoietin: From mountain top to bedside. Adv Exp Med Biol. 1989;271:1-7.
Estey EH Treatment of acute myelogenous leukemia and myelodysplastic syndromes Semin Hematol 1995 32(2):132 51 7652581
Estruch J, Domingo A, Gardella S, et al Treatment of patients with myelodysplastic syndromes using human recombinant erythropoietin: Proposal for a therapeutic protocol Biol Clin Hematol 1992 14(1):17 23
Falkson CI, Keren-Rosenberg S, Uys A, et al Recombinant human erythropoietin in the treatment of cancer-related anaemia Oncology 1994 Nov-Dec 51(6):497 501 7970493
Faulds D, Sorkin EM Epoetin (recombinant human erythropoietin). A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in anaemia and the stimulation of erythropoiesis Drugs 1989 Dec 38(6):863 99 2693045
Fein DA, Lee WR, Hanlon AL, et al Pretreatment hemoglobin level influences local control and survival of T1-T2 squamous cell carcinomas of the glottic larynx J Clin Oncol 1995 Aug 13(8):2077 83 7636551
Fenaux P [Hematopoietic growth factors in the treatment of malignant hemopathies] Rev Med Interne 1997 18(8):668 72 9365744
Fenaux P Myelodysplastic syndromes Hematol Cell Ther 1996 38(5):363 80 8915667
Fenaux P, Chomienne C Hematopoietic growth factors. Do they have a role in the management of myelodysplastic syndromes? Hematologie 1997 3(2):155 61
Filip S, Vanasek J, Blaha M, et al Circulation of progenitor cells after intensive chemotherapy followed by combination G-CSF and EPO in breast carcinoma Neoplasma 1997 44(4):212 8 9473775
Finkelstein SN, Huber SL, Greenberg PE, et al Comment: Cost comparison of recombinant human erythropoietin and blood transfusion in cancer chemotherapy-induced anemia (4) Ann Pharmacother 1997 31(9):1094 5 9296258
Fisher JW Erythropoietin: Physiologic and pharmacologic aspects Proc Soc Exper Biol Med 1997 216(3):358 69 9402140
Fjornes T, Wiedemann GJ, Sack K, et al Serum erythropoietin and creatinine concentrations as predictive factors for response to recombinant human erythropoietin treatment in anaemic tumour patients on chemotherapy Oncol Rep 1998 Jan-Feb 5(1):81 6 9458299
Foerster J. Red cell fragmentation syndromes. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999.
Frenck RW Jr, Shannon KM Hematopoietic growth factors in pediatrics Curr Opin Pediatr 1993 5(1):94 102 7690636
Frenkel EP, Bick RL, Rutherford CJ Anemia of malignancy Hematol Oncol Clin North Am 1996 Aug 10(4):861 73 8811306
Friis LS, Christensen BE Influence of selected clinical events on the need for red blood cell transfusion in patients with severe cytopenia following myeloablative chemotherapy Eur J Haematol 1996 Jan-Feb 56(1-2):23 9 8599989
Furman WL, Crist WM Biology and clinical applications of hemopoietins in pediatric practice Pediatrics 1992 90(5 I):716 28 1383919
Gabrilove JL, Einhorn LH, Livingston RB, et al. Once-weekly dosing of epoetin alfa is similar to three-times-weekly dosing in increasing hemoglobin and quality of life. American Society of Clinical Oncology 1999 Annual Meeting. Abstract #2216.
Gamucci T, Thorel MF, Frasca AM, et al. Antianemic activity of erythropoietin in cisplatin-treated patients: A randomized trial. Proc Annu Meet Am Soc Clin Oncol. 1992;11.
Gamucci T, Thorel MF, Frasca AM, et al Erythropoietin for the prevention of anaemia in neoplastic patients treated with cisplatin Eur J Cancer 1993 29A(Suppl 2):S13 S14 8398359
Ganser A Hematopoietic growth factors in the treatment of the myelodysplastic syndromes Curr Opin Hematol 1995 May 2(3):204 9 9371996
Ganser A [Myeloproliferative syndromes] Ther Umsch 1996 Feb 53(2):97 102 8629270
Ganser A, Hoelzer D Clinical use of hematopoietic growth factors in the myelodysplastic syndromes Semin Hematol 1996 Jul 33(3):186 95 8819229
Ganser A, Karthaus M Clinical use of hematopoietic growth factors Curr Opin Oncol 1996 Jul 8(4):265 9 8869799
Ganser A, Karthaus M Clinical use of hematopoietic growth factors in the myelodysplastic syndromes Leuk Lymphoma 1997 Dec 26(Suppl 1):13 27 9570676
Ganser A, Maurer A, Contzen C, et al Improved multilineage response of hematopoiesis in patients with myelodysplastic syndromes to a combination therapy with all-trans-retinoic acid, granulocyte colony-stimulating factor, erythropoietin and alpha-tocopherol Ann Hematol 1996 Apr 72(4):237 44 8624378
Garton JP, Gertz MA, Witzig TE, et al Epoetin alfa for the treatment of the anemia of multiple myeloma. A prospective, randomized, placebo-controlled, double-blind trial Arch Intern Med 1995 Oct 23 155(19):2069 74
Gebbia V, Russo A, Gebbia N, et al Recombinant human erythropoietin accelerates recovery from cisplatin induced anemia in cancer patients: Preliminary results Cancer J 1991 4(5):343 7
Geissler RG, Ganser A Myelodysplastic syndromes: A guide to treatment with epoetin andcolony-stimulating factors Biodrugs 1998 10(2):97 109 18020588
Geissler RG, Schulte P, Ganser A Clinical use of hematopoietic growth factors in patients with myelodysplastic syndromes Int J Hematol 1997 Jun 65(4):339 54 9195774
Geissler RG, Schulte P, Ganser A Treatment with growth factors in myelodysplastic syndromes Pathol Biol (Paris) 1997 Oct 45(8):656 67 9569932
Ghio R, Balleari E Clinical use of recombinant human erythropoietin in the treatment of myelodysplastic syndromes Leuk Lymphoma 1992 7(Suppl 2):
Ghio R, Balleari E, Ballestrero A, et al Subcutaneous recombinant human erythropoietin for the treatment of anemia in myelodysplastic syndromes Acta Haematol 1993 90(2):58 64 8285019
Gillio AP Potential use of recombinant human hematopoietic growth factors in pediatrics Curr Opin Pediatr 1992 4(2):319 26
Glaspy J The impact of epoetin alfa on quality of life during cancer chemotherapy: A fresh look at an old problem Semin Hematol 1997 Jul 34(3 Suppl 2):20 6 9253780
Glaspy J, Bukowski R, Steinberg D, et al Impact of therapy with epoetin alfa on clinical outcomes in patients with nonmyeloid malignancies during cancer chemotherapy in community oncology practice. Procrit Study Group J Clin Oncol 1997 Mar 15(3):1218 34 9060566
Glaspy J, Cavill I Role of iron in optimizing responses of anemic cancer patients to erythropoietin Oncology (Huntingt) 1999 Apr 13(4):461 73; discussion 477-8, 483-8 419372 10234700
Glaspy JA Economic outcomes associated with the use of hematopoietic growth factors Oncology (Huntingt) 1995 Nov 9(11 Suppl):93 105 419372 8608062
Glimelius B, Linne T, Hoffman K, et al Epoetin beta in the treatment of anemia in patients with advanced gastrointestinal cancer J Clin Oncol 1998 Feb 16(2):434 40 9469326
Gold MR, Siegel JE, Russell LB, et al., editors. Cost-effectiveness in health and medicine. Oxford New York: University Press; 1996.
Goldmann SF. Red cell transfusions for polytransfused patients. Hamatol Bluttransfus. 1985;29:102-6.
Goodnough LT. Recombinant human erythropoietin -- Could it be used in a better way? In: Alternative approaches to human blood resources in clinical practice. Sibinga CTS, Das PC, Fratantoni JC, editors. Dordrecht, Netherlands: Kluwer Academic Publ; 1998. p.75-9.
Goodnough LT, Anderson KC Recombinant growth factors Transf Sci 1995 16(1):45 62
Goodnough LT, Anderson KC, Kurtz S, et al Indications and guidelines for the use of hematopoietic growth factors Transfusion 1993 Nov-Dec(11):944 59
Goodnough LT, Monk TG, Andriole GL Erythropoietin therapy N Engl J Med 1997 336(13):933 8 9070475
Gordon MS, Nemunaitis J, Hoffman R, et al A phase I trial of recombinant human interleukin-6 in patients with myelodysplastic syndromes and thrombocytopenia Blood 1995 Jun 1 85(11):3066 76
Gough IR, Furnival CM, Schilder L, et al Assessment of the quality of life of patients with advanced cancer Eur J Cancer Clin Oncol 1983 Aug 19(8):1161 5 6684561
Goy A, Belanger C, Casadevall N, et al High doses of intravenous recombinant erythropoietin for the treatment of anaemia in myelodysplastic syndrome Br J Haematol 1993 Jun 84(2):232 7 8398823
Greenbaum BH, Herman JH Transfusion therapy in pediatric oncology Pediatr Ann 1988 Nov 17(11):687 93 3070469
Greenberg PL The role of hemopoietic growth factors in the treatment of myelodysplastic syndromes Int J Pediatr Hematol Oncol 1997 4(3):231 8
Greenberg PL Treatment of myelodysplastic syndromes with hemopoietic growth factors Semin Oncol 1992 Feb 19(1):106 14 1371018
Greenburg AG Benefits and risks of blood transfusion in surgical patients World J Surg 1996 Nov-Dec 20(9):1189 93 8864080
Gridelli C, Pertone F, Monfardini S Lung cancer in the elderly Eur J Cancer 1997 33(14):2313 4 9616273
Griggs JJ, Blumberg N Recombinant erythropoietin and blood transfusions in cancer chemotherapy-induced anemia Anti-Cancer Drugs 1998 9(10):925 32 9890704
Groopman JE, Itri LM Chemotherapy-induced anemia in adults: Incidence and treatment J Natl Cancer Inst 1999 91(19):1616 34 10511589
Haber J, Spicka I, Petruzelka L, et al [Recombinant human erythropoietin in the treatment of anemia associated with lymphoproliferative diseases -- chronic lymphadenosis and multiple myeloma] Vnitr Lek 1996 Apr 42(4):262 7 8693713
Halstenson CE, Macres M, Katz SA, et al Comparative pharmacokinetics and pharmacodynamics of epoetin alfa and epoetin beta Clin Pharmacol Ther 1991 Dec 50(6):702 12 1752115
Hann IM Haemopoietic growth factors and childhood cancer Eur J Cancer 1995 31(9):1476 8 7577075
Hansen PB, Johnsen HE, Hippe E, et al Recombinant human granulocyte-macrophage colony-stimulating factor plus recombinant human erythropoietin may improve anemia in selected patients with myelodysplastic syndromes Am J Hematol 1993 Dec 44(4):229 36 8237992
Hansen PB, Penkowa M, Johnsen HE Hematopoietic growth factors for the treatment of myelodysplastic syndromes Leuk Lymphoma 1998 Feb 28(5-6):491 500 9613978
Hartung G, Weigold A, Ohl S, et al Phase II study of subcutaneous erythropoietin for treatment of myelodysplastic syndromes (FAB type I and II): A trial of the phase I/II study group of the Association for Medical Oncology of the German Cancer Society Onkologie 1995 18(5):451 5
Hashine K, Karashima T, Kasahara K, et al [Usefulness of recombinant human erythropoietin on predeposit autologous blood transfusion in patients undergoing radical prostatectomy] Hinyokika Kiyo 1997 Jun 43(6):411 4 9250490
Hasle H Myelodysplastic syndromes in childhood classification, epidemiology, and treatment Leuk Lymphoma 1994 13(1-2):11 26 8025513
Hasselblad V. Meta-analysis of multi-treatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Hast R, Celsing F, Ekman M, et al Response to recombinant human erythropoietin treatment in myelodysplastic syndromes (MDS) J Intern Med 1991 Apr 229(4):381 2 2026993
Hast R, Eriksson M, Jakovleva K Aspects on the clinical use of hematopoietic growth factors in myelodysplastic syndromes Pol Arch Med Wewn 1998 Feb 99(2):144 9 9686516
Hedges LV, Olkin I, editors. Statistical methods for meta-analysis. Orlando: Academic Press; 1985.
Heinz R, Reisner R, Pittermann E Erythropoietin for chemotherapy patient refusing blood transfusion Lancet 1990 Mar 3 335(8688):542 3
Heiss MM, Tarabichi A, Delanoff C, et al Perisurgical erythropoietin application in anemic patients with colorectal cancer: A double-blind randomized study Surgery 1996 May 119(5):523 7 8619207
Hellman S. Principles of cancer management: Radiation therapy. In: DeVita VT Jr, et al., editors. Cancer: Principles and practice of oncology. 5th ed. Philadelphia: Lippincott-Raven; 1997.
Hellstrom E, Birgegard G, Lockner D, et al Treatment of myelodysplastic syndromes with recombinant human erythropoietin Eur J Haematol 1991 Nov 47(5):355 60 1761122
Hellstrom-Lindberg E Efficacy of erythropoietin in the myelodysplastic syndromes: A meta-analysis of 205 patients from 17 studies Br J Haematol 1995 Jan 89(1):67 71 7833279
Hellstrom-Lindberg E, Ahlgren T, Beguin Y, et al Treatment of anemia in myelodysplastic syndromes with granulocyte colony-stimulating factor plus erythropoietin: Results from a randomized phase II study and long-term follow-up of 71 patients Blood 1998 Jul 1 92(1):68 75
Hellstrom-Lindberg E, Birgegard G, Carlsson M, et al A combination of granulocyte colony-stimulating factor and erythropoietin may synergistically improve the anaemia in patients with myelodysplastic syndromes Leuk Lymphoma 1993 Oct 11(3-4):221 8
Hellstrom-Lindberg E, Kanter-Lewensohn L, Ost A Morphological changes and apoptosis in bone marrow from patients with myelodysplastic syndromes treated with granulocyte-CSF and erythropoietin Leuk Res 1997 May 21(5):415 25 9225069
Hellstrom-Lindberg E, Negrin R, Stein R, et al Erythroid response to treatment with G-CSF plus erythropoietin for the anaemia of patients with myelodysplastic syndromes: Proposal for a predictive model Br J Haematol 1997 Nov 99(2):344 51 9375752
Henke M, Guttenberger R, Barke A, et al Erythropoietin for patients undergoing radiotherapy: A pilot study Radiother Oncol 1999 50(2):185 90 10368042
Henry D Haematological toxicities associated with dose-intensive chemotherapy, the role for and use of recombinant growth factors Ann Oncol 1997 8(Suppl 3):S7 S10 9341959
Henry D, Abels R, Larholt K Prediction of response to recombinant human erythropoietin (r-HuEPO/epoetin-alpha) therapy in cancer patients Blood 1995 Mar 15 85(6):1676 8
Henry DH Epoetin alfa and high-dose chemotherapy Semin Oncol 1998 Jun 25(3 Suppl 7):54 7 9671332
Henry DH Recombinant human erythropoietin for the treatment of anemia in patients with advanced cancer Semin Hematol 1993 Oct 30(4 Suppl 6):12 6 8153671
Henry DH Recombinant human erythropoietin treatment of anemic cancer patients Cancer Pract 1996 Jul-Aug 4(4):180 4 8900758
Henry DH Supplemental iron: A key to optimizing the response of cancer-related anemia to rhuepo? Oncologist 1998 3(4):275 8 10388116
Henry DH The management of cancer anemia Support Care Cancer 1994 Nov 2(6):403 4 7858936
Henry DH, Abels RI Benefits of epoetin alfa therapy in anemic cancer patients receiving chemotherapy J Clin Oncol 1995 Sep 13(9):2473 4 7666110
Henry DH, Abels RI Recombinant human erythropoietin in the treatment of cancer and chemotherapy-induced anemia: Results of double-blind and open-label follow-up studies Semin Oncol 1994 Apr 21(2 Suppl 3):21 8
Henry DH, Brooks BJ Jr, Case DC Jr, et al Recombinant human erythropoietin therapy for anemic cancer patients receiving cisplatin chemotherapy Cancer J Sci Am 1995 Nov 1(4):
Henry DH, Spivak JL Clinical use of erythropoietin Curr Opin Hematol 1995 Mar 2(2):118 24 9371981
Henry III DH, Thatcher N Patient selection and predicting response to recombinant human erythropoietin in anemic cancer patients Semin Hematol 1996 33(1 Suppl 1):2 5
Hermanne J-P, Beguin E Use of epoetin alfa after allogeneic bone marrow transplantation Erythropoiesis 1997 8(3):80 3
Herrmann F, Mertelsmann R, Lindemann A, et al Clinical use of recombinant human hematopoietic growth factors (GM-CSF, IL-3, EPO) in patients with myelodysplastic syndrome Biotechnol Ther 1991 2(3-4):299 311 1845132
Hirashima K, Bessho M, Jinnai I. Improvement in anemia by recombinant human erythropoietin in patients with myelodysplastic syndrome and aplastic anemia. Contrib Nephrol. 1991;88:254-65. [pmid: 2040187].
Hoeltge GA, Domen RE, Rybicki LA, et al Multiple red cell transfusions and alloimmunization. Experience with 6996 antibodies detected in a total of 159,262 patients from 1985 to 1993 Arch Pathol Lab Med 1995 Jan 119(1):42 5 7802552
Hrushesky WJM, Martynowicz M, Markiewicz M, et al Chronotherapy of cancer: A major drug-delivery challenge Adv Drug Deliv Rev 1992 9(1):1 83
Iibachi N Anemia and changes in serum erythropoietin levels during chemotherapy for lung cancer Jpn J Lung Cancer 1995 35(4):393 400
Ikebuchi Y, Shimizu H, Moriyama A, et al [Autologous blood transfusion with recombinant human erythropoietin and hypotensive anesthesia in operation for gynecological malignant tumors] Nippon Sanka Fujinka Gakkai Zasshi 1995 Feb 47(2):169 72 7706859
Imamura M, Kobayashi M, Kobayashi S, et al Failure of combination therapy with recombinant granulocyte colony-stimulating factor and erythropoietin in myelodysplastic syndromes Ann Hematol 1994 Apr 68(4):163 6 7516190
Irvine D, Vincent L, Graydon JE, et al The prevalence and correlates of fatigue in patients receiving treatment with chemotherapy and radiotherapy Cancer Nurs 1994 17(5):367 78 7954384
Isnard F, Najman A, Jaar B, et al Efficacy of recombinant human erythropoietin in the treatment of refractory anemias without excess of blasts in myelodysplastic syndromes Leuk Lymphoma 1994 Jan 12(3-4):307 14 8167562
A randomized double-blind placebo-controlled study with subcutaneous recombinant human erythropoietin in patients with low-risk myelodysplastic syndromes Br J Haematol 1998 Dec 103(4):1070 4 9886322
Jacobs A, Culligan D, Bowen D. Erythropoietin and the myelodysplastic syndrome. Contrib Nephrol. 1991;88:266-70. [pmid: 2040188].
Jacobs A, Janowska-Wieczorek A, Caro J, et al Circulating erythropoietin in patients with myelodysplastic syndromes Br J Haematol 1989 Sep 73(1):36 9 2803975
Jacobs K, Shoemaker C, Rudersdorf R, et al. Isolation and characterization of genomic and cDNA clones of human erythropoietin. Nature. 1985;313:806-10. [pmid: 3838366].
James RD, Wilkinson PM, Belli F, et al Recombinant human erythropoietin in patients with ovarian carcinoma and anaemia secondary to cisplatin and carboplatin chemotherapy: Preliminary results Acta Haematol 1992 87(Suppl 1):12 5 1574960
Janssens M, Lamy M [Role of recombinant erythropoietin during the preoperative period] Ann Fr Anesth Reanim 1995 14(Suppl 1):98 106 7486323
Jeekel J Autologous blood donation and epoetin alfa in cancer surgery Semin Hematol 1996 Apr 33(2 Suppl 2):43 6; discussion 47 8723582
Jelkmann W, Wolff M, Fandrey J. Inhibition of erythropoietin production by cytokines and chemotherapy may contribute to the anemia in malignant diseases. Adv Exp Med Biol. 1994;345:525-30. [pmid: 8079754].
Jilani SM, Glaspy JA. Impact of epoetin alfa in chemotherapy-associated anemia. Semin Oncol. 1998;(5):571-6.
Jin SL The use of erythropoietin in radiation oncology Cancer Control 1998 5(2 Suppl):33 40 10762465
Jones TH, Wadler S, Hupart KH Endocrine-mediated mechanisms of fatigue during treatment with interferon-alpha Semin Oncol 1998 Feb 25(1 Suppl 1):54 63
Joosten E, Van Hove L, Lesaffre E, et al Serum erythropoietin levels in elderly inpatients with anemia of chronic disorders and iron deficiency anemia J Am Geriatr Soc 1993 Dec 41(12):1301 4 8227911
Juni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Kajikawa M, Nonami T, Kurokawa T, et al Autologous blood transfusion for hepatectomy in patients with cirrhosis and hepatocellular carcinoma: Use of recombinant human erythropoietin Surgery 1994 Jun 115(6):727 34 8197566
Kalman D, Villani LJ Nutritional aspects of cancer-related fatigue J Am Diet Assoc 1997 Jun 97(6):650 4 9183327
Karp JE Molecular pathogenesis and targets for therapy in myelodysplastic syndrome (MDS) and MDS-related leukemias Curr Opin Oncol 1998 10(1):3 9 9466478
Karthaus M, Ganser A Current practice in the clinical use of hematopoietic growth factors following chemo-/radiotherapy in gynecological malignancies Zentralbl Gynakol 1997 119(12):585 96 9483809
Kasper C, Terhaar A, Fossa A, et al Recombinant human erythropoietin in the treatment of cancer-related anaemia Eur J Haematol 1997 Apr 58(4):251 6 9186536
Kaufman JS, Reda DJ, Fye CL, et al Subcutaneous compared with intravenous epoetin in patients receiving hemodialysis N Engl J Med 1998 339(9):578 83 9718376
Kazis LE, Anderson JJ, Meenan RF Effect sizes for interpreting changes in health status Med Care 1989 27(Suppl):S178 S189 2646488
Kemmler G, Holzner B, Kapp M, et al Comparison of two quality-of-life instruments for cancer patients: The Functional Assessment of Cancer Therapy-General and the European Organization for Research and Treatment of Cancer Quality of Life Questionnaire-C30 J Clin Oncol 1999 17(9):2932 40 10561373
Kerre T, Offner F, Van Hove W Anemia in the cancer patient Tijdsch Geneeskund 1998 54(16):1079 85
Ketley NJ, Newland AC Haemopoietic growth factors Postgrad Med J 1997 Apr 73(858):215 21 9156123
Kettelhack C, Hones C, Messinger D, et al Randomized multicentre trial of the influence of recombinant human erythropoietin on intraoperative and postoperative transfusion need in anaemic patients undergoing right hemicolectomy for carcinoma Br J Surg 1998 Jan 85(1):63 7 9462386
Kettelhack C, Schoter D, Matthias D, et al Serum erythropoietin levels in patients with solid tumours Eur J Cancer 1994 30A(9):1289 91 7999415
Kikuchi M, Inagaki T, Imaida K, et al Anemia in elderly patients with malignant tumors Jpn J Geriatr 1996(10):768 73
King DJ Transfusion and the use of blood products Baillieres Clin Haematol 1991 Apr 4(2):545 69 1912669
Klaesson S. Clinical use of rHuEPO in bone marrow transplantation. Med Oncol. 1999;16:2-7. [pmid: 10382935].
Klaesson S, Ringden O, Ljungman P, et al Reduced blood transfusions requirements after allogeneic bone marrow transplantation: Results of a randomised, double-blind study with high-dose erythropoietin Bone Marrow Transplant 1994a Apr 13(4):397 402 8019463
Klaesson S, Ringden O, Ljungman P, et al Treatment with erythropoietin after allogeneic bone marrow transplantation: A randomized, double-blind study Transplant Proc 1994b Jun 26(3):1827 8 8030158
Koeller JM Clinical guidelines for the treatment of cancer-related anemia Pharmacotherapy 1998 Jan-Feb 18(1):156 69 9469689
Kouides PA, Bennett JM Understanding the myelodysplastic syndromes Oncologist 1997 2(6):389 401 10388074
Koury MJ, Bondurant MC Erythropoietin retards DNA breakdown and prevents programmed death in erythroid progenitor cells Science 1990 Apr 20 248(4953):378 81
Krantz SB Erythropoietin and the anaemia of chronic disease Nephrol Dial Transplant 1995 10(Suppl 2):10 7 7644100
Kumar M, Alter BP Hematopoietic growth factors for the treatment of aplastic anemia Curr Opin Hematol 1998 5(3):226 34 9664165
Kurata H, Yoshiya N, Higashino M, et al [Recombinant human erythropoietin in the treatment of the anemia of gynecological tumor patients] Gan To Kagaku Ryoho 1993 Nov 20(14):2243 5 8239694
Kurz C, Marth C, Windbichler G, et al Erythropoietin treatment under polychemotherapy in patients with gynecologic malignancies: A prospective, randomized, double-blind placebo-controlled multicenter study Gynecol Oncol 1997 Jun 65(3):461 6 9190976
Kurzrock R, Talpaz M, Estey E, et al Erythropoietin treatment in patients with myelodysplastic syndrome and anemia Leukemia 1991 Nov 5(11):985 90 1961041
Landis SH, Murray T, Bolden S, et al Cancer statistics, 1999 CA Cancer J Clin 1999 49(1):8 31 10200775
Langer CJ. Anaemia, fatigue and quality of life in advanced malignancy: Potential therapeutic role for epoetin. Erythropoiesis. 1997;8:63-73.
Laporte JP, Isnard F, Fenaux P, et al. Recombinant human erythropoietin at high dose is effective for the treatment of the anemia of myelodysplastic syndromes. Contrib Nephrol. 1991;88:271-2; discussion 273-5. [pmid: 2040189].
Larholt K M, Sampson A R Effects of heteroscedasticity upon certain analyses when regression lines are not parallel Biometrics 1995 Jun 51(2):731 7 7662854
Laupacis A, Sackett DL, Roberts RS An assessment of clinically useful measures of the consequences of treatment New Engl J Med 1988 318(26):1726 33
Laurencet F, Samii K, Beris P Myelodysplastic syndromes Med Hyg (Geneve) 1996 54(2116):939 45 265519
Lavey RS, Dempsey WH Erythropoietin increases hemoglobin in cancer patients during radiation therapy Int J Radiat Oncol Biol Phys 1993 Dec 1 27(5):1147 52
Lazarus HM, Goodnough LT, Goldwasser E, et al Serum erythropoietin levels and blood component therapy after autologous bone marrow transplantation: Implications for erythropoietin therapy in this setting Bone Marrow Transplant 1992 Jul 10(1):71 5 1515882
Lechner W, Artner-Dworzak E, Solder E, et al Influence on erythropoietin levels of treatment with cisplatinum-endoxan Arch Gynecol Obstet 1992 252(1):49 53 1417088
Lee GR. Anemia: A diagnostic strategy. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999a. Lee GR. Inherited and drug-induced megaloblastic anemia. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999b.
Lee GR. Iron deficiency and iron-deficiency anemia. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999c.
Lee WR, Berkey B, Marcial V, et al Anemia is associated with decreased survival and increased locoregional failure in patients with locally advanced head and neck carcinoma: A secondary analysis of RTOG 85-27 Int J Radiat Oncol Biol Phys 1998 42(5):1069 75 9869231
Leidy NK, Revicki DA, Geneste B Recommendations for evaluating the validity of quality of life claims for labeling and promotion Value Health 1999 2(3):113 27 16674343
Leitgeb C Quality of life and cytokines in oncologic therapy Wien Med Wochenschr 1998 148(18):424 6 9888178
Leitgeb C, Pecherstorfer M, Fritz E, et al Quality of life in chronic anemia of cancer during treatment with recombinant human erythropoietin Cancer 1994 May 15 73(10):2535 42
Leon Molinari P, Jimenez Monteagudo M, Barona Zamora P, et al [Recombinant human erythropoietin in anemia associated with pediatric cancer: Study of the identification of predictors of response] An Esp Pediatr 1998 Jul 49(1):17 22 9718761
Leon P, Jimenez M, Barona P, et al Recombinant human erythropoietin for the treatment of anemia in children with solid malignant tumors Med Pediatr Oncol 1998 30(2)110 16 9403020
Lesem CH, Blyler ML, Schroeder DJ, et al. Analysis of regimen selection and supportive care drug therapy in community based medical oncology practices for breast cancer patients. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Lieschke GJ, Foote M, Morstyn G. Hematopoietic growth factors in cancer chemotherapy. Cancer Chemother Biol Response Modif. 1997;17:363-89. [pmid: 9551221].
Lin F-K, Suggs S, Lin C-H, et al. Cloning and expression of the human erythropoietin gene. Proc Natl Acad Sci USA. 1985;82:7580-4. [pmcid: 391376]. [pmid: 3865178].
Link H, Boogaerts MA, Fauser AA, et al A controlled trial of recombinant human erythropoietin after bone marrow transplantation Blood 1994 Nov 15 84(10):3327 35
Link H, Brune T, Hubner G, et al Effect of recombinant human erythropoietin after allogenic bone marrow transplantation Ann Hematol 1993 Oct 67(4):169 73 8218537
Littlewood TJ, Bajetta E, Cella D, et al. For the European Epoetin Alfa Study Group. Efficacy and quality of life outcomes of epoetin alfa in a double-blind, placebo-controlled multicenter study of cancer patients receiving non-platinum containing chemotherapy. Proc Annu Meet Am Soc Clin Oncol. 1999;18. (Unpublished study; published as abstract and available as slides).
Locatelli F, Stefano PD, Pession A, et al Treatment of myelodysplastic syndromes in childhood Int J Pediatr Hematol Oncol 1996 3(2):95 104
Locatelli F, Zecca M, Beguin Y, et al Accelerated erythroid repopulation with no stem-cell competition effect in children treated with recombinant human erythropoietin after allogeneic bone marrow transplantation Br J Haematol 1993 Aug 84(4):752 4 8217839
Locatelli F, Zecca M, Pedrazzoli P, et al Use of recombinant human erythropoietin after bone marrow transplantation in pediatric patients with acute leukemia: Effect on erythroid repopulation in autologous versus allogeneic transplants Bone Marrow Transplant 1994 Apr 13(4):403 10 8019464
Locatelli F, Zecca M, Pession A, et al Myelodysplastic syndromes: The pediatric point of view Haematologica 1995 80(3):268 79 7672722
Locatelli F, Zecca M, Ponchio L, et al Pilot trial of combined administration of erythropoietin and granulocyte colony-stimulating factor to children undergoing allogeneic bone marrow transplantation Bone Marrow Transplant 1994 Dec 14(6):929 35 7536073
Locatelli M C, Tedeschi L, Clerici M, et al Cisplatin-associated anaemia in patients with solid tumours. A retrospective evaluation and considerations relative to erythropoietin administration Support Care Cancer 1996 May 4(3):218 9 8739656
Longo G, Fiorani C, Bonacorsi G, et al [Efficacy of erythropoietin in anemia of patients with immuno-lymphoproliferative disease] Recenti Prog Med 1992 Jul-Aug 83(7-8):449 54 1529159
Lowenthal RM, Marsden KA Myelodysplastic syndromes Int J Hematol 1997 Jun 65(4):319 38 9195773
Ludwig H. Epoetin in cancer-related anaemia. Nephrol Dial Transplant. 1999;14:85-92. [pmid: 10334673].
Ludwig H, Chott A, Fritz E, et al Increase of bone marrow cellularity during erythropoietin treatment in myeloma Stem Cells (Dayt) 1995 Aug 13(Suppl 2)77 87 86295
Ludwig H, Fritz E Anemia of cancer patients: Patient selection and patient stratification for epoetin treatment Semin Oncol 1998b Jun 25(3 Suppl 7):35 8
Ludwig H, Fritz EA Anemia in cancer patients Semin Oncol 1998a Jun 25(3 Suppl 7):2 6
Ludwig H, Fritz E, Kotzmann H, et al [Erythropoietin treatment of tumor-associated anemia in patients with multiple myeloma] Onkologie 1990 Feb 13(1):46 9 2186325
Ludwig H, Fritz E, Kotzmann H, et al Erythropoietin treatment of anemia associated with multiple myeloma N Engl J Med 1990 Jun 14 322(24):1693 9
Ludwig H, Fritz E, Leitgeb C, et al Erythropoietin treatment for chronic anemia of selected hematological malignancies and solid tumors Ann Oncol 1993 Feb 4(2):161 7 8448084
Ludwig H, Fritz E, Leitgeb C, et al Prediction of response to erythropoietin treatment in chronic anemia of cancer Blood 1994 Aug 15 84(4):1056 63
Ludwig H, Leitgeb C, Fritz E, et al Erythropoietin treatment of chronic anaemia of cancer Eur J Cancer 1993 29(A Suppl 2):S8 S12
Ludwig H, Pecherstorfer M, Leitgeb C, et al Recombinant human erythropoietin for the treatment of chronic anemia in multiple myeloma and squamous cell carcinoma Stem Cells (Dayt) 1993 Sep 11(5):348 55 86295 8241947
Ludwig H, Sundal E, Pecherstorfer M, et al Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy Cancer 1995 Dec 1 76(11):2319 29
Lumadue JA, Ness PM Current approaches to red blood cell transfusion Semin Hematol 1996 Oct 33(4):277 89 8916302
Lydick E, Epstein RS Interpretation of quality of life changes Qual Life Res 1993 Jun 2(3):221 6 8401458
MacDougall IC Poor response to erythropoietin should be fully investigated and treated Br Med J 1995 310(6992):1424 5 7613268
Macdougall IC Quality of life and anemia: The nephrology experience Semin Oncol 1998 Jun 25(3 Suppl 7):39 42 9671329
MacMillan ML, Freedman MH Recombinant human erythropoietin in children with cancer J Pediatr Hematol Oncol 1998 May-Jun 20(3):187 9 9628427
Mansouri A, Lipschitz DA Myelodysplastic syndromes in the elderly J Am Geriatr Soc 1992 40(4):386 91 1556367
Mantovani G, Ghiani M, Curreli L, et al Assessment of the efficacy of two dosages and schedules of human recombinant erythropoietin in the prevention and correction of cisplatin-induced anemia in cancer patients Oncol Rep 1999 6(2):421 6 10023014
Maraveyas A, Pettengell R What is the role of erythropoietin in patients with solid tumours? Ann Oncol 1998 Mar 9(3):239 41 9602254
Markham A, Bryson HM Epoetin alfa. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic use in nonrenal applications Drugs 1995 Feb 49(2):232 54 7729331
Markman M, Reichman B, Hakes T, et al The use of recombinant human erythropoietin to prevent carboplatin-induced anemia Gynecol Oncol 1993 May 49(2):172 6 8504984
Marmont AM Selective metaphasic blockade of erythroblasts in the bone marrow of patients treated sequentially with recombinant human erythropoietin and vincristine Haematologica 1991 May-Jun 76(3):251 5 1743598
McEvoy GK, editor. Epoetin alfa. In: AHFS drug information 1999. Bethesda: American Society of Health-System Pharmacists; 1999.
McPeek B, Gilbert JP, Mosteller F Sounding Boards. The clinician's responsibility for helping to improve the treatment of tomorrow's patients N Engl J Med 1980;13 302(11):630 1
Meadowcroft AM, Gilbert CJ, Maravich-May D, et al. Cost of managing anemia with and without prophylactic epoetin therapy in breast cancer patients receiving combination chemotherapy. Am J Health-Syst Pharm. 1998;55:1898-902. [pmid: 9784769].
Means RT Jr. The anemia of chronic disorders. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999.
Means RT Jr Commentary: An anemia of chronic disease, after all? J Investig Med 1999 47(5):
Means RT Jr Erythropoietin in the treatment of anemia in chronic infectious, inflammatory, and malignant diseases Curr Opin Hematol 1995 May 2(3):210 3 9371997
Mercuriali F [The role of human recombinant erythropoietin in oncologic surgery] Tumori 1997 Jul-Aug 83(4 Suppl 2):S16 S19 9487379
Mertelsmann R Case history. 1: The use of epoetin alfa in delayed anaemia Ann Oncol 1997 8(Suppl 3):S11 S12 9341960
Mertelsmann R Case history. 2: The use of epoetin alfa before high-dose chemotherapy Ann Oncol 1997 8(Suppl 3):
Mertelsmann R, Zenz M Foreword Ann Oncol 1997 8(Suppl 3):
Miaskowski C, Portenoy RK Update on the assessment and management of cancer-related fatigue Principles Pract Support Oncol Updates 1998 1(2):1 10
Miller CB, Jones RJ, Piantadosi S, et al Decreased erythropoietin response in patients with the anemia of cancer N Engl J Med 1990 Jun 14 322(24):1689 92
Miller CB, Platanias LC, Mills SR, et al Phase I-II trial of erythropoietin in the treatment of cisplatin-associated anemia J Natl Cancer Inst 1992 84(2):98 103 1735886
Miller K Erythropoietin, with and without granulocyte-colony stimulating factor (G-CSF), in the treatment of myelodysplastic syndrome (MDS) patients Leuk Res 1998 May 22(Suppl 1):S13 S16 9734694
Mittelman M Anemia of cancer: Pathogenesis and treatment with recombinant erythropoietin Isr J Med Sci 1996 Dec 32(12):1201 6 9007154
Mittelman M Recombinant erythropoietin in myelodysplastic syndromes: Whom to treat and how? More questions than answers Acta Haematol 1993 90(2):53 7 8285018
Mittelman M, Floru S, Djaldetti M, et al Subcutaneous erythropoietin for treatment of refractory anemia in hematologic disorders (1) Blood 1992 80(3):841 3 1638033
Mittelman M, Zeidman A, Fradin Z, et al Recombinant human erythropoietin in the treatment of multiple myeloma-associated anemia Acta Haematol 1997 98(4):204 10 9401498
Mitus AJ, Antin JH, Rutherford CJ, et al Use of recombinant human erythropoietin in allogeneic bone marrow transplant donor/recipient pairs Blood 1994 Apr 1 83(7):1952 7
Mohandas K, Aledort L Transfusion requirements, risks, and costs for patients with malignancy Transfusion 1995 May 35(5):427 30 7740615
Moher D, Pham B, Jones A, et al Does quality of reports of randomized controlled trials affect estimates of intervention efficacy reported in meta-analyses? Lancet 1998 Aug 22 352(9128):609 13
Mohr B, Herrmann R, Huhn D Recombinant human erythropoietin in patients with myelodysplastic syndrome and myelofibrosis Acta Haematol 1993 90(2):65 70 8285020
Molica S Erythropoietin treatment of anaemia associated with lymphoproliferative disorders Eur J Cancer 1993 29A(10):1499 500 8398286
Moliterno AR, Spivak JL Anemia of cancer Hematol Oncol Clin North Am 1996 Apr 10(2):345 63 8707759
Monga U, Jaweed M, Kerrigan AJ, et al Neuromuscular fatigue in prostate cancer patients undergoing radiation therapy Arch Phys Med Rehabil 1997 Sep 78(9):961 6 9305269
Monti M, Castellani L, Berlusconi A, et al Use of red blood cell transfusions in terminally ill cancer patients admitted to a palliative care unit J Pain Symptom Manage 1996 Jul 12(1):18 22 8718912
Morere JF, Bouillet T, Piperno-Neumann S, et al [Treatment of advanced kidney cancer using recombinant erythropoietin] Prog Urol 1997 Jun 7(3):399 402 9273066
Moscinski LC Laboratory and bone marrow evaluation in patients with cancer Cancer Control 1998 5(2 Suppl):12 16 10762461
Mulrow CD, Oxman AD, editors. Cochrane collaboration handbook. Available in the Cochrane Library [database on disk and CD-ROM]. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
Musto P The role of recombinant erythropoietin for the treatment of anemia in multiple myeloma Leuk Lymphoma 1998 Apr 29(3-4):283 91 9684926
Musto P, Catalano L, Andriani A, et al Recombinant erythropoietin for refractory anemia with ring sideroblasts Haematologica 1992 Mar-Apr 77(2):185 6 1398306
Musto P, Falcone A, Carotenuto M, et al Granulocyte colony-stimulating factor and erythropoietin for the anemia of myelodysplastic syndromes: A real improvement with respect to erythropoietin alone? Blood 1994 Sep 1 84(5):1687 8
Musto P, Falcone A, D'Arena G, et al Clinical results of recombinant erythropoietin in transfusion-dependent patients with refractory multiple myeloma: Role of cytokines and monitoring of erythropoiesis Eur J Haematol 1997 May 58(5):314 9 9222286
Musto P, Matera R, Minervini MM, et al Low serum levels of tumor necrosis factor and interleukin-1 beta in myelodysplastic syndromes responsive to recombinant erythropoietin Haematologica 1994 May-Jun 79(3):265 8 7926977
Musto P, Modoni S, Alicino G, et al Modifications of erythropoiesis in myelodysplastic syndromes treated with recombinant erythropoietin as evaluated by soluble transferrin receptor, high fluorescence reticulocytes and hypochromic erythrocytes Haematologica 1994 79(6):493 9 7896207
Musto P, Scalzulli PR, Carotenuto M Recombinant erythropoietin for myelodysplastic syndromes Br J Haematol 1995 Sep 91(1):256 8 7577647
Nagashima M Effect of recombinant human erythropoietin (rhepo) on the anemia with refractory hematological disorders J Saitama Med School 1989 16(3):293 300
Nagura H, Yamanouchi H Cerebral infarctions in elderly patients with anemia Jpn J Geriat 1992 29(12):918 21
Nail LM, Winningham ML. Fatigue and weakness in cancer patients: The symptom experience. Semin Oncol Nurs. 1995;11:272-8. [pmid: 8578035].
Nand S, Stock W Management of myelodysplastic syndromes Cancer J 1996 9(5):229 35
Nand S, Stock W Treatment of primary myelodysplastic syndromes Int J Pediatr Hematol Oncol 1997 4(3):239 53
Negrin RS, Stein R, Doherty K, et al Maintenance treatment of the anemia of myelodysplastic syndromes with recombinant human granulocyte colony-stimulating factor and erythropoietin: Evidence for in vivo synergy Blood 1996 May 15 87(10):4076 81
Negrin RS, Stein R, Vardiman J, et al Treatment of the anemia of myelodysplastic syndromes using recombinant human granulocyte colony-stimulating factor in combination with erythropoietin Blood 1993 Aug 1 82(3):737 43
Nicholls AJ. Enhanced quality of life in dialysis patients treated with erythropoietin: Are the benefits worth the cost?. Erythropoiesis. 1992;3:46-9.
Nielsen O J, Brandt M, Drivsholm A The secretory erythropoietin response in patients with multiple myeloma and Waldenstrom's macroglobulinaemia Scand J Clin Lab Invest 1990 Nov 50(7):697 703 2127316
Nowrousian MR Recombinant human erythropoietin (RhEPO) in the prevention and treatment of chemotherapy-induced anaemia Med Oncol 1998 15(3):141 4 9819790
Nowrousian MR Recombinant human erythropoietin in the treatment of cancer-related or chemotherapy-induced anaemia in patients with solid tumours Med Oncol 1998 15(Suppl 1):S19 S28 9785333
Oberhoff C, Neri B, Amadori D, et al Recombinant human erythropoietin in the treatment of chemotherapy-induced anemia and prevention of transfusion requirement associated with solid tumors: A randomized, controlled study Ann Oncol 1998 Mar 9(3):255 60 9602258
O'Brien MER, Casey S, Treleaven J, et al Use of erythropoietin in the management of the haemolytic uraemic syndrome induced by mitomycin c/tamoxifen (7) Eur J Cancer 1994 30(6):894 5
Ogawa K, Egawa M, Hirota J, et al [Preoperative autologous blood donation in patients with malignant tumors of the head and neck region] Nippon Jibiinkoka Gakkai Kaiho 1996 Feb 99(2):286 91 8851333
Ohl S Diagnosis and therapy of anemias in geriatric patients Onkologe 1998 4(1):30 5
Okamoto H, Saijo N, Shinkai T, et al Chemotherapy-induced anemia in patients with primary lung cancer Ann Oncol 1992 3(10):819 24 1286044
Oken MM Management of myeloma: Current and future approaches Cancer Control 1998 5(3):218 25 10761055
Olujohungbe A, Handa S, Holmes J Does erythropoietin accelerate malignant transformation in multiple myeloma? Postgrad Med J 1997 Mar 73(857):163 4 9135833
Onat H, Inanc S E, Dalay N, et al Effect of cisplatin on erythropoietin and iron changes Eur J Cancer 1993 29A(5):
Orhan B, Yalcin S. What are cancer patients willing to pay for prophylactic epoetin alfa? A cost benefit analysis. Cancer. 1999;86:1095-6. [pmid: 10491539].
Orhan B, Yalcin S, Evrensel T, et al Does cisplatin stimulate erythropoietin secretion from the peritubular cells of the kidney? [6] Clin Nephrol 1998 50(3):202 3 9776431
Ortega A, Dranitsaris G, Puodziunas AL What are cancer patients willing to pay for prophylactic epoetin alfa? A cost-benefit analysis Cancer 1998 Dec 15 83(12):2588 96
Ortega A, Dranitsaris G, Puodziunas A A clinical and economic evaluation of red blood cell transfusions in patients receiving cancer chemotherapy Int J Technol Assess Health Care 1998 Fall 14(4):788 98 9885467
Ortho Biotech, Inc., Procrit® (epoetin alfa) prescribing information. In: Physicians' desk reference. 53rd ed. Montvale: Medical Economics Press; 1999.
Ossenkoppele GJ Treatment of multiple myeloma in elderly patients. New developments Drugs Aging 1997 Aug 11(2):152 64 9259178
Oster W, Herrmann F, Gamm H, et al Erythropoietin for the treatment of anemia of malignancy associated with neoplastic bone marrow infiltration J Clin Oncol 1990 Jun 8(6):956 62 2189957
Osterborg A, Boogaerts MA, Cimino R, et al Recombinant human erythropoietin in transfusion-dependent anemic patients with multiple myeloma and non-Hodgkin's lymphoma -- a randomized multicenter study. The European Study Group of Erythropoietin (Epoetin Beta) Treatment in Multiple Myeloma and Non-Hodgkin's Lymphoma Blood 1996 Apr 1 87(7):2675 82
Ozsoylu S Anemia and transfusion Am J Hematol 1994 May 46(1):
Paganini EP, Eschbach JW, Lazarus JM, et al Intravenous versus subcutaneous dosing of epoetin alfa in hemodialysis patients Am J Kidney Dis 1995 Aug 26(2):331 40 7645538
Pangalis GA, Poziopoulos C, Angelopoulou MK, et al Effective treatment of disease-related anaemia in B-chronic lymphocytic leukaemia patients with recombinant human erythropoietin Br J Haematol 1995 Mar 89(3):627 9 7734364
Parkinson DR Introduction Semin Hematol 1997 34(3 Suppl 3):1 3 9025156
Pavel JN Red blood cell transfusions for anemia Semin Oncol Nurs 1990 May 6(2):117 22 2343208
Pawlicki M, Jassem J, Bosze P, et al A multicenter study of recombinant human erythropoietin (epoetin alpha) in the management of anemia in cancer patients receiving chemotherapy Anticancer Drugs 1997 Nov 8(10):949 57 9436638
Pawlicki M, Jassem J, Zborzil J, et al The use of recombinant human erythropoietin in the treatment of cancer patients with chemotherapy induced anemia Nowotwory 1994 44(4):291 7
Pedrazzini A Erythropoietin and GM-CSF following autologous bone marrow transplantation Eur J Cancer 1993 29(Suppl 2):S15 S17 8398360
Pene R, Appelbaum F R, Fisher L, et al Use of granulocyte-macrophage colony-stimulating factor and erythropoietin in combination after autologous marrow transplantation Bone Marrow Transplant 1993 Mar 11(3):219 22 8467286
Pico JL, Castagna L, Bourhis JH Recent progress in the biology of multiple myeloma and future directions in the treatment Hematol Cell Ther 1998 40(2):45 61 9615247
Piedras J, Hernandez G, Lopez-Karpovitch X Effect of androgen therapy and anemia on serum erythropoietin levels in patients with aplastic anemia and myelodysplastic syndromes Am J Hematol 1998 Feb 57(2):113 8 9462542
Pierelli L, Menichella G, Foddai ML, et al The administration of growth factors post-PBPC transplantation abrogates the dose-effect of CFU-GM on the rate of PMN recovery (1) Bone Marrow Transplant 1996 17(6):1189 90 8807136
Pierelli L, Menichella G, Scambia G, et al Growth factor administration following autologous peripheral blood progenitor cell transplantation Leuk Lymphoma 1997 27(1-2):65 75 9373197
Pierelli L, Perillo A, Greggi S, et al Erythropoietin addition to granulocyte colony-stimulating factor abrogates life-threatening neutropenia and increases peripheral-blood progenitor-cell mobilization after epirubicin, paclitaxel, and cisplatin combination chemotherapy: Results of a randomized comparison J Clin Oncol 1999 17(4):1288 95 10561191
Pierelli L, Scambia G, Menichella G, et al The combination of erythropoietin and granulocyte colony-stimulating factor increases the rate of haemopoietic recovery with clinical benefit after peripheral blood progenitor cell transplantation Br J Haematol 1996 Feb 92(2):287 94 8602987
Pieroni L, Foglietti MJ, Andreux JP, et al Factors involved in the anaemia of chronic disorders in elderly patients Gerontology 1997 43(6):326 34 9386984
Pincus T, Olsen NJ, Russell IJ, et al Multicenter study of recombinant human erythropoietin in correction of anemia in rheumatoid arthritis Am J Med 1990 Aug 89(2):161 8 2200263
Platanias LC, Miller CB, Mick R, et al Treatment of chemotherapy-induced anemia with recombinant human erythropoietin in cancer patients J Clin Oncol 1991 9(11):2021 6 1941061
Pohl C, Moter A, Hasenclever D, et al Inappropriate increase in plasma erythropoietin levels following PEB chemotherapy Onkologie 1992 15(5):384 9
Pohl C, Schobert I, Moter A, et al Serum erythropoietin levels in patients with Hodgkin's lymphoma at the time of diagnosis Ann Oncol 1992 Feb 3(2):172 3 1606092
Poisson D Eprex: History and development Nouv Rev Fr Hematol 1995 37(Suppl 1):S1 S3 7478979
Ponchio L, Beguin Y, Farina G, et al Analysis of factors predicting response to recombinant human erythropoietin in nonrenal anaemia Leuk Lymphoma 1992a 7(Suppl 2):
Ponchio L, Beguin Y, Farina G, et al Evaluation of erythroid marrow response to recombinant human erythropoietin in patients with cancer anaemia Haematologica 1992b Nov-Dec 77(6):494 501 1289186
Portenoy RK, Itri LM. Cancer-related fatigue: Guidelines for evaluation and management. Oncologist. 1999;4:1-10. [pmid: 10337366].
Portenoy RK, Thaler HT, Kornblith AB, et al Symptom prevalence, characteristics and distress in a cancer population Qual Life Res 1994 Jun 3(3):183 9 7920492
Porter JC, Leahey A, Polise K, et al Recombinant human erythropoietin reduces the need for erythrocyte and platelet transfusions in pediatric patients with sarcoma: A randomized, double-blind, placebo-controlled trial J Pediatr 1996 Nov 129(5):656 60 8917229
Poskitt TR Radiation therapy and the role of red blood cell transfusion Cancer Invest 1987 5(3):231 6 3651866
Price FV, Kelley JL, Edwards RP, et al A survey of blood transfusion practices of gynecologic oncologists Gynecol Oncol 1995 59(1):45 50 7557614
Provan D Myelodysplastic syndromes Prescribers' J 1997 37(1):17 23
Qiao ZH [Erythropoietin treatment of anemia associated with multiple myeloma (MM) and myelodysplastic syndrome (MDS)] Chung Hua Chung Liu Tsa Chih 1993 Mar 15(2):122 4 8223121
Quirt I, Couture F, Pichette R, et al The role of recombinant human erythropoietin (EPO) in reducing red blood cell transfusions and maintaining quality of life (QOL) in patients with lymphoma and solid tumors receiving cytotoxic chemotherapy. Results of a randomized, double-blind, placebo-controlled clinical trial Blood 1996 88(10 Suppl 1):
Quirt I, Micucci S, Moran LA, et al Erythropoietin in the management of patients with nonhematologic cancer receiving chemotherapy. Systemic Treatment Program Committee Cancer Prev Control 1997 Aug 1(3):241 8 9765749
Rabinowitz J, Petros WP, Stuart AR, et al Characterization of endogenous cytokine concentrations after high-dose chemotherapy with autologous bone marrow support Blood 1993 May 1 81(9):2452 9
Rafanelli D, Grossi A, Longo G, et al Recombinant human erythropoietin for treatment of myelodysplastic syndromes Leukemia 1992 Apr 6(4):323 7 1588794
Rappeport JM, Bunn HF. Bone marrow failure: Aplastic anemia and other primary bone marrow disorders. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13th ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994. p. 1754-7.
Raza A, Vadhan-Raj S, Chavez-Sanchez G [Myelodysplastic syndromes] Rev Invest Clin 1997 May 49(Suppl 1):15 21
Razzano M, Caslini C, Cortelazzo S, et al Clinical and biological effects of erythropoietin treatment of myelodysplastic syndrome Leuk Lymphoma 1993 May 10(1-2):127 34 8374520
Razzano M, Caslini C, Cortelazzo S, et al Therapy with human recombinant erythropoietin in patients with myelodysplastic syndromes Br J Haematol 1992 Aug 81(4):628 30 1390262
Reed WR, Hussey DH, DeGowin RL Implications of the anemia of chronic disorders in patients anticipating radiotherapy Am J Med Sci 1994 Jul 308(1):9 15 8010342
Reman O, Boutard P, Cheze S, et al Myelodysplastic syndrome in childhood Br J Haematol 1996 Oct 95(1):212 3 8857963
Rodman JH, Relling MV, Stewart CF, et al Clinical pharmacokinetics and pharmacodynamics of anticancer drugs in children Semin Oncol 1993 20(1):18 29
Rodriguez JN, Dieguez JC, Muniz R, et al [Human recombinant erythropoietin in the treatment of myelodysplastic syndromes anemia. Meta-analytic study] Sangre (Barc) 1994 Dec 39(6):435 9 80602 7855695
Rodriguez JN, Dieguez JC, Prados D Erythropoietin in the myelodysplastic syndromes: Meta-analytical study Br J Haematol 1995 Sep 91(1):
Roeb E, Rose-John S Cytokines: Biology and therapeutic relevance Dtsch Med Wochenschr 1996 121(24):803 9 8654216
Rogers S, Russell NH, Morgan AG Effect of erythropoietin in patients with myeloma Br Med J 1990 Sep 29 301(6753):
Rose EH, Abels RI, Nelson RA, et al The use of r-HuEpo in the treatment of anaemia related to myelodysplasia (MDS) Br J Haematol 1995 Apr 89(4):831 7 7772519
Rose E, Rai K, Revicki D, et al Clinical and health status assessments in anemic chronic lymphocytic leukemia (CLL) patients treated with epoetin alfa (EPO) Blood 1994 84(10 Suppl 1):
Rosenthal DI, Sinard RJ, Okani O, et al Seven-week continuous-infusion paclitaxel with concurrent radiotherapy for locally advanced head and neck squamous cell cancer: A phase I study Semin Oncol 1997 Dec 24(6 Suppl 19):S19 S67 to S19-S71
Rosse W, Bunn HF. Hemolytic anemias. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13th ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994. p. 1743-54.
Rosso R, Del Mastro L, Venturini M, et al [Use of erythropoietin in oncology] Tumori 1997 Jul-Aug 83(4 Suppl 2):S26 S30
Roth A, Kolaric K The effect of subcutaneous recombinant human erythropoietin (r-hu-epo)in patients with malignancies and anemia secondary to chemotherapy Libri Oncologici 1995 24(3):137 41
Royer B, Arock M [Therapeutic use of hematopoietic growth factors. I. Erythropoietin and thrombopoietin] Ann Biol Clin (Paris) 1998 Mar-Apr 56(2):143 52 9754239
Rubins J Metastatic renal cell carcinoma: Response to treatment with human recombinant erythropoietin Ann Intern Med 1995 122(9):676 7 7702229
Ruedin P Ten-year of experience with human recombinant erythropoietin Med Hyg (Geneve) 1995 53(2060):405 8 265519
Runde V, Aul C, Ebert A, et al Sequential administration of recombinant human granulocyte-macrophage colony-stimulating factor and human erythropoietin for treatment of myelodysplastic syndromes Eur J Haematol 1995 Jan 54(1):39 45 7859874
Rusthoven JJ Clinical needs for hematopoietic growth factors: Old and new Cancer Invest 1996 14(6):622 34 8951365
Rytting M, Worth L, Jaffe N Hemolytic disorders associated with cancer Hematol Oncol Clin North Am 1996 10(2):365 76 8707760
Saba HI Anemia in cancer patients: Introduction and overview Cancer Control 1998 5(2 Suppl):3 5
Saba HI Myelodysplastic syndromes in the elderly: The role of growth factors in management Leuk Res 1996 Mar 20(3):203 19 8637215
Sadahiro S, Suzuki T, Tokunaga N, et al Anemia in patients with colorectal cancer J Gastroenterol 1998 33(4):488 94 9719230
Saijo Y, Nakai Y, Saito J, et al Changes in serum erythropoietin levels during chemotherapy for lung cancer Chemotherapy 1992 38(5):281 5 1286570
Salive ME, Cornoni-Huntley J, Guralnik JM, et al Anemia and hemoglobin levels in older persons: Relationship with age, gender, and health status J Am Geriatr Soc 1992 40(5):489 96 1634703
Salvarani C, Lasagni D, Casali B, et al Recombinant human erythropoietin therapy in patients with rheumatoid arthritis with the anemia of chronic disease J Rheumatol 1991 Aug 18(8):1168 71 1941817
San Miguel JF, Sanz GF, Vallespi T, et al Myelodysplastic syndromes Crit Rev Oncol Hematol 1996 23(1):57 93 8817082
Sanz GF, Sanz MA, Vallespi T Etiopathogeny, prognosis and therapy of myelodysplastic syndromes Hematol Cell Ther 1997 39(6):277 94 9497887
Sasai K, Ono K, Hiraoka M, et al The effect of arterial oxygen content on the results of radiation therapy for epidermoid bronchogenic carcinoma Int J Radiat Oncol Biol Phys 1989 16(6):1477 81 2722590
Sawabe Y, Iida S, Tabata Y, et al Serum erythropoietin measurements by a one-step sandwich enzyme linked immunosorbent assay in patients with hepatocellular carcinoma and liver cirrhosis Jpn J Clin Oncol 1993 Oct 23(5):273 7 7693989
Sawabe Y, Kikuno K, Iseki T, et al Serum erythropoietin values and serum iron status during chemotherapy for leukemia Eur J Haematol 1998 May 60(5):315 6 9654163
Sawabe Y, Takiguchi Y, Kikuno K, et al Changes in levels of serum erythropoietin, serum iron and unsaturated iron binding capacity during chemotherapy for lung cancer Jpn J Clin Oncol 1998 Mar 28(3):182 6 9614440
Schapira L, Antin JH, Ransil BJ, et al Serum erythropoietin levels in patients receiving intensive chemotherapy and radiotherapy Blood 1990 Dec 1 76(11):2354 9
Schmitz N, Bacigalupo A, Labopin M, et al Transplantation of allogeneic peripheral blood progenitor cells -- the EBMT experience Bone Marrow Transplant 1996 Mar 17(Suppl 2):S40 S46 8722334
Schneider JG Hematopoietic growth factors: Rationale and use in gynecologic oncology Principles Pract Gynecol Oncol Updates 1993 1(5):1 12
Schouten HC, Vellenga E, van Rhenen DJ, et al Recombinant human erythropoietin in patients with myelodysplastic syndromes Leukemia 1991 May 5(5):432 6 2033964
Schroeder ML. Principles and practice of transfusion medicine. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999.
Schulz KF, Chalmers I, Hayes RJ, et al Empirical evidence of bias: Dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 273(5):408 12 7823387
Seipelt G, Hoelzer D Cytokine interaction -- possible applications Forum-Trends Exp Clin Med 1995 5(3):226 32
Sevelda P, Kurz C, Marth C, et al. Prospective randomized placebo controlled trial of erythropoietin (Erypo) in patients with chronic tumor anemia and gynecological cancer. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Sheffield RE, Sullivan SD, Saltiel E, et al. Cost comparison of recombinant human erythropoietin and blood transfusion in cancer chemotherapy-induced anemia. Ann Pharmacother. 1997;31:15-22. [pmid: 8997459].
Shepherd JD, Currie CJ, Sparling TG, et al Erythropoietin therapy of myelodysplastic syndromes Blood 1992 Apr 1 79(7):1891 2
Shimamoto Y, Matsuzaki M, Yamaguchi M Effective treatment of the anaemia associated with multiple myeloma by recombinant human erythropoietin Clin Lab Haematol 1991 13(3):311 3 1794234
Shimizu Y, Umezawa S, Takeshima N, et al [Efficacy of 24,000 U of erythropoietin in the treatment of chemotherapy-induced anemia] Gan To Kagaku Ryoho 1994 Aug 21(10):1701 3 8060150
Silvestris F, Romito A, Fanelli P, et al Long-term therapy with recombinant human erythropoietin (rHu-EPO) in progressing multiple myeloma Ann Hematol 1995 Jun 70(6):313 8 7632811
Silvestris F, Savino L, Tucci M, et al Immunomodulation of T and B cell functions in multiple myeloma patients treated with combined erythropoietin and alpha-interferon therapy Int J Clin Lab Res 1995 25(2):79 83 7663009
Simon T L, Alverson D C, AuBuchon J, et al Practice parameter for the use of red blood cell transfusions: Developed by the Red Blood Cell Administration Practice Guideline Development Task Force of the College of American Pathologists Arch Pathol Lab Med 1998 Feb 122(2):130 8 9499355
Singhal S, Mehta J, Barlogie B Advances in the treatment of multiple myeloma Curr Opin Hematol 1997 Jul 4(4):291 7 9260058
Skillings JR, Sridhar FG, Wong C, et al The frequency of red cell transfusion for anemia in patients receiving chemotherapy. A retrospective cohort study Am J Clin Oncol 1993 Feb 16(1):22 5 8424398
Smigel K Non-toxic drug being tested to treat cancer and anemias J Natl Cancer Inst 1992 Sep 16 84(18):
Smith DA, Perry PJ The efficacy of ergogenic agents in athletic competition, part II: Other performance-enhancing agents Ann Pharmacother 1992 26(5):653 9 1591427
Smith DH, Goldwasser E, Vokes EE Serum immunoerythropoietin levels in patients with cancer receiving cisplatin-based chemotherapy Cancer 1991 Sep 1 68(5):1101 5
Sosman JA, Aronson FR, Sznol M, et al Concurrent phase I trials of intravenous interleukin 6 in solid tumor patients: Reversible dose-limiting neurological toxicity Clin Cancer Res 1997 Jan 3(1):39 46 9815535
Spaeth D, Marchal C, Blanc-Vincent M-P Standards, options and recommendations (SOR) for the clinical use of erythropoietin in oncology Bull Cancer (Paris) 1998 85(4):337 46 9752298
Spicka I, Svara F, Novosadova L, et al [Effect of treatment with recombinant erythropoietin in patients with multiple myeloma and kidney failure] Sb Lek 1997 98(2):127 33 9601805
Spivak JL Cancer-related anemia: Its causes and characteristics Semin Oncol 1994 Apr 21(2 Suppl 3):3 8 8202724
Spivak JL Recombinant human erythropoietin and the anemia of cancer Blood 1994 Aug 15 84(4):997 1004 8049455
Spivak JL Serum immunoreactive erythropoietin in health and disease J Perinat Med 1995 23(1-2):13 7 7658313
Spivak JL The application of recombinant erythropoietin in anemic patients with cancer Semin Oncol 1992 Jun 19(3 Suppl 8):25 8 1615336
Spivak JL The biology and clinical applications of recombinant erythropoietin Semin Oncol 1998 Jun 25(3 Suppl 7):7 11 9671323
Spivak JL The physiologic basis for the pharmacologic use of recombinant erythropoietin Cancer Control 1998 5(2 Suppl):22 5 10762463
Spivak JL, Pham T, Isaacs M, et al Erythropoietin is both a mitogen and a survival factor Blood 1991 Mar 15 77(6):1228 33
Sridharan GV, Scorgie R Myelodysplastic syndrome in the elderly: An underdiagnosed condition? J Clin Exp Gerontol 1991 13(4):221 31
Stasi R, Brunetti M, Bussa S, et al Response to recombinant human erythropoietin in patients with myelodysplastic syndromes Clin Cancer Res 1997 3(5):733 9 9815743
Stasi R, Brunetti M, Bussa S, et al Serum levels of tumour necrosis factor-alpha predict response to recombinant human erythropoietin in patients with myelodysplastic syndrome Clin Lab Haematol 1997 Sep 19(3):197 201 9352145
Stasi R, Pagano A, Terzoli E, et al Recombinant human granulocyte-macrophage colony-stimulating factor plus erythropoietin for the treatment of cytopenias in patients with myelodysplastic syndromes Br J Haematol 1999 105(1):141 8 10233377
Steegmann JL, Lopez J, Otero MJ, et al Erythropoietin treatment in allogeneic BMT accelerates erythroid reconstitution: Results of a prospective controlled randomized trial Bone Marrow Transplant 1992 Dec 10(6):541 6 1490203
Stein RS, Abels RI, Krantz SB Pharmacologic doses of recombinant human erythropoietin in the treatment of myelodysplastic syndromes Blood 1991 Oct 1 78(7):1658 63
Stenke L, Wallvik J, Celsing F, et al Prediction of response to treatment with human recombinant erythropoietin in myelodysplastic syndromes Leukemia 1993 Sep 7(9):1324 7 8371582
Stephens MK, Stevenson MM, Taylor MB, et al Guidelines for the use of blood transfusions W V Med J 1995 Jul-Aug 91(5):193 5 7660653
Stewart FM. Cytokines in stem cell transplantation. Ann NY Acad Sci. 1995;770:53-69. [pmid: 8597382].
Stone P, Hardy J, Broadley K, et al Fatigue in advanced cancer: A prospective controlled cross-sectional study Br J Cancer 1999 79(9-10):1479 86 10188894
Stone RM, Bernstein SH, Demetri G, et al Therapy with recombinant human erythropoietin in patients with myelodysplastic syndromes Leuk Res 1994 Oct 18(10):769 76 7934135
Strum SB, McDermed JE, Scholz MC, et al Anaemia associated with androgen deprivation in patients with prostate cancer receiving combined hormone blockade Br J Urol 1997 Jun 79(6):933 41 9202563
Sudhoff T, Aul C, Kretschmer S, et al [Severe anemia requiring transfusion in the early stage of low-grade malignant non-Hodgkin's lymphoma] Internist (Berl) 1994 May 35(5):476 9 152703 8021117
Sutton L Myelodysplastic syndromes Hematologie 1997 3(2 Suppl):46 8
Suzuki M, Tsutsui M, Yokoyama A, et al Normalization of hematocrit with recombinant human erythropoietin in chronic hemodialysis patients does not fully improve their exercise tolerance abilities Artif Organs 1995 Dec 19(12):1258 61 8967885
Svara F, Spicka I, Sulkova S, et al Erythropoietin (r-HuEPO) for the treatment of anaemia in patients with multiple myeloma and end-stage renal failure Nephrol Dial Transplant 1995 Dec 10(12):2374 5
Sweeney PJ, Nicolae D, Ignacio L, et al Effect of subcutaneous recombinant human erythropoietin in cancer patients receiving radiotherapy: Final report of a randomized, open-labelled, phase II trial Br J Cancer 1998 Jun 77(11):1996 2002 9667681
Tamary H, Danon YL Recombinant human erythropoietin in children with cancer Pediatr Hematol Oncol 1996 Jul-Aug 13(4):305 8 8837134
Taniguchi S, Yamasaki K, Shibuya T, et al Recombinant human erythropoietin for long-term persistent anemia after major ABO-incompatible bone marrow transplantation Bone Marrow Transplant 1993 Oct 12(4):
Taylor J, Mactier RA, Stewart WK, et al Effect of erythropoietin on anaemia in patients with myeloma receiving haemodialysis Br Med J 1990 Sep 8 301(6750):476 7
ten Bokkel Huinink WW, Dercksen MW, van Tinteren H Further studies to ameliorate toxicity of carboplatin Semin Oncol 1994 Apr 21(2 Suppl 2):27 33;quiz 34, 58 8202718
ten Bokkel Huinink WW, de Swart CAM, van Toorn DW, et al Controlled multicentre study of the influence of subcutaneous recombinant human erythropoietin on anaemia and transfusion dependency in patients with ovarian carcinoma treated with platinum-based chemotherapy Med Oncol 1998 15(3):174 82 9819794
ten Bokkel Huinink WW, van Tinteren H, Valkenet L, et al. Treatment of platinum induced anemia in ovarian cancer patients: A controlled study with erythropoietin to prevent anemia and blood transfusions. Ann Oncol. 1994;5.
Tesarova P, Kvasnicka J [Treatment of anemia in patients with tumors] Cas Lek Cesk 1995 Oct 18 134(20):647 50
Testa U, Rutella S, Martucci R, et al Autologous stem cell transplantation: Evaluation of erythropoietic reconstitution by highly fluorescent reticulocyte counts, erythropoietin, soluble transferrin receptors, ferritin, TIBC and iron dosages Br J Haematol 1997 Mar 96(4):762 75 9074420
Thatcher N. Chemotherapy related anemia and the role of erythropoietin. In: 7th International Symposium on Supportive Care in Cancer; September 20-3, 1995; Luxembourg; 1995.
Thatcher N Controlled study of the efficacy and safety of recombinant human erythropoietin (Epoetin alfa; Cilag) in the prevention of anemia in patients with small cell lung cancer receiving chemotherapy Ann Oncol 1994 5(Suppl 8):
Thatcher N Management of chemotherapy-induced anemia in solid tumors Semin Oncol 1998 Jun 25(3 Suppl 7):23 6 9671326
Thatcher N Predicting the response to r-huepo in anaemic cancer patients undergoing chemotherapy Erythropoiesis 1995 6(4):99 106
Thatcher N, De Campos ES, Bell DR, et al Epoetin alpha prevents anaemia and reduces transfusion requirements in patients undergoing primarily platinum-based chemotherapy for small cell lung cancer Br J Cancer 1999 80(3-4):396 402 10408844
Thomas ML Anemia and quality of life in cancer patients: Impact of transfusion and erythropoietin Med Oncol 1998 15(Suppl 1):S13 S18 9785332
Thomas ML Impact of anemia and fatigue on quality of life in cancer patients: A brief review Med Oncol 1998 15(Suppl 1):S3 S7 9785330
Thompson JA, Gilliland DG, Prchal JT, et al Effect of recombinant human erythropoietin combined with granulocyte/macrophage colony-stimulating factor in the treatment of patients with myelodysplastic syndrome. GM/EPO MDS Study Group Blood 2000 Feb 15 95(4):1175 9
Toren A, Nagler R, Nagler A Involved field radiation post autologous stem cell transplantation in lymphoma patients is associated with major haematological toxicities Med Oncol 1998 15(2):113 8 9789219
Tsiara ST, Kaiafas P, Kapsali E, et al Recombinant human erythropoietin for the treatment of refractory anemia in lymphoproliferative disorders: Preliminary results Eur J Haematol 1998 May 60(5):317 9 9654164
Tsuji Y, Kambayashi J, Shiba E, et al Effect of recombinant human erythropoietin on anaemia after gastrectomy: A pilot study Eur J Surg 1995 Jan 161(1):29 33 7727602
Tsukuda M, Mochimatsu I, Nagahara T, et al Clinical application of recombinant human erythropoietin for treatments in patients with head and neck cancer Cancer Immunol Immunother 1993 36(1):52 6 8422668
Tsukuda M, Yuyama S, Kohno H, et al Effectiveness of weekly subcutaneous recombinant human erythropoietin administration for chemotherapy-induced anemia Biotherapy 1998 11(1):21 5 9617462
Urabe A, Mitani K, Yoshinaga K, et al Serum erythropoietin titers in hematological malignancies and related diseases Int J Cell Cloning 1992 10(6):333 7 1460322
Urabe A, Mizoguchi H, Takaku F, et al [Phase II clinical study of recombinant human erythropoietin on the anemia of myelodysplastic syndrome] Rinsho Ketsueki 1993 Aug 34(8):928 36 8411647
Urabe A, Mizoguchi H, Takaku F, et al [Phase II clinical study of recombinant human erythropoietin on the anemia associated with multiple myeloma] Rinsho Ketsueki 1993 Aug 34(8):919 27 8411646
Vadhan-Raj S, Hittelman WN, Lepe-Zuniga JL, et al Regulation of endogenous erythropoietin levels in anemia associated with myelodysplastic syndromes Blood 1990 Apr 15(8):1749 50
Vadhan-Raj S Recombinant human erythropoietin in combination with other hematopoietic cytokines in attenuating chemotherapy-induced multilineage myelosuppression: Brief communication Semin Hematol 1996 33(1 Suppl 1):16 8 8714611
Valeri CR, Crowley JP, Loscalzo J. Indications for red blood cell transfusion. In: Alternative approaches to human blood resources in clinical practice. Sibinga CTS, Das PC, Fratantoni: JC, editors. Dordrecht, Netherlands: Kluwer Academic Publ; 1998. p. 209-14.
Valeri CR, Crowley JP, Loscalzo J The red cell transfusion trigger: Has a sin of commission now become a sin of omission? Transfusion 1998 Jun 38(6):602 10 9661695
Valladares Ayerbes MJ, Valenzuela Claros JC, Reina Zoilo JJ, et al [Human recombinant erythropoietin in the treatment of the anemia of multiple myeloma] An Med Interna 1997 Nov 14(11):593 4
van Kaam AH, Egeler RM Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy Cancer 1996 Sep 1 78(5):1144 5
van Kamp H, Prinsze-Postema TC, Kluin PM, et al Effect of subcutaneously administered human recombinant erythropoietin on erythropoiesis in patients with myelodysplasia Br J Haematol 1991 Aug 78(4):488 93 1911340
Vannucchi AM, Bosi A, Grossi A, et al Stimulation of erythroid engraftment by recombinant human erythropoietin in ABO-compatible, HLA-identical, allogeneic bone marrow transplant patients Leukemia 1992 Mar 6(3):215 9 1564959
Vannucchi AM, Bosi A, Ieri A, et al Combination therapy with G-CSF and erythropoietin after autologous bone marrow transplantation for lymphoid malignancies: A randomized trial Bone Marrow Transplant 1996 Apr 17(4):527 31 8722349
Vannucchi AM, Bosi A, Linari S, et al High doses of recombinant human erythropoietin fail to accelerate platelet reconstitution in allogeneic bone marrow transplantation. Results of a pilot study Haematologica 1997 Jan-Feb 82(1):53 6 9107083
Varan A, Buyukpamukcu M, Kutluk T, et al Recombinant human erythropoietin treatment for chemotherapy-related anemia in children Pediatrics 1999 103(2):E161 E164 9917457
Venturini M, Del Mastro L, Testore F, et al. Erythropoietin (EPO) and GM-CSF allow intensification and acceleration of CEF regimen. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Venturini M, Del Mastro L, Testore F, et al Erythropoietin and granulocyte-macrophage colony-stimulating factor allow acceleration and dose escalation of cyclophosphamide/epidoxorubicin/5-fluorouracil chemotherapy: A dose-finding study in patients with advanced breast cancer Cancer Chemother Pharmacol 1996 38(6):487 94 8823488
Verhoef GE, De Schouwer P, Ceuppens JL, et al Measurement of serum cytokine levels in patients with myelodysplastic syndromes Leukemia 1992 Dec 6(12):1268 72 1280751
Verhoef GE, Zachee P, Ferrant A, et al Recombinant human erythropoietin for the treatment of anemia in the myelodysplastic syndromes: A clinical and erythrokinetic assessment Ann Hematol 1992 Jan 64(1):16 21 1739754
Vijayakumar S, Roach M 3d, Wara W, et al Effect of subcutaneous recombinant human erythropoietin in cancer patients receiving radiotherapy: Preliminary results of a randomized, open-labeled, phase II trial Int J Radiat Oncol Biol Phys 1993 Jul 15 26(4):721 9
Virot JS, Janin G, Guillaumie J, et al Must erythropoietin be injected by the subcutaneous route for every hemodialyzed patient? Am J Kidney Dis 1996 Sep 28(3):400 8 8804239
Vogelzang N J, Breitbart W, Cella D, et al Patient, caregiver, and oncologist perceptions of cancer-related fatigue: Results of a tripart assessment survey. The Fatigue Coalition Semin Hematol 1997 Jul 34(3 Suppl 2):4 12 9253778
Vose JM, Armitage JO Clinical applications of hematopoietic growth factors J Clin Oncol 1995 Apr 13(4):1023 35 7535842
Vose JM Cytokine use in the older patient Semin Oncol 1995 22(1 Suppl 1):6 8 7863351
Vreugdenhil G, Swaak AJ The role of erythropoietin in the anaemia of chronic disease in rheumatoid arthritis Clin Rheumatol 1990 Mar 9(1):22 7 2185909
Wasielewski S Erythropoietin in tumor-associated anemia Krankenhauspharmazie 1997 18(10):493 5
Weber J, Yang JC, Topalian SL, et al Phase I trial of subcutaneous interleukin-6 in patients with advanced malignancies J Clin Oncol 1993 11(3):499 506 7680375
Weinberg ED. Iron therapy and cancer. Kidney Int. 1999;55:S131-S134.
Weinthal JA The role of cytokines following bone marrow transplantation: Indications and controversies Bone Marrow Transplant 1996 Dec 18(Suppl 3):S10 S14 8971400
Welch RS, James RD, Wilkinson PM, et al. Recombinant human erythropoietin and platinum-based chemotherapy in metastatic ovarian carcinoma. Proc Annu Meet Am Soc Clin Oncol. 1993;12.
Welch RS, James RD, Wilkinson PM, et al Recombinant human erythropoietin and platinum-based chemotherapy in advanced ovarian cancer Cancer J Sci Am 1995 Nov 1(4):
Whitsett CF The role of hematopoietic growth factors in transfusion medicine Hematol Oncol Clin North Am 1995 Feb 9(1):23 68 7737944
Wiecek A, Chudek J, Nieszporek T, et al [Efficacy of recombinant human erythropoietin (rhuEPO) in treatment of anemia in patients with myelodysplastic syndrome] Pol Arch Med Wewn 1992 Dec 88(6):451 7 1300567
Winningham ML, Nail LM, Burke MB, et al Fatigue and the cancer experience: The state of the knowledge Oncol Nurs Forum 1994 21(1):23 36 8139999
Wood PA, Hrushesky WJ Cisplatin-associated anemia: An erythropoietin deficiency syndrome J Clin Invest 1995 Apr 95(4):1650 9 295669 7706473
Wood PA, Hrushesky WJM Erythropoietin usage in patients with cancer Cancer J Sci Am 1995 Nov 1(4):
Wuest DL Transfusion and stem cell support in cancer treatment Hematol Oncol Clin North Am 1996 10(2):397 429 8707762
Wurnig C, Windhager R, Schwameis E, et al. Erythropoietin supplement therapy mitigates effectively cytostatic induced anemia. Proc Annu Meet Am Soc Clin Oncol. 1994;13.
Wurnig C, Windhager R, Schwameis E, et al Prevention of chemotherapy-induced anemia by the use of erythropoietin in patients with primary malignant bone tumors (a double-blind, randomized, phase III study) Transfusion 1996 Feb 36(2):155 9 8614967
Yellen SB, Cella DF, Webster MA, et al. Measuring fatigue and other anemia-related symptoms with the Functional Assessment of Cancer Therapy (FACT) Measurement System. J Pain Symptom Manage. 1997;13:63-74. [pmid: 9095563].
Yoshida Y, Anzai N, Kawabata H, et al Serial changes in endogenous erythropoietin levels in patients with myelodysplastic syndromes and aplastic anemia undergoing erythropoietin treatment Ann Hematol 1993 Apr 66(4):175 80 8485205
Yoshida Y Treatment of the myelodysplastic syndromes: An updated Japanese experience Semin Hematol 1996 33(3):246 55 8819234
Zadra F, Pedretti D, Scanni A The management of chronic anaemia in cancer patients Med Biol Environ 1998 26(1):85 91
Zagonel V, Fratino L, Sacco C, et al Reducing chemotherapy-associated toxicity in elderly cancer patients Cancer Treat Rev 1996 22(3):223 44 8841391
Zarogoulidis K, Papagiannis A, Ziogas E, et al Management of chemotherapy-related anaemia with low-dose recombinant human erythropoietin in patients with small cell lung cancer Eur J Cancer 1997 Dec 33(14):2428 31 9616293
Zeigler ZR, Jones D, Rosenfeld CS, et al Recombinant human erythropoietin (rHuEPO) for treatment of myelodysplastic syndrome Stem Cells (Dayt) 1993 Jan 11(1):49 55 86295
Zhen-Hua Q Erythropoietin treatment of anemia associated with multiple myeloma (MM) and myelodysplastic syndrome (MDS) Chin J Oncol 1993 15(2):122 4
Zuckerman KS Hematopoietic abnormalities in patients with cancer Cancer Control 1998 5(2 suppl):6 11 10762460