# References

Aaronson NK, Ahmedzai S, Bergman B, et al The European Organization for Research and Treatment of Cancer QLQ-C30: A quality-of-life instrument for use in international clinical trials in oncology J Natl Cancer Inst 1993 Mar 3 85(5):365 76
Abels R Erythropoietin for anaemia in cancer patients Eur J Cancer 1993 29A(Suppl 2):S2 S8 8398361
Abels RI Recombinant human erythropoietin in the treatment of the anaemia of cancer Acta Haematol 1992 87(Suppl 1):4 11 1574966
Abels RI, Larholt KM, Krantz KD, et al. Recombinant human erythropoietin (r-HuEPO) for the treatment of the anemia of cancer. Blood cell growth factors: Their present and future use. Hematol and Oncol. 1991:121-41.
Adamson JW, Ludwig H Predicting the hematopoietic response to recombinant human erythropoietin (Epoetin alfa) in the treatment of the anemia of cancer Oncology 1999 56(1):46 53 9885377
Adamson JW, Schuster M, Allen S, et al Effectiveness of recombinant human erythropoietin therapy in myelodysplastic syndromes Acta Haematol 1992 87(Suppl 1):20 4 1574963
Adamson JW, Vapnek D. Recombinant erythropoietin to improve athletic performance. N Engl J Med. 1991;324:698-9. [pmid: 1994258].
Albitar S, Meulders Q, Hammond H, et al. Subcutaneous versus intravenous administration of erythropoietin improves its efficiency for the treatment of anaemia in haemodialysis patients. Nephrol Dial Transplant. 1995;10:40-3. [pmid: 8524493].
Aledort LM, Mohandas K Transfusion requirements in patients with malignancy Semin Hematol 1996 Jan 33(1 Suppl 1):6 9 8714609
Committee on Standards. Standards for blood banks and transfusion services. 19th ed. Washington, DC: American Association of Blood Banks; 1999.
Circular of information for the use of human blood and blood components. Brochure #ARC 1751-COI/7/98. July 1998.
Cancer: Basic facts -- 1999 facts and figures. Available at: http://www.cancer.org/statistics/cff99/basicfacts.html#hadcancer. Accessed November 16, 1999.
Practice strategies for elective red blood cell transfusion Ann Intern Med 1992 16(5):403 6
Practice guidelines for blood component therapy Anesthesiology 1996 Mar 84(3):732 47 8659805
In: Physicians' desk reference. 53rd ed. Montvale: Medical Economics Press; 1999.
Apolone G, Filiberti A, Cifani S, et al. Evaluation of the EORTC QLQ-C3-questionnaire: A comparison with SF-36 Health Survey in a cohort of Italian long-survival cancer patients. Ann Oncol. 1998:549-57.
Armitage JO Management of anemia in patients with cancer Clin Oncol Updates 1998(1):1 12
Aronson N, Seidenfeld J, Samson DJ, et al. Relative effectiveness and cost-effectiveness of methods of androgen suppression in the treatment of advanced prostatic cancer. Evidence Report/Technology Assessment No. 4. (Prepared by Blue Cross/Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-97-0015.) Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research. May 1999. AHCPR Publication No. 99-E0012.
Ayash LJ, Elias A, Hunt M, et al Recombinant human erythropoietin for the treatment of the anaemia associated with autologous bone marrow transplantation Br J Haematol 1994 May 7(1):153 61
Barosi G, Marchetti M, Liberato NL. Cost-effectiveness of human erythropoietin in the prevention of chemotherapy-induced anemia. Br J Cancer. 1998;78:781-7. [pmid: 9743301].
Begg C, Cho M, Eastwood S, et al Improving the quality of reporting of randomized trials: The CONSORT Statement JAMA 1996 Aug 28 276(8):637 9
Beguin Y Erythropoietin and the anemia of cancer Acta Clin Belg 1996 51(1):36 52 8669161
Beguin Y A risk-benefit assessment of epoetin in the management of anaemia associated with cancer Drug Safety 1998b 19(4):269 82 9804442
Beguin Y Prediction of response to optimize outcome of treatment with erythropoietin Semin Oncol 1998a Jun 25(3 Suppl 7):27 34 9671327
Beitz J Quality-of-life end points in oncology drug trials Oncology (Huntingt) 1999 Oct 13(10):1439 42 419372 10549568
Beitz J, Gnecco C, Justice R. Quality-of-life end points in cancer clinical trials: The U. S. Food and Drug Administration perspective. J Natl Cancer Inst Monogr. 1996;(20):7-9. [pmid: 8750460].
Berlin JA, Rennie D Measuring the quality of trials: The quality of the quality scales JAMA 1999 Sep 15;282(11):1083 5
Besarab A, Flaherty KK, Erslev AJ, et al. Clinical pharmacology and economics of recombinant erythropoietin end-stage renal disease: The case for subcutaneous administration. J Am Soc Nephrol. 1992;3:1405-16.
Biggs JC, Atkinson KA, Booker V, et al Prospective randomised double-blind trial of the in vivo use of recombinant human erythropoietin in bone marrow transplantation from HLA-identical sibling donors. The Australian Bone Marrow Transplant Study Group Bone Marrow Transplant 1995 Jan 15(1):129 34 7742745
Bosi A, Vannucchi AM, Grossi A, et al Serum erythropoietin levels in patients undergoing autologous bone marrow transplantation Bone Marrow Transplant 1991 Jun 7(6):421 5 1873588
Bunn HF. Pathophysiology of the anemias. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13th ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994a. p. 1717-21.
Bunn HF. Anemia associated with chronic disorders. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13th ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994b. p. 1732-4.
Bush RS The significance of anemia in clinical radiation therapy Int J Radiat Oncol Biol Phys 1986 Nov 12(11):2047 50 3771322
Canaud B, Bennhold I, Delons S, et al. What is the optimum frequency of administration of r-huepo for correcting anemia in hemodialysis patients?. Dial Transplant. 1995;24:306-9.
Cascinu S, Fedeli A, Del Ferro E, et al Recombinant human erythropoietin treatment in cisplatin-associated anemia: A randomized, double-blind trial with placebo J Clin Oncol 1994 12(5):1058 62 8164030
Case DC Jr, Bukowski RM, Carey RW, et al Recombinant human erythropoietin therapy for anemic cancer patients on combination chemotherapy J Natl Cancer Inst 1993 May 19 85(10):801 6
Catlin DH, Hatton CK. Use and abuse of anabolic and other drugs. Adv Intern Med. 1991;36:399-424. [pmid: 1673818].
Cazzola M, Messinger D, Battistel V, et al Recombinant human erythropoietin in the anemia associated with multiple myeloma or non-Hodgkin's lymphoma: Dose finding and identification of predictors of response Blood 1995 Dec 15 86(12):4446 53
Cella D The Functional Assessment of Cancer Therapy-Anemia (FACT-An) Scale: A new tool for the assessment of outcomes in cancer anemia and fatigue Semin Hematol 1997 Jul 34(3 Suppl 2):13 9 9253779
Cella DF, Tulsky DS, Gray G, et al The Functional Assessment of Cancer Therapy Scale: Development and validation of the general measure J Clin Oncol 1993 Mar 11(3):570 9 8445433
Chalmers TC, Smith H Jr, Blackburn B, et al A method for assessing the quality of a randomized control trial Controlled Clin Trials 1981 May 2(1):31 49 7261638
Chao NJ, Schriber JR, Long GD, et al A randomized study of erythropoietin and granulocyte colony-stimulating factor (G-CSF) versus placebo and G-CSF for patients with Hodgkin's and non-Hodgkin's lymphoma undergoing autologous bone marrow transplantation Blood 1994 May 15 83(10):2823 8
Chie WC, Huang CS, Chen JH, et al Measurement of the quality of life during different clinical phases of breast cancer J Formos Med Assoc 1999 98(4):254 60 10389369
Cleeland CS, Demetri GD, Glaspy J, et al. Identifying hemoglobin level for optimal quality of life: Results of an incremental analysis. ASCO annual meeting. 1999;18.
Cohen J. Statistical power analysis for the behavioral sciences. New York: Academic Press; 1977. p. 8-17.
Cremieux P-Y, Finkelstein SN, Berndt ER, et al Cost effectiveness, quality-adjusted life-years and supportive care: Recombinant human erythropoietin as a treatment of cancer-associated anaemia Pharmacoeconomics 1999 16(5 Pt 1):459 72 10662393
Dammacco F, Silvestris F, Castoldi GL, et al The effectiveness and tolerability of epoetin alfa in patients with multiple myeloma refractory to chemotherapy Int J Clin Lab Res 1998 28(2):127 34 9689556
de Andrade JR, Frei D, Guilfoyle M Integrated analysis of thrombotic/vascular event occurrence in epoetin alfa-treated patients undergoing major, elective orthopedic surgery Orthopedics 1999 Jan 22(1 Suppl):S113 S118 9927111
Del Mastro L, Venturini M, Lionetto R, et al Randomized phase III trial evaluating the role of erythropoietin in the prevention of chemotherapy-induced anemia J Clin Oncol 1997 Jul 15(7):2715 21 9215845
Demetri GD, Kris M, Wade J, et al Quality-of-life benefit in chemotherapy patients treated with epoetin alfa is independent of disease response or tumor type: Results from a prospective community oncology study. Procrit Study Group J Clin Oncol 1998 Oct 16(10):3412 25 9779721
Denton TA, Diamond GA, Matloff JM, et al Anemia therapy: Individual benefit and societal cost Semin Oncol 1994 Apr 21(2 Suppl 3):29 35
DerSimonian R, Laird N. Meta analysis in clinical trials. Controlled Clin Trials. 1986;7:177-88. [pmid: 3802833].
Dimeo FC, Stieglitz RD, Novelli-Fischer U, et al Effects of physical activity on the fatigue and psychologic status of cancer patients during chemotherapy Cancer 1999 May 15 85(10):2273 7
Dimeo FC, Tilmann MH, Bertz H, et al Aerobic exercise in the rehabilitation of cancer patients after high dose chemotherapy and autologous peripheral stem cell transplantation Cancer 1997 May 1 79(9):1717 22
Dische S Radiotherapy and anaemia -- the clinical experience Radiother Oncol 1991 20(Suppl 1)35 40 2020767
Dunphy FR, Harrison BR, Dunleavy TL, et al Erythropoietin reduces anemia and transfusions: A randomized trial with or without erythropoietin during chemotherapy Cancer 1999 Oct 1 86(7):1362 7
Dusenbery KE, McGuire WA, Holt PJ, et al Erythropoietin increases hemoglobin during radiation therapy for cervical cancer Int J Radiat Oncol Biol Phys 1994 Jul 30 29(5):1079 84
Eddy DM, Hasselblad V. FAST*PRO Software for Meta-analysis by the Confidence Profile Method. Orlando: Academic Press; 1992.
Seattle: Statistics in Epidemiology Research Corporation;1996.
Faulds D, Sorkin EM Epoetin (recombinant human erythropoietin). A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in anaemia and the stimulation of erythropoiesis Drugs 1989 Dec 38(6):863 99 2693045
Fein DA, Lee WR, Hanlon AL, et al Pretreatment hemoglobin level influences local control and survival of T1-T2 squamous cell carcinomas of the glottic larynx J Clin Oncol 1995 Aug 13(8):2077 83 7636551
Foerster J. Red cell fragmentation syndromes. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999.
Frenkel EP, Bick RL, Rutherford CJ Anemia of malignancy Hematol Oncol Clin North Am 1996 Aug 10(4):861 73 8811306
Gabrilove JL, Einhorn LH, Livingston RB, et al. Once-weekly dosing of epoetin alfa is similar to three-times-weekly dosing in increasing hemoglobin and quality of life. American Society of Clinical Oncology 1999 Annual Meeting. Abstract #2216.
Gamucci T, Thorel MF, Frasca AM, et al Erythropoietin for the prevention of anaemia in neoplastic patients treated with cisplatin Eur J Cancer 1993 29A(Suppl 2)S13 S14 8398359
Garton JP, Gertz MA, Witzig TE, et al Epoetin alfa for the treatment of the anemia of multiple myeloma. A prospective, randomized, placebo-controlled, double-blind trial Arch Intern Med 1995 Oct 23 155(19):2069 74
Glaspy J, Bukowski R, Steinberg D, et al Impact of therapy with epoetin alfa on clinical outcomes in patients with nonmyeloid malignancies during cancer chemotherapy in community oncology practice. Procrit Study Group J Clin Oncol 1997 Mar 15(3):1218 34 9060566
Glaspy J, Cavill I Role of iron in optimizing responses of anemic cancer patients to erythropoietin Oncology (Huntingt) 1999 Apr 13(4):461 73; discussion 477-8, 483-8 419372 10234700
Glimelius B, Linne T, Hoffman K, et al Epoetin beta in the treatment of anemia in patients with advanced gastrointestinal cancer J Clin Oncol 1998 Feb 16(2):434 40 9469326
Gold MR, Siegel JE, Russell LB, et al., editors. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Gordon MS, Nemunaitis J, Hoffman R, et al A phase I trial of recombinant human interleukin-6 in patients with myelodysplastic syndromes and thrombocytopenia Blood 1995 Jun 1 85(11):3066 76
Gough IR, Furnival CM, Schilder L, et al Assessment of the quality of life of patients with advanced cancer Eur J Cancer Clin Oncol 1983 Aug 19(8):1161 5 6684561
Groopman JE, Itri LM Chemotherapy-induced anemia in adults: Incidence and treatment J Natl Cancer Inst 1999 91(19):1616 34 10511589
Halstenson CE, Macres M, Katz SA, et al Comparative pharmacokinetics and pharmacodynamics of epoetin alfa and epoetin beta Clin Pharmacol Ther 1991 Dec 50(6):702 12 1752115
Hasselblad V. Meta-analysis of multi-treatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Hedges LV, Olkin I, editors. Statistical methods for meta-analysis. Orlando: Academic Press; 1985.
Hellman S. Principles of cancer management: Radiation therapy. In: DeVita VT Jr, et al., editors. Cancer: Principles and practice of oncology.5th ed. Philadelphia: Lippincott-Raven; 1997.
Hellstrom-Lindberg E Efficacy of erythropoietin in the myelodysplastic syndromes: A meta-analysis of 205 patients from 17 studies Br J Haematol 1995 Jan 89(1):67 71 7833279
Henke M, Guttenberger R, Barke A, et al Erythropoietin for patients undergoing radiotherapy: A pilot study Radiother Oncol 1999 50(2):185 90 10368042
Henry DH Epoetin alfa and high-dose chemotherapy Semin Oncol 1998 Jun 25(3 Suppl 7):54 7 9671332
Henry DH Recombinant human erythropoietin treatment of anemic cancer patients Cancer Pract 1996 Jul-Aug 4(4):180 4 8900758
Henry DH, Abels RI Recombinant human erythropoietin in the treatment of cancer and chemotherapy-induced anemia: Results of double-blind and open-label follow-up studies Semin Oncol 1994 Apr 21(2 Suppl 3):21 8
Henry DH, Brooks BJ Jr, Case DC Jr, et al Recombinant human erythropoietin therapy for anemic cancer patients receiving cisplatin chemotherapy Cancer J Sci Am 1995 Nov 1(4):
Irvine D, Vincent L, Graydon JE, et al The prevalence and correlates of fatigue in patients receiving treatment with chemotherapy and radiotherapy Cancer Nurs 1994 17(5):367 78 7954384
A randomized double-blind placebo-controlled study with subcutaneous recombinant human erythropoietin in patients with low-risk myelodysplastic syndromes Br J Haematol 1998 Dec 103(4):1070 4 9886322
Jacobs K, Shoemaker C, Rudersdorf R, et al. Isolation and characterization of genomic and cDNA clones of human erythropoietin. Nature. 1985;313:806-10. [pmid: 3838366].
Jones TH, Wadler S, Hupart KH Endocrine-mediated mechanisms of fatigue during treatment with interferon-alpha Semin Oncol 1998 Feb 25(1 Suppl 1):54 63
Juni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Kalman D, Villani LJ Nutritional aspects of cancer-related fatigue J Am Diet Assoc 1997 Jun 97(6):650 4 9183327
Kaufman JS, Reda DJ, Fye CL, et al Subcutaneous compared with intravenous epoetin in patients receiving hemodialysis N Engl J Med 1998 339(9):578 583 9718376
Kazis LE, Anderson JJ, Meenan RF Effect sizes for interpreting changes in health status Med Care 1989 27(Suppl):S178 S189 2646488
Kemmler G, Holzner B, Kapp M, et al Comparison of two quality-of-life instruments for cancer patients: The Functional Assessment of Cancer Therapy-General and the European Organization for Research and Treatment of Cancer Quality of Life Questionnaire-C30 J Clin Oncol 1999 17(9):2932 40 10561373
Klaesson S. Clinical use of rHuEPO in bone marrow transplantation. Med Oncol. 1999;16:2-7. [pmid: 10382935].
Klaesson S, Ringden O, Ljungman P, et al Reduced blood transfusions requirements after allogeneic bone marrow transplantation: Results of a randomised, double-blind study with high-dose erythropoietin Bone Marrow Transplant 1994a Apr 13(4):397 402 8019463
Klaesson S, Ringden O, Ljungman P, et al Treatment with erythropoietin after allogeneic bone marrow transplantation: A randomized, double-blind study Transplant Proc 1994b Jun 26(3):1827 8 8030158
Koeller JM Clinical guidelines for the treatment of cancer-related anemia Pharmacotherapy 1998 Jan-Feb 18(1):156 69 9469689
Koury MJ, Bondurant MC Erythropoietin retards DNA breakdown and prevents programmed death in erythroid progenitor cells Science 1990 Apr 20 248(4953):378 81
Kurz C, Marth C, Windbichler G, et al Erythropoietin treatment under polychemotherapy in patients with gynecologic malignancies: A prospective, randomized, double-blind placebo-controlled multicenter study Gynecol Oncol 1997 Jun 65(3):461 6 9190976
Landis SH, Murray T, Bolden S, et al Cancer statistics 1999 CA Cancer J Clin 1999 49(1):8 31 10200775
Langer CJ. Anaemia, fatigue and quality of life in advanced malignancy: Potential therapeutic role for epoetin. Erythropoiesis. 1997;8:63-73.
Laupacis A, Sackett DL, Roberts RS An assessment of clinically useful measures of the consequences of treatment New Engl J Med 1988 318(26):1726 33
Lavey RS, Dempsey WH Erythropoietin increases hemoglobin in cancer patients during radiation therapy Int J Radiat Oncol Biol Phys 1993 Dec 1 27(5):1147 52
Lee GR. Anemia: A diagnostic strategy. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999a. [pmcid: 192034].
Lee GR. Inherited and drug-induced megaloblastic anemia. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999b.
Lee GR. Iron deficiency and iron-deficiency anemia. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999c.
Leidy NK, Revicki DA, Geneste B Recommendations for evaluating the validity of quality of life claims for labeling and promotion Value Health 1999 2(3):113 27 16674343
Leitgeb C, Pecherstorfer M, Fritz E, et al Quality of life in chronic anemia of cancer during treatment with recombinant human erythropoietin Cancer 1994 May 15 73(10):2535 42
Leon P, Jimenez M, Barona P, et al Recombinant human erythropoietin for the treatment of anemia in children with solid malignant tumors Med Pediatr Oncol 1998 30(2):110 6 9403020
Lin F-K, Suggs S, Lin C-H, et al. Cloning and expression of the human erythropoietin gene. Proc Natl Acad Sci USA. 1985;82:7580-4. [pmcid: 391376]. [pmid: 3865178].
Link H, Boogaerts MA, Fauser AA, et al A controlled trial of recombinant human erythropoietin after bone marrow transplantation Blood 1994 Nov 15 84(10):3327 35
Link H, Brune T, Hubner G, et al Effect of recombinant human erythropoietin after allogenic bone marrow transplantation Ann Hematol 1993 Oct 67(4):169 73 8218537
Littlewood TJ, Bajetta E, Cella D, et al. for the European Epoetin Alfa Study Group. Efficacy and quality of life outcomes of epoetin alfa in a double-blind, placebo-controlled multicenter study of cancer patients receiving non-platinum containing chemotherapy. Proc Annu Meet Am Soc Clin Oncol. 1999;18. (Unpublished study; published as abstract and available as slides.).
Locatelli F, Zecca M, Pedrazzoli P, et al Use of recombinant human erythropoietin after bone marrow transplantation in pediatric patients with acute leukemia: Effect on erythroid repopulation in autologous versus allogeneic transplants Bone Marrow Transplant 1994 Apr 13(4):403 10 8019464
Lowenthal RM, Marsden KA Myelodysplastic syndromes Int J Hematol 1997 Jun 65(4):319 38 9195773
Ludwig H, Fritz E Anemia of cancer patients: Patient selection and patient stratification for epoetin treatment Semin Oncol 1998b Jun 25(3 Suppl 7):35 8
Ludwig H, Fritz EA Anemia in cancer patients Semin Oncol 1998a Jun 25(3 Suppl 7):2 6
Ludwig H, Fritz E, Leitgeb C, et al Erythropoietin treatment for chronic anemia of selected hematological malignancies and solid tumors Ann Oncol 1993 Feb 4(2):161 7 8448084
Ludwig H, Sundal E, Pecherstorfer M, et al Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy Cancer 1995 Dec 1 76(11):2319 29
Lydick E, Epstein RS Interpretation of quality of life changes Qual Life Res 1993 Jun 2(3):221 6 8401458
Markham A, Bryson HM Epoetin alfa. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic use in nonrenal applications Drugs 1995 Feb 49(2):232 54 7729331
Markman M, Reichman B, Hakes T, et al The use of recombinant human erythropoietin to prevent carboplatin-induced anemia Gynecol Oncol 1993 May 49(2):172 6 8504984
McEvoy GK, editor. Epoetin alfa. In: AHFS drug information 1999. Bethesda: American Society of Health-System Pharmacists; 1999.
McPeek B, Gilbert JP, Mosteller F Sounding boards. The clinician's responsibility for helping to improve the treatment of tomorrow's patients N Engl J Med 1980 13;302(11):630 1
Meadowcroft AM, Gilbert CJ, Maravich-May D, et al. Cost of managing anemia with and without prophylactic epoetin therapy in breast cancer patients receiving combination chemotherapy. Am J Health-Syst Pharm. 1998;55:1898-902. [pmid: 9784769].
Means RT Jr. The anemia of chronic disorders. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999.
Miaskowski C, Portenoy RK Update on the assessment and management of cancer-related fatigue Principles Pract Support Oncol Updates 1998 1(2):1 10
Miller CB, Jones RJ, Piantadosi S, et al Decreased erythropoietin response in patients with the anemia of cancer N Engl J Med 1990 Jun; 14 322(24):1689 92
Moher D, Pham B, Jones A, et al Does quality of reports of randomized controlled trials affect estimates of intervention efficacy reported in meta-analyses? Lancet 1998 Aug 22 352(9128):609 13
Moliterno AR, Spivak JL Anemia of cancer Hematol Oncol Clin North Am 1996 Apr 10(2):345 63 8707759
Monga U, Jaweed M, Kerrigan AJ, et al Neuromuscular fatigue in prostate cancer patients undergoing radiation therapy Arch Phys Med Rehabil 1997 Sep 78(9):961 6 9305269
Mulrow CD, Oxman AD, editors. Cochrane collaboration handbook. Available in the Cochrane Library [database on disk and CD-ROM]. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
Nail LM, Winningham ML. Fatigue and weakness in cancer patients: The symptom experience. Semin Oncol Nurs. 1995;11:272-8. [pmid: 8578035].
NKF-DOQI Clinical Practice Guidelines for the Treatment of Anemia of Chronic Renal Failure. New York: National Kidney Foundation; 1997.
Nicholls AJ. Enhanced quality of life in dialysis patients treated with erythropoietin: Are the benefits worth the cost?. Erythropoiesis. 1992;3:46-9.
Oberhoff C, Neri B, Amadori D, et al Recombinant human erythropoietin in the treatment of chemotherapy-induced anemia and prevention of transfusion requirement associated with solid tumors: A randomized, controlled study Ann Oncol 1998 Mar 9(3):255 60 9602258
Ortega A, Dranitsaris G, Puodziunas AL What are cancer patients willing to pay for prophylactic epoetin alfa? A cost-benefit analysis Cancer 1998 Dec 15 83(12):2588 96
Ortho Biotech, Inc. Procrit? (epoetin alfa) prescribing information. In: Physicians' desk reference. 53rd ed. Montvale: Medical Economics Press; 1999.
Osterborg A, Boogaerts MA, Cimino R, et al Recombinant human erythropoietin in transfusion-dependent anemic patients with multiple myeloma and non-Hodgkin's lymphoma -- a randomized multicenter study. The European Study Group of Erythropoietin (Epoetin Beta) Treatment in Multiple Myeloma and Non-Hodgkin's Lymphoma Blood 1996 Apr 1 87(7):2675 82
Paganini EP, Eschbach JW, Lazarus JM, et al Intravenous versus subcutaneous dosing of epoetin alfa in hemodialysis patients Am J Kidney Dis 1995 Aug 26(2):331 40 7645538
Pene R, Appelbaum FR, Fisher L, et al Use of granulocyte-macrophage colony-stimulating factor and erythropoietin in combination after autologous marrow transplantation Bone Marrow Transplant 1993 Mar 11(3):219 22 8467286
Pincus T, Olsen NJ, Russell IJ, et al Multicenter study of recombinant human erythropoietin in correction of anemia in rheumatoid arthritis Am J Med 1990 Aug 89(2):161 8 2200263
Portenoy RK, Itri LM. Cancer-related fatigue: Guidelines for evaluation and management. Oncologist. 1999;4:1-10. [pmid: 10337366].
Portenoy RK, Thaler HT, Kornblith AB, et al Symptom prevalence, characteristics and distress in a cancer population Qual Life Res 1994 Jun 3(3):183 9 7920492
Porter JC, Leahey A, Polise K, et al Recombinant human erythropoietin reduces the need for erythrocyte and platelet transfusions in pediatric patients with sarcoma: A randomized, double-blind, placebo-controlled trial J Pediatr 1996 Nov 129(5):656 60 8917229
Poskitt TR Radiation therapy and the role of red blood cell transfusion Cancer Invest 1987 5(3):231 6 3651866
Quirt I, Couture F, Pichette R, et al The role of recombinant human erythropoietin (EPO) in reducing red blood cell transfusions and maintaining quality of life (QOL) in patients with lymphoma and solid tumors receiving cytotoxic chemotherapy. Results of a randomized, double-blind, placebo-controlled clinical trial Blood 1996 88(10 Suppl 1):
Quirt I, Micucci S, Moran LA, et al Erythropoietin in the management of patients with nonhematologic cancer receiving chemotherapy. Systemic Treatment Program Committee Cancer Prev Control 1997 Aug 1(3):241 8 9765749
Rappeport JM, Bunn HF. Bone marrow failure: Aplastic anemia and other primary bone marrow disorders. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13th ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994. p. 1754-7.
Rose E, Rai K, Revicki D, et al Clinical and health status assessments in anemic chronic lymphocytic leukemia (CLL) patients treated with epoetin alfa (EPO) Blood 1994 84(10 Suppl 1)
Rosse W, Bunn HF. Hemolytic anemias. In: Harrisons: Principles and practice of internal medicine. Vol. 2, 13th ed. New York: McGraw-Hill, Inc., Health Professions Division; 1994. p. 1743-54.
Salvarani C, Lasagni D, Casali B, et al Recombinant human erythropoietin therapy in patients with rheumatoid arthritis with the anemia of chronic disease J Rheumatol 1991 Aug 18(8):1168 71 1941817
Schroeder ML. Principles and practice of transfusion medicine. In: Lee GR, et al., editors. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999.
Schulz KF, Chalmers I, Hayes RJ, et al Empirical evidence of bias: Dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 273(5):408 12 7823387
Sheffield RE, Sullivan SD, Saltiel E, et al. Cost comparison of recombinant human erythropoietin and blood transfusion in cancer chemotherapy-induced anemia. Ann Pharmacother. 1997;31:15-22. [pmid: 8997459].
Silvestris F, Romito A, Fanelli P, et al Long-term therapy with recombinant human erythropoietin (rHu-EPO) in progressing multiple myeloma Ann Hematol 1995 Jun 70(6):313 8 7632811
Simon TL, Alverson DC, AuBuchon J, et al Practice parameter for the use of red blood cell transfusions: Developed by the Red Blood Cell Administration Practice Guideline Development Task Force of the College of American Pathologists Arch Pathol Lab Med 1998 Feb 122(2):130 8 9499355
Smith DA, Perry PJ The efficacy of ergogenic agents in athletic competition, part II: Other performance-enhancing agents Ann Pharmacother 1992 26(5):653 9 1591427
Sosman JA, Aronson FR, Sznol M, et al Concurrent phase I trials of intravenous interleukin 6 in solid tumor patients: Reversible dose-limiting neurological toxicity Clin Cancer Res 1997 Jan 3(1):39 46 9815535
Spivak JL Recombinant human erythropoietin and the anemia of cancer Blood 1994 Aug 15 84(4):997 1004 8049455
Spivak JL, Pham T, Isaacs M, et al Erythropoietin is both a mitogen and a survival factor Blood 1991 Mar 15 77(6):1228 33
Steegmann JL, Lopez J, Otero MJ, et al Erythropoietin treatment in allogeneic BMT accelerates erythroid reconstitution: Results of a prospective controlled randomized trial Bone Marrow Transplant 1992 Dec 10(6):541 6 1490203
Stein RS, Abels RI, Krantz SB Pharmacologic doses of recombinant human erythropoietin in the treatment of myelodysplastic syndromes Blood 1991 Oct 1 78(7):1658 63
Stone P, Hardy J, Broadley K, et al Fatigue in advanced cancer: A prospective controlled cross-sectional study Br J Cancer 1999 79(9-10):1479 86 10188894
Suzuki M, Tsutsui M, Yokoyama A, et al Normalization of hematocrit with recombinant human erythropoietin in chronic hemodialysis patients does not fully improve their exercise tolerance abilities Artif Organs 1995 Dec 19(12):1258 61 8967885
Sweeney PJ, Nicolae D, Ignacio L, et al Effect of subcutaneous recombinant human erythropoietin in cancer patients receiving radiotherapy: Final report of a randomized, open-labelled, phase II trial Br J Cancer 1998 Jun 77(11):1996 2002 9667681
ten Bokkel Huinink WW, de Swart CAM, van Toorn DW, et al Controlled multicentre study of the influence of subcutaneous recombinant human erythropoietin on anaemia and transfusion dependency in patients with ovarian carcinoma treated with platinum-based chemotherapy Med Oncol 1998 15(3):174 82 9819794
Thatcher N, De Campos ES, Bell DR, et al Epoetin alpha prevents anaemia and reduces transfusion requirements in patients undergoing primarily platinum-based chemotherapy for small cell lung cancer Br J Cancer 1999 May 80(3-4):396 402 10408844
Thompson JA, Gilliland DG, Prchal JT, et al Effect of recombinant human erythropoietin combined with granulocyte/macrophage colony-stimulating factor in the treatment of patients with myelodysplastic syndrome. GM/EPO MDS Study Group Blood 2000 Feb 15 95(4):1175 9
Valeri CR, Crowley JP, Loscalzo J The red cell transfusion trigger: Has a sin of commission now become a sin of omission? Transfusion 1998 Jun 38(6):602 10 9661695
Vannucchi AM, Bosi A, Ieri A, et al Combination therapy with G-CSF and erythropoietin after autologous bone marrow transplantation for lymphoid malignancies: A randomized trial Bone Marrow Transplant 1996 Apr 17(4):527 31 8722349
Vannucchi AM, Bosi A, Linari S, et al High doses of recombinant human erythropoietin fail to accelerate platelet reconstitution in allogeneic bone marrow transplantation. Results of a pilot study Haematologica 1997 Jan-Feb 82(1):53 6 9107083
Varan A, Buyukpamukcu M, Kutluk T, et al Recombinant human erythropoietin treatment for chemotherapy-related anemia in children Pediatrics 1999 103(2):E161 E164 9917457
Virot JS, Janin G, Guillaumie J, et al Must erythropoietin be injected by the subcutaneous route for every hemodialyzed patient? Am J Kidney Dis 1996 Sep 28(3):400 8 8804239
Vogelzang NJ, Breitbart W, Cella D, et al Patient, caregiver, and oncologist perceptions of cancer-related fatigue: Results of a tripart assessment survey. The Fatigue Coalition Semin Hematol 1997 Jul 34(3 Suppl 2):4 12 9253778
Vreugdenhil G, Swaak AJ The role of erythropoietin in the anaemia of chronic disease in rheumatoid arthritis Clin Rheumatol 1990 Mar 9(1):22 7 2185909
Weber J, Yang JC, Topalian SL, et al Phase I trial of subcutaneous interleukin-6 in patients with advanced malignancies J Clin Oncol 1993 11(3):499 506 7680375
Welch RS, James RD, Wilkinson PM, et al Recombinant human erythropoietin and platinum-based chemotherapy in advanced ovarian cancer Cancer J Sci Am 1995 Nov 1(4):
Winningham ML, Nail LM, Burke MB, et al Fatigue and the cancer experience: The state of the knowledge Oncol Nurs Forum 1994 21(1):23 36 8139999
Wood PA, Hrushesky WJ Cisplatin-associated anemia: An erythropoietin deficiency syndrome J Clin Invest 1995 Apr 95(4):1650 9 295669 7706473
Wurnig C, Windhager R, Schwameis E, et al Prevention of chemotherapy-induced anemia by the use of erythropoietin in patients with primary malignant bone tumors (a double-blind, randomized, phase III study) Transfusion 1996 Feb 36(2):155 9 8614967
Yellen SB, Cella DF, Webster MA, et al. Measuring fatigue and other anemia-related symptoms with the Functional Assessment of Cancer Therapy (FACT) Measurement System. J Pain Symptom Manage. 1997;13:63-74. [pmid: 9095563].