# Future Research

Future research should include the following:

- For patients undergoing cancer therapy, evidence demonstrates that epoetin reduces transfusion if treatment is initiated when declining Hb levels near 10 g/dL. Randomized controlled trials, adequately powered, are needed to determine whether initiating treatment at higher baseline Hb levels would yield additional benefits in reducing transfusion use or improving quality of life.
- This review identified common deficiencies in the design and reporting of trials on epoetin. In addition to the preponderance of unblinded studies, deficiencies common to this literature included: inadequate statistical power, failure to report on concealment of allocation, failure to consistently report on a common set of clinically relevant outcomes, failure to consistently test and report on statistical significance, failure to account for patients lost to followup or excluded from analysis, and failure to use intent-to-treat analyses. Some methodologic deficiencies may result in overestimation of the effects of epoetin, and inadequacy of reporting may limit the ability to interpret and generalize results. Future trials should maintain a higher standard of methodologic quality and completeness of reporting.
- Published trials that reported on quality of life did not follow recognized principles to minimize biases. Consequently, factors other than epoetin treatment may have affected outcomes. Future trials should measure effects of epoetin on quality of life more rigorously using validated instruments, and by incorporating specific design features related to administration of questionnaires and analysis and interpretation of results.
- In nearly all trials, a substantial percentage of patients did not achieve a hematologic response to epoetin. Additionally, nonresponding patients may account for much of the transfusion use in the epoetin arms of these trials. To achieve the most efficient use of epoetin, more systematic evidence is needed on baseline characteristics that predict responsiveness and on early indicators of response.
- The reviewed evidence shows that initial doses of epoetin in the range of 300-450 units/kg/week administered subcutaneously are adequate to increase Hb and reduce the percentage of patients transfused. However, the optimal initial dose within this range has not been determined. Furthermore, within this dose range the team could not discern any difference in response rates between trials that used increasing dose regimens and those that used decreasing dose regimens. To achieve the most efficient use of epoetin, comparative trials are needed to establish an optimal initial dose and to determine the optimal dosing regimen.
- The team found evidence that patients with MDS respond to epoetin, although response rates are much lower than in other malignancies and higher doses of epoetin appear to be necessary. To achieve the most efficient use of epoetin, additional studies are needed to determine which patients with MDS are most likely to respond. Studies also are needed to establish an optimal dose and dosing regimen.