# Future Research Priorities

- For patients undergoing cancer therapy, evidence demonstrates that epoetin reduces transfusion if treatment is initiated when declining Hb levels near 10 g/dL. Randomized controlled trials, adequately powered, are needed to determine whether initiating treatment at higher baseline Hb levels yields additional benefits in reducing transfusion use or improving quality of life.

Inferences from indirect comparison of results of available trials did not provide compelling evidence to resolve the question of an optimal threshold Hb level for initiating epoetin treatment. The most robust evidence that epoetin reduces transfusion use for patients undergoing therapy for malignancy comes from trials in patient groups with mean baseline Hb <10 g/dL. Transfusion outcomes did not appear to be superior in trials where epoetin treatment was initiated in groups of patients with mean Hb >10 g/dL.

It is possible that adequately powered comparative trials might demonstrate the superiority of initiating epoetin treatment at the higher Hb levels. However, it appears more likely that the greatest yield for reducing transfusions might come from initiating epoetin before the Hb level falls substantially below 10 g/dL, rather than by initiating epoetin treatment at a level substantially above 10 g/dL. A question for which little evidence is available is whether initiating epoetin at levels above 10 g/dL might improve quality of life. Randomized controlled trials, double blinded and adequately powered, are needed to answer this question.

The trials completed to date have compared patients for whom epoetin treatment was initiated soon after study entry with patients who are not treated with epoetin. This study design is useful to measure outcomes of epoetin use compared with not using epoetin. However, trials to determine an optimal Hb level for initiating epoetin treatment require comparisons of groups of patients treated at various predetermined Hb thresholds. For example, patients who are starting chemotherapy, but who are not yet anemic, could be randomized to epoetin treatment either when Hb nears 10 g/dL or to treatment when Hb nears a higher threshold (e.g., 13, 12, or 11 g/dL). To maintain a double-blinded design, patients would need to be given placebo injections until their Hb level fell to the target threshold. A prospectively designed, adequately powered, randomized double-blind multiarm trial that collects data on transfusion rates, quality of life, and anemia-related symptoms would provide evidence to determine whether outcomes of epoetin use are superior when treatment begins at higher Hb levels. In addition, such trials should avoid the methodologic and reporting deficiencies common to most trials completed to date and addressed below.

- This review identified common deficiencies in the design and reporting of trials on epoetin. Some methodologic deficiencies may result in overestimation of the effects of epoetin, and inadequacy of reporting may limit the ability to interpret and generalize results. Future trials should maintain a higher standard of methodologic quality and completeness of reporting.

We had substantial concern about the impact of subjective judgments on measurement of treatment outcomes in the available trials. Where an outcome requires subjective judgment, double-blinding may be of paramount importance to minimize bias. The clinical outcomes of interest to this systematic review (transfusion, quality of life, fatigue, etc.) can obviously be affected by physician behavior and patient perceptions. Although most trials included in this systematic review were randomized, the preponderance of these studies were not double blinded. Our meta-analysis of randomized controlled trials showed that unblinded trials reported greater reduction of transfusion than did doubleblinded trials.

In addition to the preponderance of unblinded studies, deficiencies common to this literature included inadequate statistical power, failure to report on concealment of allocation, failure to consistently report on a common set of clinically relevant outcomes, failure to consistently test and report on statistical significance, failure to account for patients lost to followup or excluded from analysis, and failure to use intent-to-treat analyses. In addition, many of these studies suffered from incompleteness of reporting. Future trials should conform to the recommendations of the Consolidated Standards of Reporting Trials.

Future trials also should incorporate design and reporting features specific to the treatment of anemia. For example, trial protocols should specify a transfusion trigger and studies should compare arms with respect to the hemoglobin levels at which transfusion actually occurred. Other issues include the study duration, ruling out other causes of anemia, and verifying the iron status of patients. Finally, future trials should prospectively stratify patients by characteristics of interest and report outcomes separately for these stratified subgroups. Such characteristics include type of malignancy, prior treatments, therapeutic regimen, and predictors of response. This will produce a more robust body of cumulative evidence by improving the ability to compare results among trials and increasing the potential for combined analyses.

- Published trials that reported on quality of life did not follow recognized principles to minimize biases. Consequently, factors other than epoetin treatment may have affected outcomes. Future trials should measure effects of epoetin on quality of life more rigorously by incorporating specific design features related to administration of questionnaires and analysis and interpretation of results.

Recently, there has been effort to develop consensus on principles for design and conduct of oncology clinical trials that measure quality of life. These principles were not routinely incorporated into the published studies of epoetin. Consequently, it is difficult to interpret the data reported by existing studies. The hypothesis that epoetin improves quality of life has been advanced as a major rationale for its use in oncology patients. Future trials should be conducted in accordance with principles to minimize bias and to permit interpretation of the clinical significance of quality-of-life findings.

These principles include use of rigorously validated instruments that permit comparisons across trials, blinding of subjects and study personnel to treatment assignment and responses to treatment, use of a prospective plan to minimize and handle missing data, and prospective identification of primary quality-of-life outcomes and the magnitude of change that is considered clinically meaningful.

- In nearly all trials, a substantial percentage of patients did not achieve a hematologic response to epoetin. Additionally, nonresponding patients may account for much of the transfusion use in the epoetin arms of these trials. To achieve the most efficient use of epoetin, more systematic evidence is needed on baseline characteristics that predict responsiveness and on early indicators of response.

Efficient use of epoetin will be maximized if treatment is initiated only for those patients who are likely to respond and if treatment is discontinued as early as possible for those who will not respond. The studies included in this review reported scant data to systematically address predictors and early indicators of response. A systematic review of single-arm studies is merited and might yield more evidence to identify laboratory measurements that can either predict or permit early identification of patients whose anemia responds to epoetin. In addition, it may be feasible to collect patient level data from existing trials to create a large database for multivariate analysis.

- Evidence reviewed here shows that initial doses of epoetin in the range of 300 to 450 U/kg per week administered subcutaneously are adequate to increase Hb and reduce the percentage of patients transfused. However, the optimal initial dose within this range has not been determined. Furthermore, within this dose range we could not discern any difference in response rates between trials that used increasing dose regimens and those that used decreasing dose regimens. To achieve the most efficient use of epoetin, comparative trials are needed to establish an optimal initial dose and to determine the optimal dosing regimen.
- We found evidence that patients with MDSs respond to epoetin, although response rates are much lower than in other malignancies and higher doses of epoetin appear to be necessary. To achieve the most efficient use of epoetin, additional studies are needed to determine which patients with MDS are most likely to respond and to establish an optimal dose and dosing regimen.