# Results and Conclusions IV: Outcomes of Anemia Management Strategies in Patients Being Treated for Malignancy with Bone Marrow Ablation and Autologous Stem-Cell Support

## Objective

The objective of this systematic review is to compare the relative effects of epoetin treatment compared with effects of transfusion alone on health outcomes in patients being treated for a malignancy with high-dose, myeloablative chemotherapy followed by autologous stem-cell support (HDC/AuSCS) to repopulate the marrow. Initially, both allogeneic and autologous procedures used bone marrow as the exclusive source of stem cells. Two factors have led to much more widespread use of peripheral blood stem cells than bone marrow cells in autologous transplants. First, neutrophil and platelet engraftment occur more rapidly using stem cells mobilized into the peripheral circulation with myeloid growth factors (i.e., granulocyte colony-stimulating factor or granulocyte-macrophage colony-stimulating factor than with nonmobilized cells harvested from the marrow. Second, some have hypothesized that peripheral blood stem cells may be less contaminated with malignant cells than those harvested from the bone marrow, which could increase the likelihood of treatment success. Peripheral blood-derived stem cells are now the standard of care for autologous transplantation.

The literature search and review for studies of epoetin use after autologous transplantation identified six controlled trials (Ayash, Elias, Hunt, et al., 1994; Chao, Schriber, Long, et al., 1994; Link, Boogaerts, Fauser, et al., 1994; Locatelli, Zecca, Pedrazzoli, et al., 1994; Pene, Appelbaum, Fisher, et al., 1993; Vannucchi, Bosi, Ieri, et al., 1996). All of the studies used bone marrow as the exclusive source of stem cells except for Chao, Schriber, Long, et al. (1994), where all patients received bone marrow-derived stem cells, but patients with Hodgkin's lymphoma were additionally given peripheral blood-derived stem cells; however, outcomes were not reported separately. Although these studies of autologous transplantation do not meet the current standard of care regarding stem-cell source, it may be possible to use the results of these studies to predict the likely outcomes of epoetin therapy for patients undergoing peripheral blood stem-cell transplants. Growth-factor-mobilized peripheral blood stem cells have progressed further on the maturation pathway than have bone marrow-derived stem cells, and epoetin may not further stimulate their proliferation and differentiation. If autologous bone marrow stem cells do not respond to epoetin, it appears unlikely that peripheral blood stem cells would respond to epoetin.

In patients being treated for a malignancy with bone marrow ablation and autologous stem-cell support, this systematic review compares the outcomes of the following two alternatives for managing anemia:

1. Managing anemia after bone marrow ablation with transfusion initiated at a predefined Hb threshold (usually 7 to 10 g/dL) supplemented with epoetin treatment, beginning at the time of stem-cell infusion and continuing for a period of 4 to 8 weeks.
2. Managing anemia after bone marrow ablation with transfusion initiated at a predefined Hb threshold.

## Key Questions

1. Does managing anemia after high-dose chemotherapy and stem-cell support using epoetin (with RBC transfusion support initiated at a predefined Hb threshold) improve outcomes compared with managing anemia with RBC transfusion alone?
2. Are any characteristics of epoetin administration associated with superior outcomes? The characteristics of epoetin administration are dose, route, dosing regimen, and treatment duration.
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment?
4. What are the incidence and severity of adverse effects associated with the use of epoetin compared with the adverse effects of the transfusion alone?

## Overview of the Evidence

The literature search identified six controlled trials with a total enrollment of 321 patients (197 controls and 124 epoetin-treated patients) and a total number of 319 evaluable patients (196 controls and 123 epoetin-treated patients) that compared the outcomes of transfusion of RBCs initiated at a predefined threshold supplemented with epoetin treatment with the outcomes of RBC transfusion alone. Two of the six studies included patients undergoing either autologous or allogeneic transplants but reported outcomes separately for each group.

Of the six controlled trials, two were multicenter studies (Ayash, Elias, Hunt, et al., 1994; Link Boogaerts, Fauser, et al., 1994) and three were randomized (Chao, Schriber, Long et al., 1994; Link, Boogaerts, Fauser, et al., 1994; Vannucchi, Bosi, Ieri, et al., 1996). Nonrandomized trials compared epoetin-treated patients with historical controls. Studies ranged in size from 20 to 114 enrolled patients.

### Study Quality

Quality of study design and conduct was assessed as described in Chapter 2, Methodology, and a group of higher quality trials was identified for sensitivity analysis. These are summarized in Table 64, with higher quality trials shown in bold print and nonrandomized trials shown in italics. Only Link, Boogaerts, Fauser, et al. (1994) met the quality criteria by being randomized and double blinded and excluding fewer than 10 percent of patients from analysis (with <2:1 ratio of exclusion between study arms). This study also specified an Hb trigger for transfusions.

Table 64. Assessment of study quality^1^

Citation | Control Type | Randomized? (required) | Blinding (required) | Percentage of Excluded Subjects Below Specified Threshold? ^2^ (required) | Accounted for Excluded Patients? | Allocation Concealed? (NS=not specified) | Transfusion Trigger?
Autologous transplantation
Ayash, Elias, Hunt, et al., 1994 | Historical | No | Unblinded | No | Yes | No/NS | Yes
Chao, Schriber, Long, et al., 1994 | Concurrent, placebo | Yes | Single blinded | Yes | Yes | No/NS | Yes
Link, Boogaerts, Fauser, et al., 1994 | Concurrent, placebo | Yes | Double blinded | Yes | Yes | Yes | Yes
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Historical | No | Unblinded | No | Yes | No/NS | Yes
Pene, Appelbaum, Fisher, et al., 1993 | Historical | No | Unblinded | Yes | Yes | No/NS | Yes
Vannucchi, Bosi, Ieri, et al., 1996 | Concurrent | Yes | Unblinded | Yes | Yes | No/NS | Yes

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 Fewer than 10 percent of subjects within each study arm were excluded from the analysis AND the percentage of subjects excluded from analysis in each arm was less than a 2:1 ratio OR less than 5 percent of subjects were excluded in each study arm.

Examination of the evidence for epoetin intervention in studies of bone marrow ablation with autologous stem-cell transplantation in cancer patients will focus to a greater extent on the higher quality study. Evidence from other studies that were included in the evidence base will be examined in relation to the results of the higher quality study.

### Patient Populations

The patient population in these studies is representative of patients undergoing autologous stem-cell transplantation in clinical practice. One study enrolled pediatric patients exclusively (Locatelli, Zecca, Pedrazzoli, et al., 1994), and two studies included both pediatric and adult patients (Link, Boogaerts, Fauser, et al., 1994; Pene, Appelbaum, Fisher, et al., 1993). The upper limit of the age range was 64 years, and the mean/median age range for all but the exclusively pediatric study was 33 to 41 years.

Patients enrolled in these studies were scheduled for HDC/AuSCS; no other exclusion criteria specific to epoetin treatment were applied. Four studies enrolled patients with a variety of hematologic tumors, including acute and chronic leukemias and Hodgkin's and non Hodgkin's lymphoma (Chao, Schriber, Long, et al., 1994; Link, Boogaerts, Fauser, et al., 1994; Locatelli, Zecca, Pedrazzoli, et al., 1994; Vannucchi, Bosi, Ieri et, al., 1996). One trial included patients with either hematologic malignancies or solid tumors (Pene, Appelbaum, Fisher, et al., 1993), and one trial enrolled only patients with solid tumors (Ayash, Elias, Hunt, et al., 1994).

All studies used bone marrow as the source of stem cells; Chao, Schriber, Long, et al. (1994) supplemented bone marrow-derived stem cells with peripheral blood-derived stem cells for all patients with Hodgkin's lymphoma. Epoetin was administered intravenously in all studies, which may have been for the sake of convenience as patients were hospitalized and had established intravenous access. It has been suggested that the amount of epoetin administered to stem-cell transplant patients could be decreased without reduced effectiveness by using subcutaneous injection (Klaesson, 1999).

### Comparability of Study Arms

Some included studies were not randomized, and studies that were randomized were small. Therefore, included studies were reviewed to identify any imbalances in the treatment and control arms that might confound study results (see Chapter 2, Methodology).

Table 65 summarizes our examination of potential imbalances in study arms. None of the studies reported statistical comparisons between study arms, and publications did not report sufficient data to perform our own statistical tests. Three of six studies, including the higher quality study, were judged as having comparable study arms based on available patient data. Three autologous transplantation studies did not have sufficient data to evaluate comparability of study arms.^9^

9 In our final analysis of this systematic review, we discovered that two nonrandomized trials (Ayash, Elias, Hunt, et al., 1994; Pene, Appelbaum, Fisher, et al., 1993), which had been classified during our data abstraction process as having insufficient data to evaluate study arm comparability, were nevertheless inadvertently included in this analysis. Given the late date, we have not removed the studies from the systematic review. The results of these two studies have no impact on the conclusions of this portion of the systematic review.

Table 65. Study arm comparability^1^

Citation | Study Arm | N Enrolled | N Evaluable | Study Arms Balanced? | Assessment of Study Balance
Autologous transplantation
Ayash, Elias, Hunt, et al., 1994 | Control | 37 | 37 | Insufficient data | Estimated by reviewers
Ayash, Elias, Hunt, et al., 1994 | Epoetin | 11 | 10 | Insufficient data | Estimated by reviewers
Chao, Schriber, Long, et al., 1994 | Control | 17 | 17 | Yes | Estimated by reviewers
Chao, Schriber, Long, et al., 1994 | Epoetin | 18 | 18 | Yes | Estimated by reviewers
Link, Boogaerts, Fauser, et al., 1994 | Control | 57 | 57 | Yes | Estimated by reviewers
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | 57 | 57 | Yes | Estimated by reviewers
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | 11 | 10 | Yes | Estimated by reviewers
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | 10 | 10 | Yes | Estimated by reviewers
Pene, Appelbaum, Fisher, et al., 1993 | Control | 65 | 65 | Insufficient data | Estimated by reviewers
Pene, Appelbaum, Fisher, et al., 1993 | Epoetin | 18 | 18 | Insufficient data | Estimated by reviewers
Vannucchi, Bosi, Ieri, et al., 1996 | Control | 10 | 10 | Insufficient data | Estimated by reviewers
Vannucchi, Bosi, Ieri, et al., 1996 | Epoetin | 10 | 10 | Insufficient data | Estimated by reviewers
Total controls | | 197 | 196
Total epoetin-treated patients | | 124 | 123
Total patients | | 321 | 319
Total controls (higher quality studies) | | 74 | 74
Total epoetin-treated patients (higher quality studies) | | 75 | 75
Total patients (higher quality studies) | | 149 | 149

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

The specific elements reported to address comparability of study arms varied considerably from study to study. The elements sought to assess study arm balance, with the number of studies that reported each element, are listed in Table 66.

Table 66. Reporting on elements of study arm comparability

Element | No. | Element | No.
Type of malignancy(ies) | 3 | No. of chemotherapy cycles during study | 2
Patient age | 4 | Chemotherapy dose intensity (by platelet or neutrophil count) | 1
No. of chemotherapy regimens during study | 3 | Chemotherapy dose intensity (by platelet or neutrophil count) | 1
No. of patients with total body irradiation during study | 3

### Subpopulations of Interest

Table 67 shows the body of evidence available from studies included in this systematic review to assess outcomes in the subpopulations of interest.

Table 67. Evidence to compare subpopulations^1^

| | All Included Studies | | | Higher Quality Studies
Characteristic | Comparison Groups | Number of Studies | N Enrolled (controls+treated) | N Evaluable controls+treated) | Number of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
Autologous Transplantation
Tumor type | Hematologic | 4 | 190 (95+95) | 189 (94+95) | 2 | 149 (74+75) | 149 (74+75)
Tumor type | Solid organs and tissues | 1 | 48 (37+11) | 47 (37+10) | 0 | 0 | 0
Tumor type | Mixed | 1 | 83 (65+18) | 83 (65+18) | 0 | 0 | 0
Transplant conditioning regimen | TBI included | 5 | 273 (160+113) | 272 (159+113) | 2 | 149 (74+75) | 149 (74+75)
Transplant conditioning regimen | No TBI included | 0 | 0 | 0 | 0 | 0 | 0
Transplant conditioning regimen | TBI not specified | 1 | 48 (37+11) | 47 (37+10) | 0 | 0 | 0
Posttransplant supportive regimen | G- or GM-CSF included | 3 | 138 (92+46) | 138 (92+46) | 1 | 35 (17+18) | 35 (17+18)
Posttransplant supportive regimen | No G- or GM-CSF included | 3 | 183 (105+78) | 181 (104+77) | 1 | 114 (57+57) | 114 (57+57)
Posttransplant supportive regimen | G- or GM-CSF not specified | 0 | 0 | 0 | 0 | 0 | 0
Patient age | Adults | 4 | 280 (176+104) | 279 (176+103) | 2 | 149 (74+75) | 149 (74+75)
Patient age | Pediatric | 1 | 21 (11+10) | 20 (10+10) | 0 | 0 | 0
Patient age | Geriatric | 0 | 0 | 0 | 0 | 0 | 0
Patient age | Not specified | 1 | 20 (10+10) | 20 (10+10) | 0 | 0 | 0
Iron supplementation | Both arms supplemented | 0 | 0 | 0 | 0 | 0 | 0
Iron supplementation | Neither arm supplemented | 5 | 273 (160+113) | 272 (159+113) | 2 | 149 (74+75) | 149 (74+75)
Iron supplementation | Epoetin-treated arm only | 1 | 48 (37+11) | 47 (37+10) | 0 | 0 | 0
Iron supplementation | Neither arm specified | 0 | 0 | 0 | 0 | 0 | 0

1 All studies used bone marrow-derived stem cells.

#### Tumor type

One study (Ayash, Elias, Hunt, et al., 1994; n=48 enrolled) reported outcomes exclusively for patients with solid tumors. All other studies reported on patients with hematologic tumors or, in the case of one study, on a mixture of patients with either hematologic or solid tumors (Pene, Appelbaum, Fisher, et al., 1993).

#### Total body irradiation

TBI was included in the conditioning regimen for a proportion of patients in five of six studies (including the higher quality study) and was not specified for the sixth. For those studies using TBI, outcomes were not stratified by TBI.

#### Colony-stimulating factors

Three of six studies (including the higher quality study) administered posttransplantation G-CSF or GM-CSF and the other studies did not.

#### Age

Four of six studies (including the higher quality study) enrolled primarily adult patients up to the age of 64 or did not stratify by pediatric and adult age groups. Only one study focused exclusively on pediatric patients (Locatelli, Zecca, Pedrazzoli, et al., 1994); one study did not provide information on patient age, and it could not be inferred from any other study information; no studies enrolled geriatric patients.

#### Iron supplementation

Only one study, of lower quality and using historical controls, supplemented epoetin-treated patients with iron.

### Interventions

All studies used the intravenous route of administration. Control arms in all included studies were managed by transfusion of RBC when the Hb level fell below a defined threshold, which varied from 8 to 10 g/dL across studies.

Table 68 summarizes the studies included in this review according to the characteristics of epoetin treatment: dose, dosing regimen, and treatment duration. Evidence Tables IV-1 through IV-5 summarize the data abstracted from all six trials.

Table 68. Summary of all included studies by epoetin dose, route, regimen type, and treatment duration^1^ ^2^

Citation | Study Arm | N Enrolled | N Evaluable | Weekly Epoetin Dose | Epoetin Route | Epoetin Regimen Type | Duration of Treatment (weeks)
Autologous transplantation
Chao, Schriber, Long, et al., 1994 | Control | 17 | 17
Chao, Schriber, Long, et al., 1994 | Epoetin | 18 | 18 | 1,800 | iv | Decreasing | 4.3
Pene, Appelbaum, Fisher, et al., 1993 | Control | 65 | 65
Pene, Appelbaum, Fisher, et al., 1993 | Epoetin | 18 | 18 | 1,050 | iv | Decreasing | 4.7
Ayash, Elias, Hunt, et al., 1994 | Control | 37 | 37
Ayash, Elias, Hunt, et al., 1994 | Epoetin | 11 | 10 | 1,400 | iv | Decreasing | 4.0
Vannucchi, Bosi, Ieri, et al., 1996 | Control | 10 | 10
Vannucchi, Bosi, Ieri, et al., 1996 | Epoetin | 10 | 10 | 1,050 | iv | Fixed | 3.0
Link, Boogaerts, Fauser, et al., 1994 | Control | 57 | 57
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | 57 | 57 | 1,050 | iv | Fixed | 6.0
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | 11 | 10
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | 10 | 10 | 525 | iv | Fixed | 4.3
Total controls | | 197 | 196
Total epoetin-treated patients | | 124 | 123
Total patients | | 321 | 319
Total controls (higher quality studies) | | 74 | 74
Total epoetin-treated patients (higher quality studies) | | 75 | 75
Total patients (higher quality studies) | | 149 | 149

1 All studies used bone marrow-derived stem cells.

2 "Higher quality" trials in bold font ; nonrandomized studies in italics.

Three studies used decreasing dose regimens (n=165), administering epoetin at a beginning weekly dose of 1,050 to 1,800 U/kg. Patients were treated with epoetin until Hb levels reached a predetermined value without transfusion support or up to a maximum 4.0 to 4.7 weeks. None of these studies was identified as higher quality, and two used historical controls (Ayash, Elias, Hunt, et al., 1994; Pene, Appelbaum, Fisher, et al., 1993).

Three studies used fixed dose regimens (n=154), administering epoetin at a beginning weekly dose of 525 to 1,050 U/kg. Patients were treated until unsupported Hb reached a predetermined value, or up to a maximum of 3 to 6 weeks. One of these studies was identified as higher quality (Link, Boogaerts, Fauser, et al., 1994); one used historical controls (Locatelli, Zecca, Pedrazzoli, et al., 1994).

One study (Chao, Schriber, Long, et al., 1994) administered epoetin for 3 weeks, discontinued at myeloablation for 1 week, then reinitiated epoetin on the day of stem-cell infusion.

### Outcomes of Interest

Administration of exogenous epoetin beginning on the day of stem-cell infusion is intended as posttransplantation support to shorten the RBC engraftment time. In general, accelerated hematopoietic recovery of all cell lines would reduce the need for RBC transfusions and platelet transfusions, lower the risk of infection, and shorten hospitalization. For these reasons, patients are all selected by virtue of the HDC/AuSCS procedure, and administration of epoetin begins at the same time for all patients. Relevant questions relate to the effect of epoetin treatment on clinical outcomes and the most effective dose, route of delivery, dosing regimen, and duration of treatment. The primary outcomes of interest are time to RBC engraftment, number of RBC transfusions per patient, days hospitalized, and adverse effects.

Because all successful transplant patients will experience hematopoietic recovery, earlier RBC engraftment with epoetin treatment compared with no epoetin is an indicator of effectiveness; RBC engraftment is defined in the study protocols as achievement of a specified Hb level (7 to 12 g/dL) unsupported by RBC transfusion. Time to RBC engraftment was reported by three of six included studies (Table 69).

Table 69. Outcomes reported for epoetin treatment in autologous transplantation studies

Outcome | No. of Studies | N Enrolled (controls+treated) | N Evaluated (controls+treated)
Autologous transplantation
Percent of patients with RBC engraftment | 2 | 162 (94+68) | 161 (94+67)
Time to RBC engraftment by Hb level | 3 | 182 (104+78) | 181 (104+77)
Reticulocyte measure | 4 | 190 (95+95) | 189 (94+95)
RBC units transfused/patient | 6 | 321 (197+124) | 319 (196+123)
Days in hospital | 1 | 83 (65+18) | 83 (65+18)

Four of six included studies reported a reticulocyte measure as a primary or supplemental measure of RBC engraftment. Reticulocytes are nonnucleated, immature RBCs; their release from the bone marrow into the blood stream is an indicator of bone marrow engraftment of erythroid precursors. However, reported reticulocyte measures differed considerably across studies and included maximum reticulocyte count, reticulocyte count at a specific number of days after stem-cell transplantation, and days to a specified absolute reticulocyte number or to a specified percentage of reticulocytes. Lack of a consistent measure made it difficult to compare this outcome across studies. Agreement is needed on the reticulocyte measure that is the best indicator of engraftment.

It is expected that all stem-cell transplant patients will require transfusion support immediately after stem-cell infusion. Therefore, the related outcome of interest is the number of RBC units transfused per patient rather than the proportion of patients transfused. Reduction in units transfused reduces exposure to adverse events from transfusion. All studies reported mean or median RBC units transfused per patient during the posttransplantation monitoring period. It is possible that earlier RBC engraftment and reduced need for transfusion could reduce the time of hospital stay, although RBC hematopoiesis is not likely to be the limiting factor for recovery in this patient population. Only one study reported on days in hospital.

Adverse events resulting from epoetin administration that would significantly impact recovery are of interest. In particular, the number of platelet transfusions or units transfused is of interest for monitoring any possible depressive effect of epoetin on other cell lineages (a possible positive effect on platelet recovery has also been suggested). Four of six studies reported mean or median platelet units transfused per patient.

Table 69 summarizes the studies included in this systematic review that report on various outcomes of interest. In particular, the higher quality study reports time to RBC engraftment, maximum reticulocyte count, and number of RBC units transfused per patient. Table 70 summarizes reporting on adverse events by the studies included in this review.

Table 70. Adverse events reported by studies on patients being treated for malignancy

Adverse Event | No. of Studies Reporting | N evaluated (controls+treated)
Autologous transplantation
Any adverse effect (each patient counted once only) | 2 | 55 (27+28)
Hypertension (highest freq. if systolic/diastolic separated) | 2 | 134 (67+67)
Deep vein thrombosis or thromboembolism | 1 | 35 (17+18)
Hemorrhage and/or thrombocytopenia | 1 | 35 (17+18)
Skin rash, irritation, and/or pruritus | 0 | −
Seizures | 0 | −
Injection site pain | 0 | −
Fatigue | 0 | −
Withdrawals (due to adverse events) | 1 | 35 (17+18)
Mortality (from any cause, while on study) | 1 | 35 (17+18)

## Results

### Outcomes of Epoetin Treatment

Tables 71 and 72 detail RBC engraftment, transfusion, and hospitalization outcomes, ordered by weekly epoetin dose. Higher quality studies are shown in bold print; nonrandomized trials are italicized. Evidence Tables IV-1 through IV-5 summarize in detail the data abstracted from all six trials.

Table 71. RBC engraftment outcomes ordered by dose^1^ ^2^

Citation | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable Patients | Time to Engraftment (days ± SD) | p Value | Reticulocyte Measurement Reported | Reticulocyte Result ±SD | p Value
Autologous transplantation
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control (historical) | | 10 | | | Reticulocyte count at day 30 after transplant | 40.1+/−23.9 x 10^9^/L
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO | 525 | 10 | | | Reticulocyte count at day 30 after transplant | 42.0+/−26.5 x 10^9^/L | NS
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | 10 | 28.8 (mean) +/−13.2 | | Days to reticulocytes > 30 x 10^9^/L | 26.4+/−9.9 days
Vannucchi, Bosi, Ieri, et al., 1996 | EPO | 1,050 | 10 | 36.7 (mean) +/−20.8 | NS | Days to reticulocytes > 30 x 10^9^/L | 15.3+/−3.5 days | <0.05
Pene, Appelbaum, Fisher, et al., 1993 | Control (historical) | | 65
Pene, Appelbaum, Fisher, et al., 1993 | EPO | 1,050 | 18
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 57 | 27 (median) | | Maximum reticulocyte count | 15 x 10^9^/L
Link, Boogaerts, Fauser, et al., 1994 | EPO | 1,050 | 57 | 24 (median) | 0.77 | Maximum reticulocyte count | 30 x 10^9^/L | NS
Ayash, Elias, Hunt, et al., 1994 | Control (historical) | | 37 | 57 (median)
Ayash, Elias, Hunt, et al., 1994 | EPO | 1,400 | 10 | 24 (median) | 0.001
Chao, Schriber, Long, et al., 1994 | Placebo control | | 17 | | | Maximum reticulocyte count | 13 (7-29) x 10^9^/L
Chao, Schriber, Long, et al., 1994 | EPO | 1,800 | 18 | | | Maximum reticulocyte count | 22 (3-83) x 10^9^/L | 0.48

1 All studies used bone marrow-derived stem cells.

2 "Higher quality" trials in bold font ; nonrandomized studies in italics.

Table 72. Transfusion and hospitalization outcomes ordered by dose^1^ ^2^

Citation | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable Patients | Mean/Median RBC Units Transfused per Patient ± SD | p Value | RBC Units Patient per 4 Wks | Days in Hospital | p Value
Autologous transplantation
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control (historical) | | 10 | 4.7 (mean) +/− 2.2 | | 4.4
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO | 525 | 10 | 4.8 (mean) +/− 1.6 | NS | 4.5
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | 10 | 4.1 (mean) +/− 2.0
Vannucchi, Bosi, Ieri, et al., 1996 | EPO | 1,050 | 10 | 3.5 (mean) +/− 2.2 | NS
Pene, Appelbaum, Fisher, et al., 1993 | Control (historical) | | 65 | 8.0 (median) | | | 27
Pene, Appelbaum, Fisher, et al., 1993 | EPO | 1,050 | 18 | 9.5 (median) | NS | | 30.5 | NS
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 57 | 7.2 (mean) +/− 5.3 | | 5
Link, Boogaerts, Fauser, et al., 1994 | EPO | 1,050 | 57 | 7.6 (mean) +/− 6.2 | NS | 5.2
Ayash, Elias, Hunt, et al., 1994 | Control (historical) | | 37 | 9.0 (median)
Ayash, Elias, Hunt, et al., 1994 | EPO | 1,400 | 10 | 7.0 (median) | NS
Chao, Schriber, Long, et al., 1994 | Placebo control | | 17 | 6.0 (median) | | 5.6
Chao, Schriber, Long, et al., 1994 | EPO | 1,800 | 18 | 8.0 (median) | 0.22 | 7.4

1 All studies used bone marrow-derived stem cells.

2 "Higher quality" trials in bold font; nonrandomized studies in italics.

### Time to RBC Engraftment

Only three of six studies, including the higher quality study, reported comparisons of mean/median time to RBC engraftment, as defined by a predetermined Hb level unsupported by transfusion. The higher quality and largest study (Link, Boogaerts, Fauser, et al., 1994) did not detect a significant difference (p=0.77) for autologous transplant patients but did report a significant difference favoring epoetin for median time to RBC engraftment in allogeneic transplant patients. Of the other two reporting studies, one detected no difference, and in fact epoetin-treated patients on average took longer to engraft (Vannucchi, Bosi, Ieri, et al., 1996). Ayash, Elias, Hunt, et al. (1994) found a significant difference between 10 epoetin-treated patients and 37 historical controls treated with the same HDC/AuSCS protocol. Lack of randomization, the use of historical controls, and a small number of epoetin-treated patients make it difficult to interpret the results of this study. There is no reason to suspect that engraftment outcomes were biased by inadequate followup. Table 73 details treatment duration and followup duration for both RBC engraftment and transfusion outcomes.

Table 73. Significant outcomes ordered by epoetin regimen type and treatment duration^1^ ^2^

Citation | Treatment Arm (weekly dose, U/kg/week) | Epoetin Regimen Type | Epoetin Treatment Duration (weeks) | Number Enrolled Patients | Number Evaluable Patients | Time to RBC Engraftment (p Value) | Engraftment Maximum Followup Duration (wks) | Reticulocyte Measure (p Value) | RBC Units Transfused per Patient (p Value) | Transfusion Maximum Followup Duration (wks)
Autologous transplantation
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | | 10 | 10
Vannucchi, Bosi, Ieri, et al., 1996 | EPO (1,050) | Fixed | 3 | 10 | 10 | NS | > 13 | <0.05 | NS | > 5
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | | 57 | 57
Link, Boogaerts, Fauser, et al., 1994 | EPO (1,050) | Fixed | 6 | 57 | 57 | 0.77 | 7 | NS | NS^3^ | 14
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | | | 11 | 10
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO (525) | Fixed | 4.3 | 10 | 10 | | > 8 | NS | NS | 4.3
Chao, Schriber, Long et al., 1994 | Placebo control | | | 17 | 17
Chao, Schriber, Long et al., 1994 | EPO (1,800) | Decreasing | 4.3 | 18 | 18 | | > 21 | 0.48 | 0.22 | > 21
Pene, Appelbaum, Fisher, et al., 1993 | Control | | | 65 | 65
Pene, Appelbaum, Fisher, et al., 1993 | EPO (1,050) | Decreasing | 4.7 | 18 | 18 | | 10 | | NS | > 4.7
Ayash, Elias, Hunt, et al., 1994 | Control | | | 37 | 37
Ayash, Elias, Hunt, et al., 1994 | EPO (1,400) | Decreasing | 4 | 11 | 10 | 0.001 | > 13 | | NS | > 13

All studies used bone marrow-derived stem cells.

2 "Higher quality" trials in bold font; nonrandomized studies in italics.

3 Results also not significant for weeks 3 to 6.

### RBC Engraftment by Reticulocyte Measurement

Four of six included studies, including the higher quality study, reported reticulocyte measures, which were variably defined and difficult to compare across studies. The higher quality study reported maximum reticulocyte counts and found no significant difference, although the epoetin-treated arm had a higher average maximum reticulocyte count. In contrast, this study, which enrolled both autologous and allogeneic stem-cell transplant patients, reported a significant difference favoring epoetin for maximum reticulocyte count in allogeneic transplant patients. Of the other three reporting studies, two found no significant difference between study arms for either the maximum reticulocyte count (Chao, Schriber, Long, et al., 1994) or the reticulocyte count at day 30 after transplant (Locatelli, Zecca, Pedrazzoli, et al., 1994), whereas the third found a significant difference between study arms favoring epoetin for days to reticulocytes >30 x 10^9^/L. Taken together, there is insufficient evidence for a favorable effect of epoetin on reticulocyte measures. The one study to report a significant difference administered an epoetin dose of 1,050 U/kg/wk, which was not the highest dose reported. The included studies do not provide evidence to support a dose-response effect on reticulocyte outcomes.

### Transfusion Outcomes

All studies reported comparisons of control and epoetin-treatment study arms for mean/median RBC units transfused per patient, and no study reported a significant difference. Results for epoetin-treated patients were similar to and, in some cases, higher than those for control patients. The included studies do not provide evidence suggesting a beneficial effect of epoetin on this outcome. It is interesting to note that the higher quality study, which enrolled both autologous and allogeneic stem-cell transplant patients, also did not report significant outcomes for transfusion in allogeneic transplant patients.

### Days in Hospital

Only one study, not a higher quality study and one using historical controls, compared study arms regarding length of hospital stay and did not find a significant difference (Pene, Appelbaum, Fisher, et al., 1993). Thus, the included studies do not provide evidence suggesting that epoetin administration decreases hospital stay. It is likely that other aspects of HDC/AuSCS, such as infection and leukocyte engraftment, that are unaffected by epoetin treatment, are more important determinants of overall patient recovery and length of hospital stay. Therefore, this measure may be of limited relevance in this clinical situation.

### Summary

Taken together, the evidence does not support a beneficial effect of epoetin administration on patients undergoing high-dose chemotherapy and autologous bone marrow-derived stem-cell support for treatment of malignancy for RBC engraftment, RBC transfusion, or length of hospital stay outcomes. Neither is there evidence from these studies to suggest that higher epoetin doses are likely to have a beneficial effect. Nearly all patients undergoing HDC/AuSCS have had prior chemotherapy and/or irradiation, which can damage the stem-cell population. For some malignancies, the stem cells also may be altered by the underlying disease. Since the high-dose conditioning regimen most likely depletes viable erythroid progenitors in the circulation, recovery of erythropoiesis depends on growth and differentiation of reinfused stem cells. It is possible that autologous stem cells are less able to respond to epoetin than the healthy donor stem cells infused in allogeneic transplants (Henry, 1998).

### Treatment Regimen and Study Design: Effect on Outcomes

Information on epoetin dose, regimen, treatment duration, and duration of followup for engraftment and transfusion outcomes was provided in Table 73.

Epoetin was administered for a maximum of 6 weeks in one study (Link, Boogaerts, Fauser, et al., 1994) and for less than 5 weeks in all other studies. Patients were monitored for engraftment outcomes for at least 7 weeks, and in most studies longer. However, time to RBC engraftment was not significantly shorter for two of three reporting studies, including the higher quality study (Link, Boogaerts, Fauser, et al., 1994; Vannucchi, Bosi, Ieri, et al., 1996) and was significant in only one small study that used historical controls (Ayash, Elias, Hunt et al., 1994). Reticulocyte measures were not significantly different for epoetin-treated patients in three of four reporting studies; the fourth, although randomized, was a small, unblinded study (Vannucchi, Bosi, Ieri, et al., 1996).

As noted, autologous bone marrow may be affected by previous therapy for malignancy and may be less responsive to epoetin. Alternatively, or in addition, these studies administered epoetin for a relatively short period of time. As noted in the prior section, studies of epoetin in the allogeneic transplantation setting reported that epoetin administered for 6 weeks or more tended to be associated with significantly shorter RBC engraftment times. Patients receiving autologous bone marrow transplants may require longer treatment with epoetin to see an effect. However, reticulocyte measures, which tended to be significant for all allogeneic studies and which are an earlier indicator of engraftment, do not indicate any probable effect in autologous transplant studies.

There were no significant outcomes for RBC units transfused per patient; therefore, it is not possible to comment on treatment duration in relation to this outcome. Neither does outcome appear to be explained by the duration of followup, since studies reported a variety of followup durations.

There were no significant outcomes for the higher quality trial, which used a fixed regimen, and there were few significant outcomes for other trials. Since the available evidence does not show a benefit for epoetin treatment, the included studies do not provide evidence to favor a particular treatment regimen. Similarly, there is no evidence from these studies to suggest that a higher dose, within the range of doses used in these studies (525 to 1,800 U/kg/per week), is more likely to have an effect.

### Summary

Since the available evidence does not show a clear benefit for epoetin treatment, there is no evidence from these studies to favor a particular dose, treatment regimen, or treatment duration. It is possible that the treatment duration was too short to see benefit in these studies; however, reticulocyte measures give no early indication of improved RBC engraftment with epoetin treatment.

### Patient Subgroups

Few data are available to analyze the efficacy of epoetin treatment for stem-cell transplant patients in the patient subgroups identified in the objectives of this review (see section, Patient Populations, Populations of Interest). Three of the six studies of epoetin treatment of patients receiving autologous stem-cell transplants administered G- or GM-CSF to all patients after transplantation. Whether or not G/GM-CSF was used in conjunction with epoetin, almost all studies reported no significant outcomes.

One study exclusively enrolled pediatric patients (Locatelli, Zecca, Pedrazzoli, et al., 1994) but reported no significant results, findings consistent with adult patients. This study also used a much lower weekly dose than others, but for the patients in this study receiving allogeneic stem-cell transplants, this same dose was effective as measured by reticulocyte counts and for RBC units transfused per patient. There is no further information to evaluate the effect of epoetin on pediatric versus adult patients.

One study exclusively enrolled patients with solid tumors (Ayash, Elias, Hunt, et al., 1994) and reported a significantly shorter time to RBC engraftment in the epoetin study arm. However, this study used historical controls and evaluated only 10 patients in the epoetin-treated arm; the evidence is insufficient to draw conclusions about the effect of epoetin in patients with solid tumors.

### Adverse Events

Most included studies reported extensively on adverse events relating to HDC/AuSCS toxicity, but few reported on adverse events related to epoetin therapy. Presence or absence of hypertension was reported by two of six studies of autologous transplantation and, in these studies, epoetin treatment was not associated with a significantly greater incidence of hypertension (Table 74). Data collected on other potentially epoetin-related adverse events were similarly not significant for increased incidence with epoetin treatment. There do not appear to be significant adverse events associated with epoetin treatment in patients receiving autologous stem-cell transplants; however, reporting was sparse.

Table 74. Adverse events reported by studies on patients being treated for HDC/AuSCS

Adverse Event | No. of Studies Reporting | N Evaluated (controls+treated) | Percent Controls with Adverse Effects | Percent Treated with Adverse Effects | p Value ^1^
Autologous transplantation
Any adverse effect (each patient counted once only) | 2 | 55 (27+28) | 3.7 | 14.3 | 0.35
Hypertension (highest freq. if systolic/diastolic separated) | 2 | 134 (67+67) | 4.5 | 0 | 0.24
Deep vein thrombosis or thromboembolism | 1 | 35 (17+18) | 0 | 5.6 | 1.0
Hemorrhage and/or thrombocytopenia | 1 | 35 (17+18) | 0 | 5.6 | 1.0
Skin rash, irritation, and/or pruritus | 0 | −
Seizures | 0 | −
Injection site pain | 0 | −
Fatigue | 0 | −
Withdrawals (due to adverse events) | 1 | 35 (17+18) | 0 | 5.6 | 1.0
Mortality (from any cause, while on study) | 1 | 35 (17+18) | 5.9 | 11.1 | 1.0

1 Two-tailed Fisher's exact test.

Five of six studies, including the higher quality study, reported comparisons of control and epoetin-treatment study arms for mean/median platelet transfusions or units transfused per patient (Table 75). The higher quality study reported no significant difference, and only one of the other studies reported a significant difference favoring the epoetin-treated study arm (Ayash, Elias, Hunt et al., 1994). Thus, these studies provided no evidence suggesting that epoetin administration depresses platelet recovery.

Table 75. Effect of epoetin on platelet transfusion^1^ ^2^

Citation | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable Patients | Mean/Median Platelet Transfusions ^3^ or Units Transfused ^4^ per Patient (mean/median ± SD) | p Value
Autologous transplantation
Chao, Schriber, Long, et al., 1994 | Placebo Control | | 17 | 5.0 (median) ^3^
Chao, Schriber, Long, et al., 1994 | EPO | 1,800 | 18 | 10.0 (median) ^3^ | 0.14
Vannucchi, Bosi, Ieri, et al., 1996 | Control | | 10 | 7.2 (mean) +/− 3.0 ^3^
Vannucchi, Bosi, Ieri, et al., 1996 | EPO | 1,050 | 10 | 6.1 (mean) +/− 2.0 ^3^ | NS
Pene, Appelbaum, Fisher, et al., 1993 | Control | | 65
Pene, Appelbaum, Fisher, et al., 1993 | EPO | 1,050 | 18
Ayash, Elias, Hunt, et al., 1994 | Control | | 37 | 83.0 (not specified)^4^
Ayash, Elias, Hunt, et al., 1994 | EPO | 1,400 | 10 | 58.0 (not specified)^4^ | 0.05
Link, Boogaerts, Fauser, et al., 1994 | Placebo | | 57
Link, Boogaerts, Fauser, et al., 1994 | EPO | 1,050 | 57 | | NS
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | | 10 | 9.6 (mean) +/− 6.2^3^
Locatelli, Zecca, Pedrazzoli, et al., 1994 | EPO | 525 | 10 | 7.5 (mean) +/− 4.0^3^ | NS

1 All studies used bone marrow-derived stem cells.

2 "Higher quality" trials in bold font ; nonrandomized studies in italics

3 Platelet transfusion.

4 Units transfused.

## Conclusions

1. Does managing anemia after high-dose chemotherapy and autologous stem-cell support using epoetin (with RBC transfusion support initiated at a predefined Hb threshold) improve outcomes compared with managing anemia with RBC transfusion alone?
  - The evidence from included studies does not support a beneficial effect of epoetin administration on RBC engraftment, RBC transfusion, or length of hospital stay outcomes.
  - It is particularly noteworthy that two studies that used the same epoetin protocol for both allogeneic and autologous stem-cell transplant patients reported several outcomes significantly improved for allogeneic stem-cell transplant patients but not for autologous stem-cell transplant patients (Link, Boogaerts, Fauser, et al., 1994; Locatelli, Zecca, Pedrazzoli, et al., 1994).
2. Are any characteristics of epoetin administration associated with superior outcomes? The characteristics of epoetin administration are dose, route, dosing regimen, and treatment duration.
  - Since the available evidence does not show a clear benefit for epoetin treatment, there is no evidence to favor a particular dose, treatment regimen, or treatment duration.
  - Although it is possible that treatment duration was too short in all included studies to significantly improve outcomes, reticulocyte measures, an early indicator of RBC engraftment, did not indicate a probable response.
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment?
  - Epoetin did not show a beneficial effect for the entire population of patients treated in these studies. Results among the subpopulations was consistent with overall results, and no subpopulation that derived benefit from epoetin treatment could be identified.
4. What are the incidence and severity of adverse effects associated with the use of epoetin compared with the adverse affects of the transfusion alone?
  - There do not appear to be significant adverse events associated with epoetin treatment in patients receiving autologous stem-cell transplants.