# Results and Conclusions III: Outcomes of Anemia Management Strategies in Patients Being Treated for Malignancy with Bone Marrow Ablation and Allogeneic Stem-Cell Support

## Objective

In patients being treated for a malignancy with bone marrow ablation and allogeneic stem-cell support, this systematic review compares the outcomes of the following two alternatives for managing anemia.

1. Managing anemia after bone marrow ablation with transfusion initiated at a predefined Hb threshold (usually 7 to 10 g/dL) supplemented with epoetin treatment, beginning at the time of stem-cell infusion and continuing for a period of 4 to 8 weeks.
2. Managing anemia after bone marrow ablation with transfusion initiated at a predefined Hb threshold.

## Key Questions

1. Does managing anemia after high-dose chemotherapy and stem-cell support using epoetin (with RBC transfusion support initiated at a predefined Hb threshold) improve outcomes compared with managing anemia with RBC transfusion alone?
2. Are any characteristics of epoetin administration associated with superior outcomes? The characteristics of epoetin administration are dose, route, dosing regimen, and treatment duration.
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment?
4. What are the incidence and severity of adverse effects associated with the use of epoetin compared with the adverse effects of the transfusion alone?

## Overview of the Evidence

The literature search identified seven controlled trials with a total enrollment of 493 patients (258 controls and 235 epoetin-treated patients) and a total of 474 evaluable patients (250 controls and 224 epoetin-treated patients) that compared the outcomes of transfusion of RBCs initiated at a predefined threshold supplemented with epoetin treatment with the outcomes of RBC transfusion alone. Two studies included patients undergoing either autologous or allogeneic transplants but reported outcomes separately for each group; these will be included as individual studies in both the allogeneic and autologous transplant sections of this systematic review.

Of the seven controlled trials, two were multicenter studies (Biggs, Atkinson, Booker, et al., 1995; Link Boogaerts, Fauser, et al., 1994) and all but two (Link, Brune, Hubner, et al., 1993; Locatelli, Zecca, Pedrazzoli, et al., 1994) were randomized. Nonrandomized trials compared epoetin-treated patients with historical controls; these studies are indicated in italics in all tables. The largest study enrolled and evaluated 215 patients (Link, Boogaerts, Fauser, et al., 1994); all other studies enrolled fewer than 100 patients (range, 20 to 91 patients enrolled; 20 to 83 evaluable patients).

## Study Quality

Quality of study design and conduct was assessed as described in Chapter 2, Methodology, and a group of higher quality trials for sensitivity analysis was identified. These are summarized in Table 51, with higher quality trials shown in bold print and nonrandomized trials shown in italics.

Table 51. Assessment of study quality^1^

Citation | Control Type | Randomized? (required) | Blinding (required) | Percentage of Excluded Subjects Below Specified Threshold? ^2^ (required) | Accounted For Excluded Patients? | Allocation Concealed? | Transfusion Trigger?
Allogeneic transplantation
Biggs, Atkinson, Booker, et al., 1995 | Concurrent, placebo | Yes | Double blinded | Yes | Yes | No/NS | Yes
Klaesson, Ringden, Ljungman, et al., 1994a | Concurrent, placebo | Yes | Double blinded | Yes | Yes | Yes | Yes
Link, Brune, Hubner, et al., 1993 | Historical | No | Unblinded | Yes | Yes | No/Not reported | Yes
Link, Boogaerts, Fauser, et al., 1994 | Concurrent, placebo | Yes | Double blinded | Yes | Yes | Yes | Yes
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Historical | No | Unblinded | No | Yes | No/Not reported | Yes
Steegmann, Lopez, Otero, et al., 1992 | Concurrent | Yes | Unblinded | Yes | No/Not reported ^3^ | No/Not reported | Yes
Vannucchi, Bosi, Linari, et al., 1997 | Concurrent, placebo | Yes | Single blinded | Yes | Yes | No/Not reported | Yes

1 "Higher quality" trials in bold font ; nonrandomized studies in italics.

2 Fewer than 10% of subjects within each study arm were excluded from the analysis AND the percentage of subjects excluded from analysis in each arm was less than a 2:1 ratio OR less than 5% of subjects were excluded in each study arm.

3 Number enrolled by study arm not reported.

Three studies of allogeneic transplantation met the quality criteria by being randomized and double blinded and by having fewer than 10 percent of patients from analysis (with <2:1 ratio of exclusions between arms excluded). In addition, most studies reported reasons for excluding patients from evaluation of results. In general, the reasons for patient exclusions were similar; exclusions occurred in three of seven studies for death within 28 days of transplant or for development of conditions resulting in blood loss and therefore affecting Hb levels and transfusion requirements. The three studies that met quality criteria also specified an Hb trigger for transfusions.

Of the four trials not meeting the criteria for defining higher quality studies, two were randomized but not doubleblinded (Steegmann, Lopez, Otero, et al., 1992; Vannucchi, Bosi, Linari, et al., 1997), and two were not randomized and used historical controls (Link, Brune, Hubner, et al., 1993; Locatelli, Zecca, Pedrazzoli, et al., 1994). All of these studies defined a specific Hb threshold for transfusion. Locatelli, Zecca, Pedrazzoli, et al.; (1994) did not meet the quality standards for the numbers of patients excluded from analysis. Steegmann, Lopez, Otero, et al.; (1992) reported the total number of patients enrolled but not the number enrolled per study arm, therefore the number in each arm excluded from analysis could not be evaluated.

Examination of the evidence for epoetin intervention in studies of bone marrow ablation with allogeneic transplantation in cancer patients will focus primarily on the higher quality studies. Evidence from other studies that were included in the evidence base will be examined in relation to the results of higher quality studies.

### Patient Populations

The patient population in these studies is representative of patients undergoing allogeneic stem-cell transplantation in clinical practice. Two studies enrolled only adult patients (Biggs, Atkinson, Booker, et al., 1995; Vannucchi, Bosi, Linari, et al., 1997) with a total age range of 17 to 58 years. Four studies included pediatric patients (Klaesson, Ringden, Ljungman, et al., 1994a; Link, Boogaerts, Fauser, et al., 1994; Link, Brune, Hubner, et al., 1993; Steegmann, Lopez, Otero, et al., 1992) with an overall age range of 1 to 55 years and a range of mean/median ages of 25 to 37 years. Only one study focused exclusively on pediatric patients with an age range of 2 to 18 years (Locatelli, Zecca, Pedrazzoli, et al., 1994 ). Patients enrolled in these studies were scheduled for HDC/SCS; no other exclusion criteria specific to epoetin treatment were applied. Enrolled patients had a variety of hematologic tumors, including acute and chronic leukemias, lymphoma, multiple myeloma, and myelodysplastic syndrome. No trials included patients with solid tumors; patients with solid tumors undergoing HDC/SCS usually receive autologous stem-cell support.

All included studies used bone marrow as the source of stem cells, and no studies administered posttransplantation granulocyte or granulocyte/macrophage colony stimulating factors (G-CSF [filgrastim] or GM-CSF [sargramostim], respectively). Also, no studies supplemented either study arm with iron. Epoetin was administered intravenously in all studies, which may be a convenience given that patients are hospitalized and have intravenous lines available for other reasons. It has been suggested that the amount of epoetin administered to stem-cell transplant patients could be decreased without reduced effectiveness by using subcutaneous injection (Klaesson, 1999).

#### Comparability of Study Arms

Some included studies were not randomized, and studies that were randomized were small. Therefore, included studies were reviewed to identify any imbalances in the treatment and control arms that might bias study results (Table 52; see Chapter 2, Methodology). The elements abstracted to assess study arm balance, with the number of studies that reported each element, are listed in decreasing order of frequency in Table 53.

Table 52. Study arm comparability^1^

Citation | Study Arm | N Enrolled | N Evaluable | Study Arms Balanced? | Assessment of Study Balance
Allogeneic transplantation
Biggs, Atkinson, Booker, et al., 1995 | Control | 43 | 39 | Yes | Reported statistical tests
Biggs, Atkinson, Booker, et al., 1995 | Epoetin | 48 | 44
Klaesson, Ringden, Ljungman, et al., 1994a | Control | 25 | 23 | Yes | Estimated by reviewers
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin | 25 | 22
Link, Brune, Hubner, et al., 1993 | Control | 43 | 43 | Yes | Estimated by reviewers
Link, Brune, Hubner, et al., 1993 | Epoetin | 19 | 19
Link, Boogaerts, Fauser, et al., 1994 | Control | 109 | 109 | Yes | Estimated by reviewers
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | 106 | 106
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | 17 | 15 | Yes | Estimated by reviewers
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | 14 | 10
Steegmann, Lopez, Otero, et al., 1992 | Control | 11 | 11 | Yes | Reported statistical tests
Steegmann, Lopez, Otero, et al., 1992 | Epoetin | 13 | 13
Vannucchi, Bosi, Linari, et al., 1997 | Control | 10 | 10 | Yes | Estimated by reviewers
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin | 10 | 10
Total controls | | 258 | 250
Total epoetin-treated patients | | 235 | 224
Total patients | | 493 | 474
Total controls (higher quality studies) | | 187 | 181
Total epoetin-treated patients (higher quality studies) | | 189 | 182
Total patients (higher quality studies) | | 376 | 363

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

Table 53. Reporting on elements of study arm comparability

Element | No. | Element | No.
Type of malignancy(ies) | 7 | No. of chemotherapy cycles during study | 2
Patient age | 7 | Chemotherapy dose intensity (by platelet or neutrophil count) | 2
No. of chemotherapy regimens during study | 7 | Chemotherapy dose intensity (by platelet or neutrophil count) | 2
No. of patients with total body irradiation during study | 6

The specific elements available to address comparability of study arms varied considerably from study to study. Only two studies, one higher quality, reported a statistical comparison of patient characteristics by study arm. All seven studies were judged as having comparable study arms based on available patient data.

#### Subpopulations of Interest

This systematic review sought evidence from the studies included to compare outcomes of anemia management strategies in several subpopulations of interest. Table 54 shows the body of evidence available from studies included in this systematic review to assess outcomes in the subpopulations of interest.

Table 54. Evidence on subpopulations

| | All Included Studies | | | Higher Quality Studies
Characteristic | Comparison Groups | Number of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated) | Number of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
Allogeneic transplantation
Transplant conditioning regimen | TBI included (20-74%) | 6 | 402 (215+187) | 391(211+180) | 2 | 265 (134+131) | 260 (132+128)
| No TBI included | 0 | 0 | 0 | 0 | 0 | 0
| TBI not specified | 1 | 91 (43+48) | 83 (39+44) | 1 | 91 (43+48) | 83 (39+44)
Posttransplant supportive regimen II | MTX included | 5 | 247 (132+115) | 234 (126+108) | 2 | 141 (68+73) | 128 (62+66)
| No MTX included | 1 | 31 (17+14) | 25 (15+10) | 0 | 0 | 0
| MTX not specified | 1 | 215 (109+106) | 215 (109+106) | 1 | 215 (109+106) | 215 (109+106)
Patient age | Adults | 6 | 462 (241+221) | 449 (235+214) | 3 | 356 (177+179) | 343 (171+172)
| Pediatric | 1 | 31 (17+14) | 25 (15+10) | 0 | 0 | 0
| Geriatric | 0 | 0 | 0 | 0 | 0 | 0

##### Total Body Irradiation

Total body irradiation (TBI) could decrease the likelihood of obtaining a significant response to epoetin therapy. Six of 7 studies (2 of 3 higher quality studies) used TBI as part of the conditioning regimen for transplantation.

##### Methotrexate Use

Use of methotrexate (MTX) in the regimen for prophylaxis of GVHD could decrease the likelihood of obtaining a significant response to epoetin therapy. Five of seven studies (two of three higher quality studies) included MTX in the posttransplantation supportive regimen; one higher quality study did not specify whether MTX was used (Link, Boogaerts, Fauser, et al., 1994) and one study clearly did not use MTX (Locatelli, Zecca, Pedrazzoli, et al., 1994).

##### Age

Only one study, which was not randomized and which was of lower quality, focused exclusively on the pediatric population (Locatelli, Zecca, Pedrazzoli, et al., 1994). All other studies either focused on adults between 17 and 58 years of age or included pediatric patients but had overall mean/median ages ranging from 25 to 37. Aside from the pediatric study, results were not stratified by adult and pediatric age groups.

#### Interventions

Patients in both epoetin-treated and control arms in all included studies were administered RBC transfusions when the Hb level fell below a defined threshold, which varied from 7 to 10 g/dL across studies. Table 55 summarizes the studies included in this review according to the characteristics of epoetin administration: dose, dosing regimen, and treatment duration.

Table 55. Summary of all included studies^1^ by epoetin dose, route, regimen type, and treatment duration^2^

Citation | Study Arm | N Enrolled | N Evaluable | Weekly Epoetin Dose | Epoetin Route | Epoetin Regimen Type | Duration of treatment (weeks)
Allogeneic transplantation
Biggs, Atkinson, Booker, et al., 1995 | Control | 43 | 39
Biggs, Atkinson, Booker, et al., 1995 | Epoetin | 48 | 44 | 900 | iv | Decreasing | 6.0
Klaesson, Ringden, Ljungman, et al., 1994a | Control | 25 | 23
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin | 25 | 22 | 1,400 | iv | Decreasing | 8.0
Link, Brune, Hubner, et al., 1993 | Control | 43 | 43
Link, Brune, Hubner, et al., 1993 | Epoetin | 19 | 19 | 1,050 | iv | Fixed | 7.9
Link, Boogaerts, Fauser, et al., 1994 | Control | 109 | 109
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | 106 | 106 | 1,050 | iv | Fixed | 6.0
Vannucchi, Bosi, Linari, et al., 1997 | Control | 10 | 10
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin | 10 | 10 | 3,500 | iv | Fixed | 4.3
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control | 17 | 15
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | 14 | 10 | 525 | iv | Fixed | 4.3
Steegmann, Lopez, Otero, et al., 1992 | Control | 11 | 11
Steegmann, Lopez, Otero, et al., 1992 | Epoetin | 13 | 13 | 700 | iv | Increasing for all | 4.3
Total controls | | 258 | 250
Total epoetin-treated patients | | 235 | 224
Total patients | | 493 | 474
Total controls (higher quality studies) | | 187 | 181
Total epoetin-treated patients (higher quality studies) | | 189 | 182
Total patients (higher quality studies) | | 376 | 363

1 All studies used bone marrow-derived stem cells; no studies used G- or GM-CSF.

2 "Higher quality" trials in bold font; nonrandomized studies in italics.

Two studies used decreasing dose regimens (n=128 patients evaluable), with a starting weekly dose of either 900 or 1,400 U/kg. These studies administered epoetin for a maximum duration of 6 or 8 weeks. Both studies are of higher quality (Biggs, Atkinson, Booker, et al., 1995; Klaesson, Ringden, Ljungman, et al., 1994a).

Four studies used fixed-dose regimens (n=322). Epoetin weekly doses varied considerably, ranging from 525 U/kg in a pediatrics study (Locatelli, Zecca, Pedrazzoli, et al., 1994) to 3,500 U/kg for a small study (Vannucchi, Bosi, Linari, et al., 1997). The one higher quality study in this group ( Link, Boogaerts, Fauser, et al., 1994) and a pilot study reported by the same group (Link, Brune, Hubner, et al., 1993 ) used a dose of 1,050 U/kg. Epoetin was administered over a maximum duration of 4.3 to 7.9 weeks; the higher quality study administered epoetin for a maximum of 6 weeks.

One study (Steegmann, Lopez, Otero, et al., 1992; n=24), treated patients with 700U/kg during the first week, and 1,050 U/kg during the rest of the treatment duration (4.3 weeks).

In general, higher quality studies used a moderate weekly epoetin dose (900 to 1,400 U/kg) and a longer maximum treatment duration of 6 to 8 weeks. Actual average treatment duration was not reported in these studies.

### Outcomes of Interest

Administration of exogenous epoetin beginning on the day of stem-cell infusion is intended as posttransplantation support to shorten the RBC engraftment time. In general, accelerated hematopoietic recovery of all cell lines would reduce the need for RBC transfusions and platelet transfusions, lower the risk of infection, and shorten hospitalization. For these reasons, patients are all selected by virtue of the HDC/SCS procedure, and administration of epoetin begins at the same time for all patients. Relevant questions relate to the effect of epoetin treatment on outcomes and the most effective dose, route of delivery, dosing regimen, and duration of treatment. The primary outcomes of interest are time to RBC engraftment, number of RBC transfusions per patient, day of last transfusion, days hospitalized, and adverse effects.

Because all successful transplant patients will experience hematopoietic recovery, earlier RBC engraftment with epoetin treatment compared with engraftment without is an indicator of effectiveness. RBC engraftment is defined in the study protocols as achievement of a specified Hb level (7 to 12 g/dL) unsupported by RBC transfusion. Time to RBC engraftment was reported by five of seven included studies (Table 56).

Table 56. Outcomes reported for epoetin treatment in allogeneic and autologous transplantation studies

Outcome | No. of Studies | N enrolled (controls+treated) | N evaluated (controls+treated)
Allogeneic transplantation
Percent of patients with RBC engraftment | 4 | 388 (205+183) | 380 (201+179)
Time to RBC engraftment by Hb level | 5 | 438 (230+208) | 425 (224+201)
Reticulocyte measure | 7 | 493 (258+235) | 474 (250+224)
RBC units transfused/patient | 7 | 493 (258+235) | 474 (250+224)
Day of last transfusion | 4 | 347 (187+160) | 342 (185+157)
Days in hospital | 2 | 141 (68+73) | 128 (62+66)

All included studies reported a reticulocyte measure as a primary or supplemental measure of RBC engraftment. Reticulocytes are nonnucleated, immature RBCs; their release from the bone marrow into the blood stream is an indicator of bone marrow engraftment of erythroid precursors. However, reported reticulocyte measures differed considerably across studies and included maximum reticulocyte count reticulocyte count at a specific number of days after stem-cell transplantation, or days to a specified absolute reticulocyte number or to a specified percentage of reticulocytes. Lack of a consistent measure made it difficult to compare this outcome across studies. Agreement is needed on the reticulocyte measure that is the best indicator of engraftment.

It is expected that all stem-cell transplant patients will require transfusion support immediately after stem-cell infusion. Therefore, the related outcomes of interest are the number of RBC units transfused per patient and the day of last transfusion rather than the proportion of patients transfused. Reduction in units transfused reduces exposure to the risk of adverse events from transfusion. The day of last transfusion is clinical evidence of successful RBC engraftment. All studies reported mean or median RBC units transfused per patient during the posttransplantation monitoring period. It is possible that earlier RBC engraftment and reduced need for transfusion could reduce the time of hospital stay, although RBC hematopoiesis is not likely to be the limiting factor for recovery and discharge in this patient population. Only two studies reported on days in hospital (Biggs, Atkinson, Booker, et al., 1995; Klaesson, Ringden, Ljungman, et al., 1994a).

Adverse events resulting from epoetin administration that would significantly impact recovery are of interest. In particular, the number of platelet transfusions or units transfused is of interest for monitoring any possible depressive effect of epoetin on other cell lineages (a possible positive effect on platelet recovery has also been suggested). Five of seven studies reported mean or median platelet units transfused per patient.

Table 56 summarizes the studies included in this systematic review that report on various outcomes of interest. Table 57 summarizes reporting on adverse events by the studies included in this review.

Table 57. Adverse events reported by studies on patients being treated for malignancy

Adverse Event | No. of Studies Reporting | N evaluated (controls+treated)
Allogeneic transplantation
Any adverse effect (each patient counted once only) | 0 | -
Hypertension (highest freq. if systolic/diastolic separated) | 5 | 334 (170+164)
Deep vein thrombosis or thromboembolism | 1 | 20 (10+10)
Hemorrhage and/or thrombocytopenia | 1 | 50 (25+25)
Skin rash, irritation, and/or pruritus | 0 | -
Seizures | 0 | -
Injection site pain | 0 | -
Fatigue | 0 | -
Withdrawals (due to adverse events) | 2 | 74 (36+38)
Mortality (from any cause while on study) | 1 | 50 (25+25)

## Results

### Outcomes of Epoetin Treatment

Tables 58 and 59 detail RBC engraftment, transfusion outcomes, and days of hospitalization ordered by weekly epoetin dose. Higher quality studies are shown in bold print; nonrandomized trials are italicized. Evidence Tables III-1 to III-4 summarize in detail the data abstracted from all seven trials.

Table 58. RBC engraftment outcomes ordered by dose^1^ ^2^

Citation | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable Patients | Mean/Median Time to Engraftment (days ± SD) | p Value | Reticulocyte Measurement Reported | Reticulocyte Result ± SD | p Value
Allogeneic transplantation
Locatelli, Zecca, Pedrazzoli,, et al., 1994 | Control (historical) | | 15 | | | Reticulocyte count at day 30 after transplant | 107.2+/−63.4 x 10^9^/L
Locatelli, Zecca, Pedrazzoli,, et al., 1994 | Epoetin | 525 | 10 | | | Reticulocyte count at day 30 after transplant | 186.9+/−51.4 x 10^9^/L | <0.05
Steegmann, Lopez, Otero, et al., 1992 | Control | | 11 | | | Days to reticulocytes >1% | 19.5 (13-38) days
Steegmann, Lopez, Otero, et al., 1992 | Epoetin | 700 | 13 | | | Days to reticulocytes >1% | 13 (10-24) days | <0.05
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | 39 | 41 (median) | | Maximum reticulocyte count | 60 x 10^9^/L
Biggs, Atkinson, Booker, et al., 1995 | Epoetin | 900 | 44 | 26 (median) | 0.002 | Maximum reticulocyte count | 130 x 10^9^/L | <0.0005
Link, Brune, Hubner, et al., 1993 | Control (historical) | | 43 | 24 (median) | | Maximum reticulocyte count | 20 x 10^9^/L
Link, Brune, Hubner, et al., 1993 | Epoetin | 1,050 | 19 | 17 (median) | 0.015 | Maximum reticulocyte count | 92 x 10^9^/L | 0.065
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 109 | 27 (median) | | Maximum reticulocyte count | 52 x 10^9^/L
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | 1,050 | 106 | 19 (median) | 0.003 | Maximum reticulocyte count | 155 x 10^9^/L | <0.05
Klaesson, Ringden, Ljungman, et al., 1994a | Placebo control | | 23 | 24 (mean) | | Days to reticulocytes >0.2% | 17+/−5 days
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin | 1,400 | 22 | 14 (mean) | 0.03 | Days to reticulocytes >0.2% | 15+/−5 days | NS
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | 10 | 36.6 (mean) +/−18.1 | | Days to reticulocytes >30 x 10^9^/L | 15.5+/−2.5 days
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin | 3500 | 10 | 25.6 (mean) +/−11.1 | NS | Days to reticulocytes >30 x 10^9^/L | 11.6+/−1.6 days | <0.01

1 All studies used bone marrow-derived stem cells; no studies used G- or GM-CSF.

2 "Higher quality" trials in bold font; nonrandomized trials in italics.

Table 59. Transfusion outcomes and days in hospital ordered by dose^a^ ^2^

Citation | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable Patients | Mean/Median RBC Units Transfused per Patient ± SD | p Value | RBC Units/Patient/4 wks | Day of Last Transfusion ± SD | p Value | Days in Hospital ± SD | p Value
Allogeneic transplantation
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control (historical) | | 15 | 3.9 (mean) +/− 1.2 | | 3.6
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | 525 | 10 | 1.6 (mean) +/− 1.2 | <0.001 | 1.5
Steegmann, Lopez, Otero, et al., 1992 | Control | | 11 | 12.0 (median) | | 11.2
Steegmann, Lopez, Otero, et al., 1992 | Epoetin | 700 | 13 | 4.0 (median) | <0.05 | 3.7
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | 39 | 7.0 (mean) +/− 5.0 | | 4.7 | | | 29 +/− 8
Biggs, Atkinson, Booker, et al., 1995 | Epoetin | 900 | 44 | 6.0 (mean) +/− 5.0 | NS | 4 | | | 28 +/− 8 | NS
Link, Brune, Hubner, et al., 1993 | Control (historical) | | 43 | 9.7 (mean) +/− 6.9 | | 9 | 24 (median) (10-100)
Link, Brune, Hubner, et al., 1993 | Epoetin | 1,050 | 19 | 7.1 (mean) +/− 3.7 | 0.1 | 6.6 | 17 (median) (11-55) | 0.015
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | 109 | 8.7 (mean) +/− 6.6 | | 6 | 27 (median) (22.3- >42)
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | 1,050 | 106 | 8.0 (mean) +/− 6.1 | NS | 5.5 | 19 (median) | 0.003
Klaesson, Ringden, Ljungman, et al., 1994a | Placebo control | | 23 | 10.0 (mean) +/− 9.0 | | 5 | 30 +/− 22 | | 37
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin | 1,400 | 22 | 5.0 (mean) +/− 5.0 | 0.04 | 2.5 | 17 +/−14 | 0.03 | 35 | NS
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | 10 | 4.2 (mean) +/− 2.7 | | 3.9 | 30 +/− 15
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin | 3,500 | 10 | 2.2 (mean) +/− 2.5 | <0.05 | 2 | 15.3 +/− 7.0 | NS

1 All studies used bone marrow-derived stem cells; no studies used G- or GM-CSF.

2 "Higher quality" trials in bold font; nonrandomized trials in italics.

#### Time to RBC Engraftment

Five of seven studies reported mean or median time to RBC engraftment, defined as achieving a specified Hb level (7 to 10 g/dL) unsupported by RBC transfusion. All three higher quality studies reported significant p values for this outcome, favoring epoetin treatment. Vannucchi, Bosi, Linari, et al. (1997) detected a nonsignificant trend favoring epoetin treatment; this study was most likely underpowered to detect a significant difference (10 per study arm). The fifth study (Link, Brune, Hubner, et al., 1993) also reported a significant difference favoring epoetin treatment.

Significance values for time to engraftment were not all calculated using the same statistical method. Among higher quality studies, Link, Boogaerts, Fauser, et al. (1994) used Kaplan-Meier analysis to calculate median time to engraftment and compared study arms using the Mantel-Haenszel log rank test. Estimates derived using this method can be affected by competing events, such as transplant-related death. However, if complete data are available for all patients and all patients engraft at some time during followup, the estimate at time t should equal the proportion of patients who have engrafted by time t. In the Link, Boogaerts, Fauser, et al. (1994) study, all enrolled patients were evaluable for time to engraftment. Other higher quality studies used either the Wilcoxon-Mann-Whitney test (Biggs, Atkinson, Booker, et al., 1995) or the t-test (Klaesson, Ringden, Ljungman, et al. (1994a). As the distribution of results may not be normal, the former is preferable. Among lower quality studies reporting this outcome, Link, Brune, Hubner, et al. (1993) used Kaplan-Meier analysis and Vannucchi, Bosi, Linari, et al. (1997) used the Wilcoxon-Mann-Whitney test. Despite the variety of testing procedures, the results consistently indicate significantly shorter time to RBC engraftment for patients given epoetin than for controls.

The differences between mean or median times to engraftment vary from 8 to 15 days for higher quality studies (7 to 11 days for the lower quality studies) reporting this outcome. Thus, patients would be free of RBC transfusions 1 to 2 weeks earlier with epoetin administration. However, if not all patients engraft during the reporting period, and particularly if disproportionate numbers of patients engraft in each study arm, time to engraftment could represent a biased result. Moreover, it is difficult to compare results across studies since they use different levels of Hb to define engraftment (7 to 10 g/dL).

Three studies report percentage of patients engrafted. Two studies (Link, Brune, Hubner, et al., 1993; Vannucchi, Bosi, Linari, et al., 1997) report 95 to 100 percent of patients engrafted during the study period. Link, Boogaerts, Fauser, et al. (1994) show percentage of patients engrafted (free from transfusion) at 6 weeks as 56 percent for controls and 79 percent for epoetin-treated patients when time to engraftment was analyzed. However, as all patients were followed for 100 days and evaluated for transfusion support during this time, it appears that all patients survived to 100 days and most likely engrafted. Final evaluation of time to engraftment might reveal an even greater difference between treatment arms in this study. There is no reason to suspect that not all evaluable patients engrafted in the other studies not reporting this outcome, and there is no reason to suspect that RBC engraftment results are biased by lack of adequate followup. Table 60 contains detail on treatment duration and followup duration for both RBC engraftment and transfusion outcomes.

Table 60. Significant outcomes ordered by epoetin regimen type and treatment duration ^1^ ^2^

Citation | Treatment Arm (weekly dose, U/kg/week) | Epoetin Regimen Type | Epoetin Treatment Duration (weeks) | Number Enrolled Patients | Number Evaluable Patients | Time to RBC Engraftment (p Value) | Reticulocyte measure (p Value) | Engraftment Maximum Followup Duration (wks.) | RBC Units Transfused per Patient (p Value) | Transfusion Maximum Followup Duration (wks.)
Allogeneic transplantation
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | | 43 | 39
Biggs, Atkinson, Booker, et al., 1995 | Epoetin (900) | Decreasing | 6 | 48 | 44 | 0.002 | <0.0005 | 6 | NS | 6
Klaesson, Ringden, Ljungman, et al., 1994a | Placebo control | | | 25 | 23
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin (1,400) | Decreasing | 8 | 25 | 22 | 0.03 | NS | 8 | 0.04 | 8
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | | 10 | 10
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin (3,500) | Fixed | 4.3 | 10 | 10 | NS | <0.01 | >6 | <0.05 | 4.3
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control (historical) | | | 17 | 15
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin (525) | Fixed | 4.3 | 14 | 10 | | <0.05 | >8 | <0.001 | 4.3
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | | | 109 | 109
Link, Boogaerts, Fauser, et al., 1994 | Epoetin (1,050) | Fixed | 6 | 106 | 106 | 0.003 | <0.05 | 7 | NS^3^ | 14
Link, Brune, Hubner, et al., 1993 | Control (historical) | | | 43 | 43
Link, Brune, Hubner, et al., 1993 | Epoetin (1,050) | Fixed | 7.9 | 19 | 19 | 0.015 | 0.065 | > 14 | 0.10 | 4.3
Steegmann, Lopez, Otero, et al., 1992 | Control | | | 11 | 11
Steegmann, Lopez, Otero, et al., 1992 | Epoetin (700) | Increasing for all | 4.3 | 13 | 13 | | <0.05 | > 13 | <0.05 | 4.3

1 All studies used bone marrow-derived stem cells; no studies used G- or GM-CSF.

2 "Higher quality" trials in bold font; nonrandomized studies in italics.

3 p=0.04 for weeks 3-6.

#### RBC Engraftment by Reticulocyte Measurement

Two of three higher quality studies found significant differences in reticulocyte measures favoring the epoetin-treated study arm. The third study (Klaesson, Ringden, Ljungman, et al., 1994a) found no significant difference between study arms for days to reticulocytes >0.2 percent or for absolute reticulocyte counts at 1 or 2 months, although this study did reveal a significant difference between study arms for time to engraftment. Of the lower quality studies, three of four showed significant differences, and the fourth (Link, Brune, Hubner, et al., 1993) showed a near-significant trend (p=0.065), all favoring epoetin. Thus, the majority of studies found a significant difference favoring epoetin in their chosen reticulocyte measure, consistent with time to RBC engraftment (by unsupported Hb value) results. However, reticulocyte results cannot be compared across studies because of the high variability in the measure reported, making this a less useful outcome measure. There appears to be no agreement on the best reticulocyte measure to indicate engraftment.

#### Transfusion Outcomes

Four studies, two of them higher quality studies (Klaesson, Ringden, Ljungman, et al., 1994a; Link, Boogaerts, Fauser, et al., 1994) reported day of last transfusion. Results significantly favored the epoetin-treated study arm in three reporting studies; the fourth (Vannucchi, Bosi, Linari, et al., 1997) enrolled only 20 patients and found a trend in favor of epoetin treatment that did not reach significance. These results are related to and correlate with time to engraftment as measured by Hb level unsupported by transfusion.

All studies reported mean/median RBC units transfused per patient, and in all studies the result was lower for the epoetin-treated study arm. However, only one of three higher quality studies reported a statistically significant difference (Klaesson, Ringden, Ljungman, et al., 1994a), and this was the smallest study of the three. The largest study (Link, Boogaerts, Fauser, et al., 1994) found no significant difference over the entire followup period of 100 days (maximum treatment duration, 42 days after stem-cell infusion) but did find a significant difference during days 21 to 42 (p=0.004). Biggs, Atkinson, Booker, et al.; (1995) did not find a significant difference for either the study duration or for the intervals of 0 to 14, 15 to 28, or 29 to 42 days. In higher quality studies, control patients received on average between 4 and 10 RBC units. In the one higher quality study reporting a significant result, RBC units per patient decreased from 10 units in the controls to 5 units in epoetin-treated patients. In the higher quality studies that reported nonsignificant results, the decrease was approximately 1 RBC unit. Of the four lower quality studies, three found significant differences and one did not, with number of RBC units per patient decreased by 2 to 3 units in three studies and by eight units in the fourth.

Overall, results suggest that epoetin treatment shortens the time to the last transfusion, providing clinical evidence of earlier engraftment. In addition, epoetin may decrease the number of RBC units transfused per patient. The range of decrease reported in these studies was 1 to 5 units. However, not all studies resulted in a significant decrease, and it is not known if the average decrease lies within this range or if there is no true difference in transfusion requirements.

#### Days in Hospital

Only two studies compared days in hospital for control and epoetin-treated study arms and both were higher quality studies, although not large ones (Biggs, Atkinson, Booker, et al., 1995; Klaesson, Ringden, Ljungman, et al., 1994a). Neither found a significant difference or evidence of a trend. Although limited, the available evidence suggests that epoetin treatment has no significant effect on length of hospital stay. It is likely that other aspects of HDC/SCS, such as graft-versus-host disease, infection, and leukocyte engraftment that cannot be ameliorated by epoetin treatment, are more important determinants of overall patient recovery and length of hospital stay.

#### Summary

There is consistent evidence, particularly among higher quality trials, that epoetin administration to patients undergoing high-dose chemotherapy and allogeneic bone marrow-derived stem-cell support for treatment of malignancy significantly shortens time to RBC engraftment, as indicated by achievement of a predetermined Hb level independent of transfusion support. This is supported by significantly shorter times to last transfusion in four reporting studies. On average, patients in these studies were free of RBC transfusions 1 to 2 weeks earlier with epoetin administration. Various measures of reticulocytes, which tend to predict RBC engraftment, also suggest more rapid engraftment with epoetin administration. The evidence regarding RBC transfusion requirements is less clear. Results from different, higher quality studies suggest that epoetin treatment may decrease the number of RBC units transfused per patient. Finally, limited evidence suggests that epoetin treatment has no significant effect on length of hospital stay.

### Treatment Regimen and Study Design: Effect on Outcomes

Information on epoetin dose, regimen, treatment duration, and duration of followup for engraftment and transfusion outcomes was provided in Table 60.

Although all studies administer epoetin over a relatively short duration, those treating for only 4.3 weeks (three studies) appear to be distinct in several respects. None were higher quality studies; all enrolled small numbers of patients. Two of these studies did not report time to RBC engraftment outcomes by Hb level or time to last transfusion (Locatelli, Zecca, Pedrazzoli, et al., 1994; Steegmann, Lopez, Otero, et al., 1992), and the third reported nonsignificant comparisons between control and epoetin-treated study arms for both outcomes (Vannucchi, Bosi, Linari, et al., 1997). The duration of followup for this outcome extended well beyond the duration of treatment in all studies and does not appear to explain the lack of results. Low study power may at least partially explain the lack of significant comparisons. All studies did monitor reticulocytes in some way, and all found significant differences between study arms for the measure chosen; however, the variability in reticulocyte measurements reported prevents comparison across studies. All studies found significant differences between control and epoetin-treated arms for transfusion outcomes.

In contrast, among studies administering epoetin for 6 or more weeks (four studies), three were higher quality and included the two largest studies. All found a significant difference between study arms for time to RBC engraftment by Hb level. Two of four studies reported no differences between study arms for reticulocyte outcomes; however, this may reflect the variety of measures chosen across studies. In this group of studies, three monitored transfusion requirements for at least 6 weeks, and two studies reported no significant differences between study arms for transfusion outcomes (Biggs, Atkinson, Booker, et al., 1995; Link, Boogaerts, Fauser, et al., 1994); the third study barely attained significance at p=0.04 (Klaesson, Ringden, Ljungman, et al., 1994a). However, Link, Boogaerts, Fauser, et al. (1994) also reported outcomes for 3 to 6 weeks postinfusion and reported a highly significant difference in RBC units transfused (p=0.004). Biggs, Atkinson, Booker, et al. (1995) also reported transfusion outcomes for 2 to 4 weeks and 4 to 6 weeks after transplantation but did not find significant differences for either interval. Link, Brune, Hubner, et al. (1993) did not report a significant difference for transfusion outcomes after 4.3 weeks, but this study used historical controls making comparisons more difficult. Link and colleagues (1994) and Klaesson and colleagues (1994a) reported significantly shorter time to last transfusion for the epoetin-treated arm.

Thus, it is possible that RBC engraftment outcomes are related to treatment duration; statistically significant differences in outcomes are associated with epoetin treatment durations of 6 weeks or more. It should be noted that the treatment duration abstracted from included studies was the maximum treatment time; patients who achieved a predetermined Hb level without transfusion support had epoetin discontinued in most studies. Therefore, treatment duration in reality is variable across studies, and it is not possible to identify a minimum necessary treatment time for complete epoetin benefits. In addition, studies treating for a shorter time also tended to be underpowered for detecting significant differences in outcomes.

Transfusion outcomes may also be associated with treatment duration, with longer treatment duration more often associated with nonsignificant outcomes. However, this may also be related to followup duration. During the early posttransplant period, allogeneic cells are relatively healthy and able to respond to elevated epoetin levels (Henry, 1998). After about 30 days, however, bone marrow may be affected by developing graft-versus-host disease, and the need for RBC transfusions may increase. Therefore, studies that evaluate RBC transfusions per patient during a posttransplant period of 4 to 6 weeks may be more likely to detect an effect of epoetin treatment, whereas transfusion evaluation over a longer period of time may in some studies be affected by patients with graft-versus-host disease and increased need for transfusion, regardless of erythropoietin levels. Thus, because transfusion requirements are not reported for the same followup duration across studies, it is hard to draw firm conclusions about the effect of epoetin on transfusion outcomes.

Dose appears to be a less influential factor than treatment and followup duration. Two studies administered extremes of dose (525 U/kg per week, Locatelli, Zecca, Pedrazzoli, et al., 1994; 3,500 U/kg per week, Vannucchi, Bosi, Linari, et al., 1997) and reported similar results. Both of these studies used a fixed delivery regimen. The other five studies used moderate doses either increasing from 700 U/kg per week (Steegmann, Lopez, Otero, et al., 1992), fixed at 1,050 U/kg per week (Link, Brune, Hubner, et al., 1993), or decreasing from 900 U/kg per week (Biggs, Atkinson, Booker, et al., 1995) or from 1,400 U/kg per week (Klaesson, Ringden, Ljungman, et al., 1994a).

#### Summary

Epoetin dose and regimen of administration do not appear to significantly influence outcomes, and low to moderate doses appear to have no less effect than higher doses. Short epoetin treatment duration (<6 weeks), however, may be insufficient to realize significantly shorter times to engraftment. Transfusion outcomes are difficult to compare across studies, as the duration of followup for reporting and statistical comparison between study arms may influence the result. Epoetin may have a detectably beneficial effect within 4 to 6 weeks, but after that time calculation of the effect may be influenced by patients requiring transfusions for graft-versus-host disease.

### Patient Subgroups

Few data are available to analyze the efficacy of epoetin treatment for stem-cell transplant patients in the patient subgroups identified in the objectives of this review (see Sections Patient Populations, Populations of Interest). Table 61 shows the significance of outcomes ordered by the percentage of patients in each arm given total body irradiation as part of the conditioning regimen. Significant outcomes do not appear to be associated with the use of TBI in a decreasing percentage of patients.

Table 61. Outcomes of epoetin treatment vs. control by use of total body irradiation and methotrexate use^1^ ^2^

Citation | Treatment Arm | TBI? (% of patients treated) | Methotrexate use? | N Enrolled | N Evaluable | Time to Engraftment p Value | Reticulocyte Measure p Value | RBC Units Transfused p Value
Allogeneic transplantation
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | Not specified | Yes | 43 | 39
Biggs, Atkinson, Booker, et al., 1995 | Epoetin | Not specified | Yes | 48 | 44 | 0.002 | <0.0005 | NS
Steegmann, Lopez, Otero, et al., 1992 | Control | Some (?) | Yes | 11 | 11
Steegmann, Lopez, Otero, et al., 1992 | Epoetin | Some (?) | Yes | 13 | 13 | | <0.05 | <0.05
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control (historical) | Some (?) | No | 17 | 15
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | Some (?) | No | 14 | 10 | | <0.05 | <0.001
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | Some (20%) | Yes | 10 | 10
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin | Some (20%) | Yes | 10 | 10 | NS | <0.01 | <0.05
Link, Brune, Hubner, et al., 1993 | Control (historical) | Some (51%) | Yes | 43 | 43
Link, Brune, Hubner, et al., 1993 | Epoetin | Some (40%) | Yes | 19 | 19 | 0.015 | 0.065 | 0.10
Klaesson, Ringden, Ljungman, et al., 1994a | Placebo control | Some (64%) | Not specified | 25 | 23
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin | Some (56%) | Not specified | 25 | 22 | 0.03 | NS | 0.04
Link, Boogaerts, Fauser, et al., 1994 | Placebo control | Some (71%) | Yes | 109 | 109
Link, Boogaerts, Fauser, et al., 1994 | Epoetin | Some (74%) | Yes | 106 | 106 | 0.003 | <0.05 | NS

1 All studies used bone marrow-derived stem cells; no studies used G- or GM-CSF.

2 "Higher quality" trials in bold font; nonrandomized studies in italics.

Locatelli, Zecca, Pedrazzoli, et al. (1994) conducted a small study of epoetin in pediatric transplant patients (age range, 2 to 18 years; n=25 enrolled), comparing treated patients with historical controls. This study also used the lowest dose per body mass of all studies. Although this study does not meet higher quality criteria, results were significant and in favor of epoetin treatment for all outcomes reported (reticulocytes, RBC, and platelet transfusions).

Methotrexate was used for prophylaxis of graft-versus-host disease in five of seven studies; one study did not specify use (Link, Boogaerts, Fauser, et al., 1994), and one study did not use methotrexate (Locatelli, Zecca, Pedrazzoli, et al., 1994). Methotrexate use and outcomes are shown in Table 61. Studies using methotrexate showed significantly improved outcomes for the epoetin treatment arm. Therefore, the use of methotrexate does not appear to preclude benefit from epoetin.

### Adverse Events

Most included studies reported extensively on adverse events relating to HDC/SCS toxicity, but few reported on adverse events related to epoetin therapy. This could be because the adverse events we abstracted did not occur frequently in this population or because they were much less severe than transplant-associated adverse events. Presence or absence of hypertension was reported most often, by five of seven studies of allogeneic transplantation. Epoetin was not associated with a significantly greater incidence of hypertension (Table 62). Data collected on other potentially epoetin-related adverse events were similarly not significant for increased incidence with epoetin treatment. There do not appear to be significant adverse events associated with epoetin treatment in patients receiving allogeneic stem-cell transplants; however reporting was sparse.

Table 62. Adverse events reported by studies on patients being treated for HDC/SCS

Adverse Event | No. of Studies Reporting | N Evaluated (controls+treated) | Percent Controls with Adverse Effects | Percent Treated with Adverse Effects | p Value ^1^
Allogeneic Transplantation
Any adverse effect (each patient counted once only) | 0 | --
Hypertension (highest freq. if systolic/diastolic separated) | 5 | 334 (170+164) | 4.1 | 7.3 | 0.24
Deep vein thrombosis or thromboembolism | 1 | 20 (10+10) | 0 | 0 | 1.0
Hemorrhage and/or thrombocytopenia | 1 | 50 (25+25) | 36 | 36 | 1.0
Skin rash, irritation, and/or pruritus | 0 | --
Seizures | 0 | --
Injection site pain | 0 | --
Fatigue | 0 | --
Withdrawals (due to adverse events) | 2 | 74 (36+38) | 0 | 18.4 | 0.01
Mortality (from any cause, while on study) | 1 | 50 (25+25) | 20 | 24 | 0.70

1 Two-tailed Fisher's exact test.

Data on platelet transfusions or units transfused per patient were also collected (Table 63) to determine whether or not epoetin might depress the recovery of other cell lineages. It is also possible that epoetin could improve platelet engraftment times because of hypothesized effects on other cell lineages. All three higher quality studies reported comparisons between control and epoetin-treated study arms for mean/median platelet transfusions or units transfused per patient, and none found a significant difference. Two of three lower quality studies did report a significant difference; however, patients in the epoetin-treated arm required fewer (rather than more) platelet unit transfusions. Thus, epoetin does not appear to depress platelet engraftment and higher quality studies do not indicate a significant improvement

Table 63. Effect of epoetin on platelet transfusion^1^

Citation | Treatment Arm | Weekly Dose (U/kg) | Number Evaluable Patients | Mean/Median Platelet Transfusions ^2^ or Units Transfused per Patient ^3^ ± SD | p Value
Allogeneic transplantation
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Control (historical) | | 15 | 7.3^2^ (mean) +/− 5.2
Locatelli, Zecca, Pedrazzoli, et al., 1994 | Epoetin | 525 | 10 | 4.0^2^ (mean) +/− 2.3 | <0.05
Steegmann, Lopez, Otero, et al., 1992 | Control | | 11 | 138.5 ^3^ (median)
Steegmann, Lopez, Otero, et al., 1992 | Epoetin | 700 | 13 | 36.0 ^3^ (median) | <0.05
Biggs, Atkinson, Booker, et al., 1995 | Placebo control | | 39 | 11.0^2^ (mean) +/− 7.0
Biggs, Atkinson, Booker, et al., 1995 | Epoetin | 900 | 44 | 11.0^2^ (mean) +/− 9.0 | NS
Klaesson, Ringden, Ljungman, et al., 1994a | Placebo control | | 23 | 17.0^3^ (mean) +/− 15.0
Klaesson, Ringden, Ljungman, et al., 1994a | Epoetin | 1400 | 22 | 16.0^3^ (mean) +/− 12.0 | NS
Vannucchi, Bosi, Linari, et al., 1997 | Placebo control | | 10 | 5.7 ^2^ (mean) +/− 2.8
Vannucchi, Bosi, Linari, et al., 1997 | Epoetin | 3,500 | 10 | 4.5 ^2^ (mean) +/− 1.8 | NS

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 Platelet transfusions.

3 Units transfused.

## Conclusions

The evidence concerning the use of epoetin after high-dose chemotherapy and allogeneic stem-cell transplantation is derived from studies of patients who are representative of those undergoing bone marrow-derived allogeneic stem-cell transplantation in clinical practice. The overall age range was 1 to 58 years; the range of mean/median ages was 9.7 to 37 with only one study exclusively enrolling pediatric patients. Enrolled patients had a variety of hematologic tumors. All studies used bone marrow as the stem-cell source, and all studies administered epoetin intravenously.

1. Does managing anemia after high-dose chemotherapy and allogeneic stem-cell support using epoetin (with RBC transfusion support initiated at a predefined Hb threshold) improve outcomes compared with managing anemia with RBC transfusion alone?
  - Epoetin consistently results in a statistically significant decrease in the time to RBC engraftment, as indicated by achievement of a predetermined Hb level independent of transfusion support. The range of reduction reported was 1 to 2 weeks.
  - Reticulocyte measures, which tend to predict RBC engraftment, also suggest more rapid engraftment with epoetin administration. However, because reticulocyte measures were highly variable across studies, this outcome measure was less useful.
  - Outcomes for day of last transfusion are related to and correlate with RBC engraftment by Hb level results, significantly favoring the epoetin-treated study arm.
  - Epoetin administration is unlikely to spare anyone from transfusions, as recipients of HDC/SCS are uniformly anemic following the procedure and response to erythropoetin, whether endogenous or exogenous, is not immediate. The evidence suggests that epoetin treatment may decrease the number of RBC units transfused.
  - Limited evidence suggests that epoetin treatment has no significant effect on length of hospital stay.
2. Are any characteristics of epoetin administration associated with superior outcomes? The characteristics of epoetin administration are dose, route, dosing regimen, and treatment duration.
  - RBC engraftment outcomes may be related to treatment duration; reporting and significant outcomes are associated with epoetin treatment durations of 6 weeks or more.
  - Transfusion outcomes appear to be associated with the duration of followup for reporting and statistical comparison; shorter followup is more often associated with a significant beneficial effect, whereas longer followup may be complicated by transfusions for graft-versus-host disease and result in nonsignificant outcomes for epoetin.
  - For both RBC engraftment and RBC transfusion outcomes, the evidence does not suggest that the lower doses are any less effective than the higher doses used in these studies.
  - Four of seven studies administered epoetin using a fixed and continuous regimen. Significant outcomes favoring epoetin treatment were not, however, limited to studies using this regimen. There is no pattern among the various outcomes that consistently associates significant outcomes with a particular type of epoetin treatment regimen.
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment?
  - Most studies used TBI for a percentage of patients. Significant outcomes do not appear to be associated with decreasing percentages of patients treated with TBI.
  - Although only one small study (nonrandomized, historical controls) specifically examined the use of epoetin in a pediatric population, results are consistent with those obtained in all other studies, which enrolled primarily adult populations. Additionally, significant results were obtained in this study using a dose per kilogram per week that was one-half or less the doses used in studies of adult patients.
  - In the included studies, the use of methotrexate in the pretransplant conditioning regimen does not appear to preclude positive effects of epoetin on outcomes.
4. What are the incidence and severity of adverse effects associated with the use of epoetin compared with the adverse effects of the transfusion alone?
  - There do not appear to be significant adverse events associated with epoetin treatment in patients receiving allogeneic stem-cell transplants; however reporting was sparse. The incidence of hypertension was reported most often; available evidence suggests that the incidence of hypertension in the epoetin-treated population is not significantly greater than in the control population.
  - The available evidence shows no depression of platelet engraftment with epoetin treatment.