# Results and Conclusions II: Anemia Due Primarily to Malignant Disease

## Objective

In patients who would be anemic whether or not they were receiving treatment for their malignancy, this systematic review compares the outcomes of the following alternatives for managing anemia;

1. Initiating epoetin when the level of hemoglobin (Hb) decreases to a specified threshold;
  - Hb >12 g/dL
  - Hb >10 and <12 g/dL
  - Hb <10 g/dL
2. Managing anemia without epoetin, using transfusion (usually initiated when Hb decreases to a threshold between 7 and 9 g/dL).

## Key Questions

1. What are the outcomes of managing anemia with epoetin (plus transfusion when necessary) compared with transfusion alone? What are the relative effects of epoetin treatment when different Hb thresholds are used to initiate treatment?
2. In the studies included in this review, does varying the characteristics of the administration of epoetin affect the outcomes of treatment, particularly correction of anemia? The characteristics of epoetin administration are dose, route, dosing regimen (fixed, increasing, or decreasing dose), and treatment duration. Are the characteristics of epoetin administration likely to confound the interpretation of the evidence on the relative effects of epoetin treatment when different Hb thresholds are used to initiate epoetin treatment?
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment? Are there laboratory measurements that can either predict or permit early identification of patients whose anemia is likely to respond to epoetin?
4. What are the incidence and severity of adverse effects associated with the use of epoetin and how do these compare with the adverse effects of transfusion alone?

## Overview of the Evidence

The literature search identified six controlled trials, all randomized (n=693), that enrolled anemic patients meeting the other inclusion criteria for this systematic review, regardless of whether patients were receiving concurrent cancer therapy. Three trials were placebo controlled and double blind (n=332; 48 percent), and four (n=448; 65 percent) were multicenter trials. Of the 693 patients enrolled, 648 (93.5 percent) were reported as evaluable. Throughout this section, Overview of the Evidence, "n" refers to the total number of patients enrolled. In the "Results" section, "n" refers to the number of patients evaluable.

Evidence Tables II-1 through II-6 summarize the data abstracted from all six trials. Each trial compared the outcomes of epoetin treatment (n=448 enrolled), supplemented with RBC transfusion if necessary, with the outcomes of RBC transfusion alone (n=245 enrolled) for patients with anemia due primarily to malignant disease. As shown in Evidence Table II-1, three studies specified that RBC transfusions should be given when the patient's Hb level fell below a defined threshold, and the other three trials did not report an Hb threshold for transfusion.

All patients in these studies had hematologic malignancies. There were two studies of patients with multiple myeloma (n=95), two of patients with either multiple myeloma or non-Hodgkin's lymphoma (n=290), one of patients with MDSs (n=87) and one of patients with CLL (n=221), which was published only as an abstract. Five of these trials included patients receiving concurrent therapy for their malignancy. In the sixth study on MDS, none of the patients was given concurrent therapy.

Several publications from an additional randomized controlled trial were relevant but were not included in the evidence tables because of incomplete reporting (Abels, 1993; Abels, Larholt, Krantz, et al., 1991; Henry and Abels, 1994). This study included three groups of patients: a group receiving platinum chemotherapy, another receiving nonplatinum chemotherapy, and a third with malignant disease but not undergoing concurrent treatment. Patients with myeloid malignancies and acute leukemias were excluded. This study reported outcomes separately for the group of patients with anemia but not undergoing treatment for their malignancy, but did not report baseline patient characteristics separately for this group. Of particular concern, no information was available specifically for the group receiving no chemotherapy on the malignancies included and the distribution of those malignancies in the epoetin and control arms. As a result, it was not possible to assess comparability of study arms and the outcomes reported must be interpreted cautiously. Nonetheless, for completeness, we briefly describe these outcomes in the Results section to supplement the body of evidence included in this systematic review.

### Patient Populations

#### Baseline Hemoglobin

Mean or median Hb at enrollment was <10 g/dL for all trials (Evidence Table II-2). Thus, all six trials fell in the same baseline Hb category for initiating epoetin treatment, and no data are available to address alternative baseline Hb levels.

The upper limit of eligibility for enrollment was 11 g/dL in one trial (n=146; Cazzola, Messinger, Battistel, et al., 1995) and 10.7 g/dL in a second trial (n=221; Rose, Rai, Revicki, et al., 1994). It was 10.0 g/dL in three trials (Dammacco, Silvestris, Castoldi, et al., 1998; Garton, Gertz, Witzig, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996) and 9.0 g/dL in the study on MDS (Italian Cooperative Study Group for rHuEPO in MDS, 1998). In the study reported by Cazzola and colleagues (1995), the trial with the highest upper limit of Hb for eligibility, the highest mean baseline Hb in any arm was 9.5 ± 1.1 g/dL.

#### Concurrent Treatment for Malignancy

Two of the trials provided no data on the percentage of patients receiving concurrent treatments (Garton, Gertz, Witzig, et al., 1995; Rose, Rai, Revicki, et al., 1994). Although no information on concurrent treatments was available for the study by Rose and coworkers (1994), it was clear that an unknown percentage of those in the study by Garton and colleagues (1995) did receive some therapy during the trial. In three other trials, the percentage of patients receiving concurrent therapy ranged from 79 percent to 88 percent (Cazzola, Messinger, Battistel, et al., 1995; Dammacco, Silvestris, Castoldi, et al., 1998; Osterborg, Boogaerts, Cimino, et al., 1996). Only one study restricted enrollment to patients who were not receiving concurrent therapy (Italian Cooperative Study Group for rHuEpo in MDS, 1998).

#### Comparability of Study Arms

Included studies were reviewed to identify any imbalances in the populations randomized to treatment and control arms that might bias study results (Table 35; see Chapter 2, Methodology. The elements abstracted to assess study arm balance, with the number of studies that reported each element, are listed in decreasing order of frequency in Table 36.

Table 35. Study arm comparability

Were Study Arms Balanced Based on Available Data? | What Type of Test was Used to Assess the Balance of Study Arms? | N Enrolled Patients | N Evaluable Patients | Number of Studies
Insufficient data | Estimated by reviewers | 245 | 241 | 2
Yes | Estimated by reviewers | 448 | 407 | 4
| Totals | 693 | 648 | 6

Table 36. Reporting on elements of study arm comparability

Type of malignancy(ies) | 5 | No. of patients with bone marrow metastases | 0
Baseline hemoglobin value | 4 | No. of patients with previous platinum based chemotherapy | 0
Patient age | 4 | No. of patients with previous radiotherapy | 0
No. of transfusion-dependent patients | 2 | No. of patients with previous total body irradiation | 0
Performance score | 1
No. of previous chemotherapy regimens | 1
No. of previous chemotherapy cycles | 1

Overall, four of six studies were judged as having comparable study arms based on available patient data. In all cases, the reviewers compared the data elements reported to assess comparability. No studies reported a statistical comparison of patient characteristics by study arm, and sufficient information was not reported for the reviewers to perform a statistical analysis. Two studies did not have sufficient data to evaluate comparability of study arms. The specific elements reported to address comparability of study arms varied considerably from study to study. Most studies did not give specific data on concurrent cancer treatment but simply stated that entry into the study did not require a change in current treatment.

#### Subpopulations of Interest

##### Type of Malignancy

All patients in these studies had hematologic malignancies (Evidence Table II-1). Four of the six studies (n=385 enrolled) included patients with multiple myeloma, either exclusively (n=95; Dammacco, Silvestris, Castoldi, et al., 1998; Garton, Gertz, Witzig, et al., 1995) or pooled with non-Hodgkin's lymphoma patients (Cazzola, Messinger, Battistel, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996). One study (n=221), published as an abstract only, was limited to patients with CLL (Rose, Rai, Revicki, et al., 1994).

The sixth study (n=87) was limited to patients with MDSs (Italian Cooperative Study Group for rHuEpo in MDS, 1998). The mechanism(s) of anemia in MDS are distinct from those in other hematologic malignancies (see Chapter 1, Mechanisms and Classification of Anemia section). Thus, results of epoetin treatment from the trial on patients with MDS probably cannot be generalized to other malignancies and vice versa.

##### Age

All trials enrolled adults (Evidence Table II-2), with age ranges that extended into the seventies and eighties (e.g., Garton, Gertz, Witzig, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996). One trial did not report patient age, but the disease (CLL) is one of adults (Rose, Rai, Revicki, et al., 1994). None of the trials reported outcomes for patient subpopulations stratified by age.

##### Transfusion History

As shown in Table 37, three studies reported outcomes for patient groups all with a prior history of transfusion (n=222), and three studies reported outcomes for patient populations in which 0 to 20 percent previously had been transfused (n=214).

Table 37. Evidence on subpopulations

Characteristic | Groups of Interest | Number of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
Transfusion history | <20% previously transfused | 3 | 214 (58+156) | 214 (58+156)
| 100% previously transfused | 3 | 222 (88+134) | 199 (78+121)
Iron supplementation | Used iron supplements | 3 | 304 (103+201) | 286 (95+191)
| Iron supplements not specified | 3 | 389 (142+247) | 362 (129+233)

##### Iron Supplementation

Table 37 also shows that three studies used iron supplements (n=304), but the other three studies (n=389) did not specify whether patients were supplemented with iron.

##### Predictors of Response

Four studies (n=401 enrolled) reported information on factors that might predict response to epoetin treatment. (Table 49 in the Results section of this chapter reports the results on any factor that was analyzed as a potential predictor of response in at least two papers.)

Table 49. Factors tested for significance as predictors of hematologic responses to epoetin in patient with anemia of malignancy

Citation | Analysis Method | Serum EPO at Entry | Serum EPO O/E Ratio | Malignancy Type | Other Predictor | Other Predictor Result | Comment
Garton, Gertz, Witzig, et al., 1995 | Univariate | p =0.23 | | | Duration of MM; No. of Chemo cycles Baseline retic count | p =0.93 p =0.32 p =0.06 | Prediction of response in Epo-treated patients only
Osterborg, Boogaerts, Cimino, et al., 1996 | Univariate and multivariate Cox proportional hazards regression | | p<0.01, univariate; significant by multivariate analysis | p=0.42, univariate | PLT count | p<0.01, univariate; NS, by multivariate as Epo O/E ratio accounts for all of variance | Response freq. in patients with O/P >0.9 = 17% in controls, 10% (increasing dose) and 41% (fixed dose) in tx arms (NS)
Osterborg, Boogaerts, Cimino, et al., 1996 | Univariate and multivariate Cox proportional hazards regression | Chemo (Y/N) | p<0.01, univariate; significant by multivariate analysis | p=0.42, univariate | p =0.10, univariate | | Response freq. in patients with O/P >0.9 = 17% in controls, 10% (increasing dose) and 41% (fixed dose) in tx arms (NS)
Cazzola, Messinger, Battistel, et al., 1995 ^1^ | Multivariate Cox proportional hazards regression | p= 0.0089 | p=0.039 | (NS by univariate analysis) | Average PLT count (controls) | p=0.0347 | Significant response predictors evaluated in both treatment and control arms
Italian Cooperative Study Group, 1998 | Univariate | 92.3% negative predictive value (i.e., for nonresponse) at >200 mU/L | | | | | Significant response predictors evaluated in both treatment and control arms (?)

1 For doses of 5, 000 or 10, 000 Units/day

### Interventions

All six trials compared outcomes of epoetin (plus RBC transfusion as necessary) to outcomes of transfusion alone. In three studies, transfusions were administered when the Hb level fell below a defined threshold, which varied from 7 to 10 g/dL (Evidence Table II-1) (Dammacco, Silvestris, Castoldi, et al., 1998; Italian Cooperative Study Group, 1998; Osterborg, Boogaerts, Cimino, et al., 1996). Patients in each arm of the other three trials were transfused at the discretion of treating physicians, and no information was provided as to mean Hb value at transfusion by study arm. Table 38 summarizes the studies included in this review according to the characteristics of epoetin administration: dose, dosing regimen, and treatment duration. All six trials used the subcutaneous route of administration.

Table 38. Evidence to compare epoetin interventions

Dose (U/kg/week) | Regimen Type | Duration | No. of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
Multiarm Studies for Direct Comparison
0 to 1,000 | Fixed/continuous | <10 weeks | 1 (5 arms) | 146 (29+117) | 146 (29+117)
0 to 200 | Start/stop versus increasing | >20 weeks | 1 (3 arms) | 144 (49+95) | 121 (39+82)
Two-Arm Studies for Indirect Comparison
450 | Fixed/continuous | 12 to 16 weeks | 1 | 221 (80+141) | 221 (80+141)
450 | Increasing | 12 to 16 weeks | 1 | 24 (13+11) | 20 (10+10)
450 | Increasing | >20 weeks | 1 | 71 (31+40) | 65 (29+36)
1,050 | Fixed/continuous | <10 weeks | 1 | 87 (43+44) | 75 (37+38)

Three trials used doses of 450 U/kg per week (n=316; Dammacco, Silvestris, Castoldi, et al., 1998; Garton, Gertz, Witzig, et al., 1995; Rose, Rai, Revicki, et al., 1994). Of these, one used a fixed dose/continuous treatment regimen, while two used an increasing-dose regimen. Two of these trials used a treatment duration of 12 to 16 weeks, while one used a treatment duration of >20 weeks.

Two studies were multi-arm trials that directly compared outcomes for different characteristics of epoetin administration. A five-arm study (n=146) of <10 weeks' duration compared fixed and continuous epoetin doses ranging from 100 to 1,000 U/kg per week with controls managed by transfusion alone (Cazzola, Messinger, Battistel, et al., 1995). A three-arm trial (n=144) of >20 weeks' duration compared a start/stop regimen starting at 1,000 U/kg per week with an increasing-dose regimen starting at 200 U/kg per week and with controls managed by transfusion alone (Osterborg, Boogaerts, Cimino, et al., 1996).

The single trial on MDS patients used a fixed dose of 1,050 U/kg per week (Italian Cooperative Study Group for rHuEPO in MDS, 1998). However, any relationship between dose and response observed in this study might not generalize to patients with other malignancies because of the distinct mechanism(s) of anemia in patients with MDS.

### Outcomes of Interest

#### Efficacy Outcomes

As summarized in Table 39, hematologic outcomes were reported more frequently than transfusion outcomes.

Table 39. Evidence to compare outcomes

Outcome | Grouping | No. of Studies Reporting | N enrolled (controls+treated) | N evaluated (controls+treated)
% of patients responding | All trials | 6 | 693 (245+448) | 648 (224+424)
% of patients responding | MM±NHL | 4 | 385 (122+263) | 352 (107+245)
Change in Hb levels | All trials | 4 | 535 (171+364) | 508 (158+350)
Change in Hb levels | MM±NHL | 3 | 314 (91+223) | 287 (78+209)
% of patients transfused | All trials | 2 | 290 (78+212) | 267 (68+199)
% of patients transfused | MM±NHL | 2 | 290 (78+212) | 267 (68+199)
RBC units per patient | All trials | 3 | 355 (107+248) | 338 (99+239)
RBC units per patient | MM±NHL | 3 | 355 (107+248) | 338 (99+239)
All included studies | | 6 | 693 (245+448) | 648 (224+424)

- Percentage of patients who had a hematologic response was reported in all six trials (n=693).
- Change in Hb levels was reported for all patients in four trials (n=535) and for patients without prior transfusions in the other two trials.
- Percentage transfused was reported for all patients in two trials (n=290) and in a third trial only for patients without prior transfusions.
- RBC units transfused per patient was reported for all patients in two trials (n=290); a third trial reported RBC units transfused per patient separately for subgroups with and without prior transfusions.

In addition to the outcomes listed in Table 39, we sought data that compared epoetin-treated patients with controls with respect to: quality of life, symptoms of anemia (including shortness of breath, dyspnea on exertion, or angina), number of days in hospital, and changes in performance status. As shown in Evidence Table II-5 (Appendix II), no studies reported data on any of these outcomes. A trial on patients with CLL published only as an abstract reported significant between-group differences with respect to some measures of quality of life (Rose, Rai, Revicki, et al., 1994). However, no other data were provided.

#### Adverse Events

Table 40 summarizes reporting on adverse events by the included studies.

Table 40. Reporting on adverse events in studies on anemia of malignancy

Adverse Event | No. of Studies Reporting | N evaluated (controls+treated)
Any adverse effect (each patient counted once only) | 4 | 436 (146+290)
Hypertension (highest freq. if systolic/diastolic separated) | 3 | 236 (91+145)
Deep vein thrombosis or thromboembolism | 1 | 144 (49+95)
Hemorrhage and/or thrombocytopenia | 0 | 0
Skin rash, irritation, and/or pruritus | 3 | 290 (117+173)
Seizures | 0 | 0
Injection site pain | 0 | 0
Fatigue (separate from quality of life reporting) | 0 | 0
Withdrawals (due to adverse events) | 4 | 311 (128+183)
Mortality (from any cause, while on study) | 3 | 361 (109+252)

### Study Quality

Quality of study design and conduct was assessed as described in the "Methodology" chapter. Table 41 summarizes all parameters of study quality abstracted from the six included studies. The objective was to identify a group of higher quality trials for purposes of sensitivity analysis.

Table 41. Assessment of study quality^1^

Citation | Blinding (required) | Percentage of Excluded Subjects Below Specified Threshold? ^2^ (required) | Accounted for Excluded Patients? | Allocation Concealed? | Transfusion Trigger? | R/O Other Anemia Causes? | Fe Status Confirmed? ^3^ | Patients Blinded to Hb Levels? ^4^
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | Double blinded | No | No/NS | No/NS | Yes | No | Yes
Garton, Gertz, Witzig, et al., 1995 | Double blinded | No | No/NS | No/NS | No | No | No
Osterborg, Boogaerts, Cimino, et al., 1996 | Unblinded | No | No/NS | Yes | Yes | No | Yes
Cazzola, Messinger, Battistel, et al., 1995 | Unblinded | Yes | Yes | No/NS | No | Yes | Yes
Dammacco, Silvestris, Castoldi, et al., 1998 | Unblinded | Yes | Yes | No/NS | Yes | No | Yes
Rose, Rai, Revicki, et al., 1994 (abstract only) | Double blinded | Unknown | Unknown | No/NS | Unknown | Unknown | Unknown | No/NS

1 All are randomized, controlled trials.

2 <5 percent of subjects were excluded in each study arm OR (<10 percent of subjects were excluded in each study arm AND the ratio between arms for the percentage of subjects excluded from the analysis was <2:1).

No trials met our requirements for higher quality studies. Three studies were double blinded, but excluded too many subjects from analysis and did not use intent to treat analysis (Garton, Gertz, Witzig, et al., 1995; Italian Cooperative Study Group for rHuEpo in MDS, 1998; Rose, Rai, Revicki, et al., 1994). None of these double-blinded studies reported on other methodologic dimensions such as allocation concealment, nor did they account for the reasons patients were excluded from analysis. Only the study on MDS reported on transfusion triggers. Furthermore, one of the studies was published only as an abstract and there was insufficient detail for evaluating study quality (Rose, Rai, Revicki, et al., 1994).

Of the three unblinded trials, one reported on-allocation concealment (Osterborg, Boogaerts, Cimino, et al., 1996). The other two were the only studies with <5 percent of patients in each arm (or <10 percent for the entire study) excluded from analysis, and both adequately accounted for the reasons patients were excluded from analysis (Cazzola, Messinger, Battistel, et al., 1995; Dammacco, Silvestris, Castoldi, et al., 1998). Two of the three unblinded studies also reported transfusion triggers (Dammacco, Silvestris, Castoldi, et al., 1998; Osterborg, Boogaerts, Cimino, et al., 1996).

The presence of iron deficiency or the failure to rule out other causes of anemia might lead to underestimating the effects of epoetin. Four trials met our stringent requirement for the adequacy of measures used to verify the patients' iron status (Cazzola, Messinger, Battistel, et al., 1995; Dammacco, Silvestris, Castoldi, et al., 1998; Italian Cooperative Study Group for rHuEpo in MDS, 1998; Osterborg, Boogaerts, Cimino, et al., 1996). Only one trial reported ruling out all other causes of anemia in enrolled patients (Cazzola, Messinger, Battistel, et al., 1995).

## Results

### Comparison of Epoetin with Transfusion Alone and Relative Effects of Epoetin as a Function of Hemoglobin Threshold for Initiating Treatment

#### Hematologic Outcomes

Table 42 summarizes the data reported on percentage of patients responding and on mean change in Hb levels. In the trial on patients with MDS (n=75 evaluable), significantly more patients treated with epoetin (37 percent) than controls (11 percent) achieved a hematologic response (Italian Cooperative Study Group for rHuEpo in MDS, 1998). Significantly more patients also responded in the epoetin arms (31 to 75 percent for those given >200 U/kg per week of epoetin) than for those in the control arms (7 to 23 percent) in all five trials on other hematologic malignancies (n=573) (Cazzola, Messinger, Battistel, et al., 1995; Dammacco, Silvestris, Castoldi, et al., 1998; Garton, Gertz, Witzig, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996; Rose, Rai, Revicki, et al., 1994).

Table 42. Hematologic and transfusion outcomes for studies grouped by baseline Hb levels

Citation | Transf. Trigger or Mn Hb @ transf. ^1^ | Baseline Hb | Study Arm | N Enrolled | N Evaluable | Start Final EPO dose U/kg/week | | Percent Response (PR+CR) | p Value | Hb Change (± SD) g/dL | p Value | Percent Transfused | p Value | RBC Units per Patient ± SD | p Value | RBC Units per Patient per 4 Wks
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 8 | | Control | 43 | 37 | 0 | | 10.8 (10.8+0.0)
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 8 | | Epo | 44 | 38 | 450 | | 36.8 (23.7+13.2) | 0.007
Garton, Gertz, Witzig et al., 1995 | | 8.7 | Control | 13 | 10 | 0 | | 0.0 (0.0+0.0)
Garton, Gertz, Witzig et al., 1995 | 8.7 | Epo | 11 | 10 | 450 | 900 | 70.0 (10.0+60.0) | 0.0015 ^2^ | | 0.02
Cazzola, Messinger, Battistel et al., 1995 | | 9.5 | Control | 29 | 29 | 0 | | 7.4 | 0.0001 ^3^ (Kaplan-Meier & log-rank) | 0.15 | | 27.6 | | 0.9 | | 0.4
Cazzola, Messinger, Battistel et al., 1995 | 9.3 | Epo-1 | 31 | 31 | 100 | | 6.5 | | 0.4 | 0.57 ^4^ | 22.6 | NS ^2^ | 0.7 | | 0.4
Cazzola, Messinger, Battistel et al., 1995 | 9.4 | Epo-2 | 29 | 29 | 200 | | 31.0 | | 1.8 | 0.05 ^4^ | 17.2 | NS ^2^ | 0.7 | | 0.3
Cazzola, Messinger, Battistel et al., 1995 | 9.4 | Epo-3 | 31 | 31 | 500 | | 61.3 | | 2 | 0.01 ^4^ | 19.4 | NS ^2^ | 0.5 | | 0.3
Cazzola, Messinger, Battistel et al., 1995 | 9.4 | Epo-4 | 26 | 26 | 1,000 | | 61.5 | | 1.6 | 0.0001 ^4^ | 15.4 | | 0.2 | | 0.1
Rose, Rai, Revicki et al., 1994 | | 9.2 | Control | 80 | 80 | 0 | | 15.0 | | 0.5
Rose, Rai, Revicki et al., 1994 | 9.2 | Epo | 141 | 141 | 450 | | 49.6 | <0.0001 | 1.9 | <0.0001
Dammacco, Silvestris, Castoldi et al., 1998 | 7 | 8.3 | Control | 31 | 29 | 0 | | 20.7 (10.3+10.3)
Dammacco, Silvestris, Castoldi et al., 1998 | 7 | 8.3 | Epo | 40 | 36 | 450 | 300 | 75.0 (30.6+44.4) | <0.001
Osterborg, Boogaerts, Cimino, et al., 1996 | See footnote ^5^ | 8.1 | Control | 49 | 39 | 0 | | 23.1 | | 0.5 | | 82.1
Osterborg, Boogaerts, Cimino, et al., 1996 | See footnote ^5^ | 8.0 | Epo-1 | 47 | 38 | 1,000 | | 60.5 | 0.01 | 2.1 | NS | 57.9 | <0.05 | | NS
Osterborg, Boogaerts, Cimino, et al., 1996 | See footnote ^5^ | 8.0 | Epo-2 | 48 | 44 | 200 | 1,0000 | 59.1 | 0.02 | 1.5 | NS | 63.6 | <0.05 | | NS

1 Single entry = transfusion trigger; multiple entries = mean Hb levels at transfusion.

2 Calculated for this review using Fisher's exact test.

3 Log rank test comparing all treatment groups with dose ≥2,000 to control.

4 p Value is compared with control for mean weekly increase in Hb level based on intention-to-treat analysis.

5 No transfusion trigger given, but transfusion was not permitted if Hb ≥ 10.

Of the three trials with data on change in Hb levels, the differences between epoetin-treated and control arms were statistically significant in favor of epoetin in one study (n=221, p<0.0001; Rose, Rai, Revicki, et al., 1994) and were not significant in a second (n=121; Osterborg, Boogaerts, Cimino, et al., 1996). The third study did not report a test of statistical significance for change in Hb from baseline to end of study, which is the outcome reported in Table 42 (Cazzola, Messinger, Battistel, et al., 1995). However, Cazzola and coworkers did report an intention-to-treat analysis of median average increase in Hb level per week by dosage level. All but the 100 U/kg per week dose (p=0.57) were significantly greater than the control group (p=0.05; p=0.01; p=0.0001, respectively). Excluding the study arm given epoetin doses <200 U/kg per week, the differences between treated and control arms ranged from 1.0 to 1.9 g/dL across all three trials. A fourth study reported a statistically significant difference favoring epoetin (p=0.02) but did not report the magnitude of Hb change for either arm (Garton, Gertz, Witzig, et al., 1995). The trial on patients with MDS did not report on changes in Hb levels (Italian Cooperative Study Group for rHuEpo in MDS, 1998).

Data reported by the trial excluded for insufficient baseline information agree with these results (Abels, 1993; Abels; Larholt, Krantz, et al., 1991; Henry and Abels, 1994). Hematologic responses were reported for 31.7 percent of 63 treated patients compared with 11 percent of the 55 patients on placebo (p<0.008). Mean change in Hb levels (calculated from hematocrit) was −0.03 g/dL for controls compared with 0.9 g/dL (p<0.004) for the treatment group.

#### Transfusion Outcomes

Only two of six included trials (n=267) reported on the percentage of patients transfused and RBC units transfused for all evaluable patients (Cazzola, Messinger, Battistel, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996). These data are summarized in Table 42. A third trial (n=71; Evidence Table II-4) reported transfusion outcomes separately for subgroups with and without prior transfusions (Dammacco, Silvestris, Castoldi, et al., 1998). The trial on patients with MDS did not report transfusion outcomes (Italian Cooperative Study Group for rHuEpo in MDS, 1998).

Osterborg, Boogaerts, Cimino, et al. (1996; n=121) reported significantly fewer patients transfused in the epoetin arms than in controls (82 versus 58 to 64 percent; p<0.05) but no significant reduction in RBC units per patient. Cazzola, Messinger, Battistel, et al., (1995; n=146) reported fewer patients transfused (27 versus 15 to 19 percent) and fewer RBC units per patient (0.9 versus 0.2 to 0.5) in the arms given epoetin doses >500 U/kg per week but did not report a test of statistical significance for either outcome. The differences in percentage of patients transfused are not statistically significant by Fisher's exact test.

Although epoetin appeared to spare patients from transfusion in both the Osterborg and Cazzola trials, these studies differed markedly with respect to the percentages transfused in the two control (82 versus 27 percent) and two epoetin arms (58 to 64 versus 15 to 19 percent). Both trials were unblinded and enrolled patients with multiple myeloma and non-Hodgkin's lymphoma; neither trial had a transfusion trigger. The high transfusion rates in both arms of the Osterborg study may be related to the lower mean Hb at enrollment in the Osterborg trial than in the Cazzola trial (8.0 to 8.1 versus 9.3 to 9.5). Additionally, all patients in the Osterborg trial were transfusion dependent at study entry, whereas <20 percent of patients in the Cazzola study were previously transfused (Evidence Table II-2).

These results, however, are confounded by the lack of a transfusion trigger in either study. The Osterborg protocol only states that transfusion was barred at Hb levels >10 g/dL. It appears that transfusions were given at Hb levels that were high compared with those in other studies, although this appears to be the case for the treatment as well as the control arms. Another factor potentially contributing to the discrepant results is that the duration of treatment was substantially longer in the Osterborg study than in the Cazzola study; 24 compared with 8 weeks.

Dammacco, Silvestris, Castoldi, et al. (1998; Evidence Table II-4) reported fewer epoetin-treated patients (25 percent; n=24) than controls (45 percent; n=20) transfused in the subgroup without a history of previous transfusion at study entry, but the difference was not statistically significant. Epoetin significantly reduced the RBC units per patient for those previously transfused (n=27; 0.4 versus 0.1 units/patient/4 weeks; p=0.013), but not for those without a history of previous transfusion (n=44; 0.4 versus 0.2 units/patient/4 weeks; p=0.12).

The trial (n=118) excluded for insufficient baseline information also reported fewer patients transfused in the epoetin arm (38.2 versus 33.3 percent) and fewer RBC units per patient (2.2 versus 1.5), both nonsignificant differences (Abels, 1993; Abels, Larholt, Krantz, et al., 1991; Henry and Abels, 1994).

#### Inferences on Transfusion Outcomes

In view of the consistent evidence on hematologic response and the sparse evidence on transfusion outcomes, we sought additional evidence from the six included studies that might permit inferences on the relationship between hematologic response and transfusion avoidance in patients with anemia primarily to malignant disease. We looked for data on the magnitude of increase in Hb level and mean Hb at study end that suggested that an Hb level adequate to reduce transfusion risk (i.e., >10 g/dL) could be maintained. Table 43 shows that final Hb levels for controls ranged from 8.2 to 9.7 g/dL, whereas the range for the treatment arms (excluding the 100 U/kg per week arm in Cazzola, Messinger, Battistel, et al., 1995), was 10.1 to 11.7 g/dL. The study by Garton, Gertz, Witzig, et al. (1995), which did not provide data on final Hb levels, reported that 60 percent of patients in the treatment arm achieved a complete response, defined as Hb >12.7. Taken together, these data suggest that the response to epoetin in the included studies was adequate to place patients in a range of Hb level where transfusion risk is likely to be reduced. However, it is not possible to estimate the magnitude of benefit that might be expected.

Table 43. Final Hb levels

Citation | Transf Trigger or Mn Hb @ transf. ^1^ | Base-line Hb | Study Arm | N Enrolled | N Evaluable | EPO Dose U/kg/Week | | Final Hb Level | Hb Change (± SD) g/dL | p Value
Citation | Transf Trigger or Mn Hb @ transf. ^1^ | Base-line Hb | Study Arm | N Enrolled | N Evaluable | Start | Final | Final Hb Level | Hb Change (± SD) g/dL | p Value
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 8 | | Control | 43 | 37 | 0 | | 8.2 (mean)
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 8 | | Epoetin | 44 | 38 | 450 | | 10.1(mean)
Garton, Gertz, Witzig, et al., 1995 | | 8.7 | Control | 13 | 10 | 0
Garton, Gertz, Witzig, et al., 1995 | 8.7 | Epoetin | 11 | 10 | 450 | 900 | CR>12.7 | | 0.02
Cazzola, Messinger, Battistel, et al., 1995 | | 9.5 | Control | 29 | 29 | 0 | | 9.6 (mean) | 0.15
Cazzola, Messinger, Battistel, et al., 1995 | 9.3 | Epo-1 | 31 | 31 | 100 | | 9.7 (mean) | 0.4
Cazzola, Messinger, Battistel, et al., 1995 | 9.4 | Epo-2 | 29 | 29 | 200 | | 11.2 (mean) | 1.8
Cazzola, Messinger, Battistel, et al., 1995 | 9.4 | Epo-3 | 31 | 31 | 500 | | 11.4 (mean) | 2
Cazzola, Messinger, Battistel, et al., 1995 | 9.4 | Epo-4 | 26 | 26 | 1,000 | | 11.0 (mean) | 1.6
Rose, Rai, Revicki, et al., 1994 | | 9.2 | Control | 80 | 80 | 0 | | 9.7 (mean) | 0.5
Rose, Rai, Revicki, et al., 1994 | 9.2 | Epoetin | 141 | 141 | 450 | | 11.0 (mean) | 1.9 | <0.0001
Damacco, Silvestris, Castoldi, et al., 1998 | 7 | 8.3 | Control | 31 | 29 | 0 | | 8.2 ± 1.7 (mean) ^2^
Damacco, Silvestris, Castoldi, et al., 1998 | 7 | 8.3 | Epoetin | 40 | 36 | 450 | 900 | 10.8 ± 2.0 (mean)^2^
Osterborg, Boogaerts, Cimino, et al., 1996 | | 8.1 | Control | 49 | 39 | 0 | | | 0.5
Osterborg, Boogaerts, Cimino, et al., 1996 | 8.0 | Epo-1 | 47 | 38 | 1,000 | | | 2.1 | NS
Osterborg, Boogaerts, Cimino, et al., 1996 | 8.0 | Epo-2 | 48 | 44 | 200 | 1,000 | | 1.5 | NS

1 Single entry = transfusion trigger; multiple entries = mean Hb levels at transfusion.

2 Non-pretransfused subgroup only.

#### Quality of Life

The only included study (n=221 evaluable) that compared measurements of quality of life for patients with anemia due to malignancy managed with and without epoetin was published only as an abstract (Rose, Rai, Revicki, et al., 1994). The specific quality-of-life instrument used was not identified. This study on patients with CLL reported significant between-group differences that favored the epoetin-treated group with respect to energy scores (p<0.05). However, information is not available to assess the study protocol for methods to collect quality-of-life data, the potential for bias because of missing data, or the clinical significance of the reported changes in quality-of-life scores.

The trial excluded for insufficient baseline information did report results of quality of life measurement using the linear analog self-assessment scale for three items (Abels, 1993; Abels, Larholt, Krantz, et al., 1991; Henry and Abels, 1994). However, all quality of life results reported from this study either pooled data for patients who were or were not receiving therapy for their malignancy or reported only on those given platinum-containing (Henry, Brooks, Case, et al., 1995) or platinum-free chemotherapy (Case, Bukowski, Carey, et al., 1993).

#### Relative Effects of the Hemoglobin Threshold for Initiating Treatment on Transfusion Outcomes

All patients included in these studies had baseline Hb <10 g/dL. Consequently, the evidence available from controlled trials does not address alternative thresholds for initiating epoetin treatment of patients with anemia primarily associated with malignant disease. The hypothesis that outcomes such as transfusion use or quality of life may be improved by initiating epoetin when declining Hb levels near 10 g/dL, relative to outcomes of using epoetin at or just below Hb of 10 g/dL, remains untested.

### Effect of Characteristics of Epoetin Administration on Outcomes

All six trials used the subcutaneous route of administration. There were two multiple-arm trials and four two-arm trials. Table 44 provides data on epoetin dose, regimen, and duration from the two multiple-arm studies that permit direct comparison of outcomes for different characteristics of epoetin administration to patients with anemia due primarily to malignant disease. Table 45 summarizes information on epoetin dose, regimen, and treatment duration from the four two-arm studies.

Table 44. Evidence for direct comparison of epoetin interventions in multiple-arm studies

Citation | Dose (U/kg per week) | Epo Regimen Class ^1^ | Epo Tx Duration ^2^ | N Enrolled | N Evaluable | Percent Response | p Value | Hb Change ± SD | p Value | Percent Trans-fused | p Value | RBC Units per Patient | p Value | RBC Units per Patient per 4 Weeks
Cazzola, Messinger, Battistel, et al., 1995 | 0 | | | 29 | 29 | 7.4 | | 0.15 | | 27.6 | | 0.9 | | 0.4
Cazzola, Messinger, Battistel, et al., 1995 | 100 | 2 | 1 | 31 | 31 | 6.5 | 0.0001 ^4^ | 0.4 | 0.57 ^3^ | 22.6 | | 0.7 | | 0.4
Cazzola, Messinger, Battistel, et al., 1995 | 200 | 2 | 1 | 29 | 29 | 31.0 | 0.0001 ^4^ | 1.8 | 0.05 | 17.2 | NS ^5^ | 0.7 | | 0.3
Cazzola, Messinger, Battistel, et al., 1995 | 500 | 2 | 1 | 31 | 31 | 61.3 | 0.0001 ^4^ | 2 | 0.01 | 19.4 | NS ^5^ | 0.5 | | 0.3
Cazzola, Messinger, Battistel, et al., 1995 | 1000 | 2 | 1 | 26 | 26 | 61.5 | 0.0001 ^4^ | 1.6 | 0.0001 | 15.4 | NS ^5^ | 0.2 | | 0.1
Osterborg, Boogaerts, Cimino, et al., 1996 | 0 | | | 49 | 39 | 23.1 | | 0.5 | | 82.1
Osterborg, Boogaerts, Cimino, et al., 1996 | 1000 | 2 | 3 | 47 | 38 | 60.5 | 0.01 | 2.1 | NS | 57.9 | <0.05 | | NS
Osterborg, Boogaerts, Cimino, et al., 1996 | 200 | 3 | 3 | 48 | 44 | 59.1 | 0.02 | 1.5 | NS | 63.6 | <0.05 | | NS

1 Treatment regimen; 1=fixed; 2=decreasing dose; 3=increasing dose.

2 Treatment duration; 1=≤10 weeks; 2=12 to 16 weeks; 3=≥20 weeks.

3 p value is compared with control for median increase in Hb level per week based on intention-to-treat analysis. Only 200 U/kg per week significant compared to next lower dose (0.01).

4 Log rank test comparing all treatment groups with control

5 Calculated for this review using Fisher's exact test.

Table 45. Evidence for indirect comparison of epoetin interventions from two-arm studies

Citation | Dose (U/kg per week) | EPO Regimen Class ^1^ | EPO Tx Duration ^2^ | N Enrolled | N Evaluable | Percent Response (PR+CR) | p Value | Hb Change ±S.D. | p Value | Percent Transfused | p Value | RBC Units per Patient | p Value | RBC units per Patient per 4 Weeks
Rose, Rai, Revicki, et al., 1994 | 0 | 1 | 2 | 80 | 80 | 15.0 | | 0.5
Rose, Rai, Revicki, et al., 1994 | 450 | 1 | 2 | 141 | 141 | 49.6 | <0.0001 | 1.9 | <0.0001
Garton, Gertz, Witzig, et al., 1995 | 0 | 3 | 2 | 13 | 10 | 0.0 (0.0+0.0)
Garton, Gertz, Witzig, et al., 1995 | 450 | 3 | 2 | 11 | 10 | 70.0 (10.0+60.0) | 0.0015 ^3^ | | 0.02
Dammacco, Silvestris, Castoldi, et al., 1998 | 0 | 3 | 3 | 31 | 29 | 20.7 (10.3+10.3)
Dammacco, Silvestris, Castoldi, et al., 1998 | 450 | 3 | 3 | 40 | 36 | 75.0 (30.6+44.4) | <0.001
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 0 | 1 | 1 | 43 | 37 | 10.8 (10.8+0.0)
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 1050 | 1 | 1 | 44 | 38 | 36.8 (23.7+13.2) | 0.007

1 Treatment regimen; 1=fixed; 2=decreasing dose; 3=increasing dose.

2 Treatment Duration; 1=≤10 weeks; 2= 12 to 16 weeks; 3=≥20 weeks.

3 Calculated for this review using Fisher's exact test.

#### Direct Comparisons

A five-arm trial (n=26 to 31 per arm) compared controls managed by transfusion alone with four groups treated with epoetin doses ranging from 100 to 1,000 U/kg per week (Cazzola, Messinger, Battistel, et al., 1995). The treatment regimen used in this study reduced the epoetin dosage for responding patients; the duration of treatment and outcomes measurement was 8 weeks. Mean weekly change in Hb level was the only hematologic outcome for which statistical significance was reported. Patients in the control arm experienced a mean weekly change in Hb levels of −0.04±0.38 g/dL. When each of the four epoetin-treated arms were compared with controls, the results were; 0.10±0.40 (p=0.57), 0.17±0.32 (p=0.055), 0.3±0.52 (p=0.014), and 0.44±0.45 (p=0.0001) g/dL, respectively, for epoetin doses of 100, 200, 500, and 1,000 U/kg per week. When the epoetin-treated arms were compared with each other, there was a significant difference between the mean weekly Hb change produced by 200 U/kg per week and that produced by 100 U/kg per week (p=0.0124), but not between 200, 500, or 1,000. Intention-to-treat analysis was used for these comparisons. These results suggest that doses <100 U/kg per week are insufficient to increase Hb levels significantly above controls.

The three-arm randomized trial (n=38 to 44 per arm) compared a regimen that started at 1,000 U/kg per week, with decreases for responding patients, with a regimen that started at 200 U/kg per week, with increases for nonresponding patients to a maximum of 1,000 U/kg per week (Osterborg, Boogaerts, Cimino, et al., 1996). The duration of treatment was 24 weeks. Both regimens resulted in a significant difference in the percentage of patients experiencing a response to therapy relative to control patients, although the magnitude of change in Hb levels was not significantly different (See Table 44). Neither regimen appeared superior to the other.

In summary, there is limited evidence to compare hematologic outcomes according to the different characteristics of epoetin administration. One multiple-arm trial suggests that epoetin doses of <100 U/kg per week are insufficient to produce a statistically significant hematologic response in treated patients compared with untreated control patients (Cazzola, Messinger, Battistel, et al., 1995). In this study, there was not a statistically significant difference in hematologic response among starting doses of 200, 500, and 1,000 U/kg per week. A second multiple-arm trial suggests that a regimen starting with a dose of 200 U/kg per week and increasing for nonresponders is comparable to a regimen that starts with 1,000 U/kg per week and reduces the weekly dose for responders (Osterborg, Boogaerts, Cimino, et al., 1996).

#### Indirect Comparisons

Three (n=306) trials used a starting dose of 450 U/kg per week (Dammacco, Silvestris, Castoldi, et al., 1998; Garton, Gertz, Witzig, et al., 1995; Rose, Rai, Revicki, et al., 1994). One of these trials used a fixed dose regimen, and two used increasing doses. The duration of treatment was greater than 20 weeks in one of the increasing dose trials and 12 to 16 weeks in the other two trials. As was shown in Table 45, all three trials reported that more patients met criteria for a hematologic response in the epoetin arms (50 to 75 percent) than in the control arms (0 to 21 percent), and two reported that the difference was statistically significant. Two of the three also report significantly larger increases in Hb levels for the epoetin arms (Garton, Gertz, Witzig, et al., 1995; Rose, Rai, Revicki, et al., 1994). Taken together, these studies suggest that starting doses of 200 to 450 U/kg per week are adequate to achieve hematologic response. Hematologic responses were achieved at this starting dose range using fixed and increasing dose regimens.

A fourth two-arm trial studied patients with MDS (Italian Cooperative Study Group for rHuEpo in MDS, 1998). This trial used a starting dose of 1,050 U/kg per week delivered in a fixed dose regimen with a treatment duration of 10 weeks or less. There was a statistically significant difference in the percentage of patients who had a hematologic response, favoring the treatment arm (37 versus 11 percent; p=0.007). Despite the higher dose used in this study, the response rate was lower than in trials on patients with other malignancies. This may reflect the clonal hematopoietic disorder that underlies MDS, which may make erythropoietic progenitor cells less responsive to epoetin.

The trial excluded for insufficient baseline information used a fixed dose regimen of 300 U/kg per week for 8 weeks and reported statistically significant hematologic outcomes in the treatment arm (Abels, 1993; Abels, Larholt, Krantz, et al., 1991; Henry and Abels, 1994).

The evidence from these trials does not suggest that any of these starting dosages (>100 U/kg per week) or regimens is superior to another. There is no concern that differences in the characteristics of epoetin administration might confound interpretation of evidence on relative effects of alternative Hb thresholds for initiating epoetin treatment, since the available studies do not permit comparison of alternative baseline Hb levels.

### Patient Subpopulations and Predictors of Response

#### Type of Malignancy

Each included study limited enrollment to patients with either one or two hematologic malignancies. Evidence summarized in Table 46 shows significantly more hematologic responses among patients in the epoetin arms than among controls from trials on each malignancy studied. This includes CLL, 50 versus 15 percent (Rose, Rai, Revicki, et al., 1994); multiple myeloma alone, 75 versus 21 percent (Dammacco, Silvestris, Castoldi, et al., 1998) or with NHL, 60 versus 23 percent (Osterborg, Boogaerts, Cimino, et al., 1996); and MDS, 37 versus 11 percent (Italian Cooperative Group for rHuEpo in MDS, 1998).

Table 46. Comparison of outcomes of epoetin for different malignancies

Citation | N Enrolled (controls+treated) | N Evaluable (controls+treated) | Percent Response p Value (controls vs. treated) | Hb Change, g/dL p Value (controls vs. treated) | Percent Transfused p Value (controls vs. treated) | RBC Units/pt p Value (controls vs. treated)
Chronic lymphocytic leukemia
Rose, Rai, Revicki, et al., 1994 | 221 (80+141) | 221 (80+141) | <0.0001 (15.0 vs. 49.6) | <0.0001 (0.5 vs. 1.9) | NR | NR
Multiple myeloma/non-Hodgkin's lymphoma
Osterborg, Boogaerts, Cimino, et al., 1996 | 144 (49+47+48) | 121 (39+38+44) | 0.01, 0.02 (23.1 vs. 60.5, 59.1) | NS, NS (0.5 vs. 2.1, 1.5) | <0.05, <0.05 (82.1 vs. 57.9, 63.6) | NR
Cazzola, Messinger, Battistel, et al., 1995 | 146 (29+31+29+31+26) | 146 (29+31+29+31+26) | (7.4 vs. 6.5, 31.0, 61.3, 61.5) | (0.15 vs. 0.4, 1.8, 2, 1.6) | (27.6 vs. 22.6, 17.2, 19.4, 15.4) | (0.9 vs. 0.7, 0.7, 0.5, 0.2)
Multiple myeloma
Garton, Gertz, Witzig et al., 1995 | 24 (13+11) | 20 (10+10) | 0.0015 ^1^ (0.0 vs. 70.0) | 0.02 | NR | NR
Dammacco, Silvestris, Castoldi, et al., 1998 | 71 (31+40) | 65 (39+46) | <0.001 (20.7 vs. 75.0) | NR | NR | NR
Myelodysplastic syndrome
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 87 (43+44) | 75 (37+38) | 0.007 (10.8 vs. 36.8) | NR | NR | NR

1 Calculated for this review using Fisher's exact test.

Despite a higher dose of epoetin, fewer patients with MDS responded than the number reported for those with other hematologic malignancies.^8^ The distinct mechanism of anemia in this clonal disorder probably contributes to the reduced response rate (see Chapter 1, Mechanisms and Classification of Anemia section). Note that data from uncontrolled trials suggest some FAB categories of MDS (refractory anemia with ringed sideroblasts, refractory anemia with excess blasts in transformation) may be less responsive than others (refractory anemia, refractory anemia with excess blasts) to epoetin (Hellstrom-Lindberg, 1995).

8 An additional study on transfusion-dependent MDS patients was published recently (Thompson, Gilliland, Prchal, et al., 2000). This trial randomized 45 patients to 12 weeks of treatment with epoetin plus GM-CSF and 21 patients to treatment with placebo plus GM-CSF. The dose of epoetin used in this trial was 450 U/kg per week by three subcutaneous injections. Hematologic responses, defined as increases in Hb levels of >2 g/dL unrelated to transfusion, were reported in four (9 percent) epoetin-treated patients and one (5 percent) control patient. Mean change in Hb levels was +0.06 g/dL for epoetin-treated patients and −0.95 g/dL for controls. RBC transfusions were required during the study for 76 percent of epoetin-treated patients and 90 percent of controls. No tests of statistical significance were reported for these results, which confirm the low response rates to epoetin in MDS patients. Although no significant improvement was reported for the epoetin arm, this might be explained by the fact that these patients were transfusion-dependent at entry and were treated with a lower dose of epoetin than was used in the Italian Cooperative Group study.

Additional data showed significantly larger increases in Hb levels for those in the epoetin arms than for controls from trials on CLL (Rose, Rai, Revicki, et al., 1994) and multiple myeloma (Garton, Gertz, Witzig, et al., 1995). Only one trial, with patients who had either myeloma or NHL, reported significant reduction of the percentage of patients transfused (Osterborg, Boogaerts, Cimino, et al., 1996).

Patients with tumors of solid tissues and organs were among those in the study excluded for lack of adequate baseline data (Abels, 1993; Abels, Larholt, Krantz, et al., 1991; Henry and Abels, 1994). However, information was not provided on the distribution of tumor types within each study arm or on outcomes by tumor type.

#### Age

As shown in Evidence Table II-2, all of the included studies enrolled adult patients. Although the age ranges in some of the trials extended into the seventies and eighties (e.g., Garton, Gertz, Witzig, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996), none reported outcomes stratified by age. There are no studies of pediatric patients.

#### Iron Supplementation

Table 47 summarizes the evidence related to iron supplementation. Three of the six trials supplemented patients with oral iron (Cazzola, Messinger, Battistel, et al., 1995; Dammacco, Silvestris, Castoldi, et al., 1998; Italian Cooperative Study Group for rHuEpo in MDS, 1998). Published reports from the other three trials did not specify whether iron supplementation was given (Garton, Gertz, Witzig, et al., 1995; Osterborg, Boogaerts, Cimino, et al., 1996; Rose, Rai, Revicki, et al., 1994). Trials from each of these two groups reported statistically significant increases in the percentage of patients with hematologic responses to epoetin. No evidence is available from trials in which patients were definitely not supplemented with iron.

Table 47. Comparison of outcomes for subpopulations differing by iron supplementation

Citation | N Enrolled (controls+Epo) | N Evaluable (controls+Epo) | p Values, Percent Response (controls vs. Epo) | p Values, Hb Change, g/dL (controls vs. Epo) | p Values, Percent ransfused (controls vs. Epo) | p Values, RBC Units/Pt. (controls vs. Epo)
Studies that did not specify iron supplementation
Garton, Gertz, Witzig, et al., 1995 | 24 (13+11) | 20 (10+10) | 0.0015 ^1^ (0.0 vs.70.0) | 0.02 | NR | NR
Osterborg, Boogaerts, Cimino, et al., 1996 | 144 (49+47+48) | 121 (39+38+44) | 0.01, 0.02 (23.1 vs. 60.5, 59.1) | NS, NS (0.5 vs. 2.1, 1.5) | <0.05, <0.05 (82.1 vs. 57.9, 63.6) | NR
Rose, Rai, Revicki, et al., 1994 | 221 (80+141) | 221 (80+141) | <0.0001 (15.0 vs. 49.6) | <0.0001 (0.5 vs. 1.9) | NR | NR
Studies that used iron supplementation
Cazzola, Messinger, Battistel, et al., 1995 | 146 (29+31+29+31+26) | 146 (29+31+29+31+26) | (7.4 vs. 6.5, 31.0, 61.3, 61.5) | (0.15 vs 0.4, 1.8, 2, 1.6) | (27.6 vs. 22.6, 17.2, 19.4, 15.4) | (0.4 vs. 0.4, 0.3, 0.3, 0.1)
Dammacco, Silvestris, Castoldi, et al., 1998 | 71 (31+40) | 65 (29+36) | <0.001 (20.7 vs. 75.0) | NR | NR | NR
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 87 (43+44) | 75 (37+38) | 0.007 (10.8 vs. 36.8 | NR | NR | NR

1 Calculated for this review using Fisher's exact test.

#### Prior Transfusion History

Table 48 summarizes the evidence available to compare outcomes for patients that differed with respect to their prior transfusion history. There are two studies of patients with multiple myeloma and non-Hodgkin's lymphoma, one with fewer than 20 percent of patients with a history of prior transfusion (Cazzola, Messinger, Battistel, et al., 1995) and one with 100 percent of patients with a history of prior transfusion (Osterborg, Boogaerts, Cimino, et al., 1996). Two additional studies reported outcomes for multiple myeloma patients (Dammacco, Silvestris, Castoldi, et al., 1998) and patients with MDS stratified by prior transfusion history (Italian Cooperative Study Group for rHuEpo in MDS, 1998).

Table 48. Comparison of outcomes for subpopulations differing by prior transfusion history

Citation | N Enrolled (controls+Epo) | N Evaluable (controls+Epo) | p Values, Percent Response (controls vs. Epo) | p Values, Hb Change, g/dL (controls vs. Epo) | p Values, Percent Transfused (controls vs. Epo) | p Values, RBC Units/Pt (controls vs. Epo)
Study arms or strata with <20% of patients previously transfused
Dammacco, Silvestris, Castoldi, et al., 1998 | 44 (20+24) | 44 (20+24) | NR | 0.0001 (−0.2±1.5 vs. 2.1± 1.7) | 0.23 (45.0 vs. 25.0) | 0.12 (2.5 vs. 1.2)
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 24 (9+15) | 24 (9+15) | 0.0068 (0.0 vs.60.0) | 0.0004 (−0.28 vs. 1.72) | NR | NR
Cazzola, Messinger, Battistel, et al., 1995 | 146 (29+31+29+31+26) | 146 (29+31+29+31+26) | 0.0001 ^1^ (7.4 vs. 6.5, 31.0, 61.3, 61.5) | 0.57. 0.05, 0.01, 0.0001 ^2^ (0.15 vs 0.4, 1.8, 2, 1.6) | NS (27.6 vs. 22.6, 17.2, 19.4, 15.4) | (0.9 vs. 0.7, 0.7, 0.5, 0.2)
Study arms or strata with 100% of patients previously transfused
Osterborg, Boogaerts, Cimino, et al., 1996 | 144 (49+47+48) | 121 (39+38+44) | 0.01, 0.02 (23.1 vs. 60.5, 59.1) | NS, NS (0.5 vs. 2.1, 1.5) | <0.05, <0.05 (82.1 vs. 57.9, 63.6) | NS, NS
Dammacco, Silvestris, Castoldi, et al., 1998 | 27 (11+16) | 27 (11+16) | NR | NR | NR | 0.013 (2.6 vs. 0.6)
Italian Cooperative Study Group for rHuEpo in MDS, 1998 | 51 (28+23) | 51 (28+23) | 0.72 (14.3 vs 21.7) | NR | NR | NR

1 Log rank test comparing all treatment groups with control

2 p Value is compared with control for median increase in Hb level per week based on intention-to-treat analysis. Only 200 U/kg per week significant compared with next lower dose (0.01).

Among patients with multiple myeloma or non-Hodgkin's lymphoma, both Cazzola and coworkers (<20 percent prior transfusion) and Osterborg and coworkers (100 percent prior transfusion) reported a statistically significant difference in percentage of patients demonstrating hematologic response. Osterborg and colleagues reported significantly fewer patients transfused in the epoetin arm, and Cazzola and colleagues observed a nonsignificant trend toward reduced transfusion in the higher dose epoetin groups. Dammacco and colleagues reported fewer epoetin-treated patients transfused in the subgroup without a history of previous transfusion, but the difference was not statistically significant. Among the subgroup of patients with a prior history of transfusion, epoetin significantly reduced the RBC units per patient.

Among patients with MDS, epoetin significantly increased hematologic responses for patients without a prior history of transfusion (p=0.0068) but not for those previously transfused (p=0.72) (Italian Cooperative Study Group for rHuEpo in MDS, 1998). Furthermore, epoetin increased Hb levels in the MDS patients who were not previously transfused from a mean of 8.35 g/dL at entry to a mean of 10.1 g/dL at the conclusion of the study. This increase of +1.7 g/dL was significantly greater than the change seen in controls who also had no history of previous transfusion (−0.28 g/dL; p=0.0004). However, no history of prior transfusion may be associated with other characteristics of the natural history of MDS. For example, normal erythropoiesis may be conserved in patients who have a shorter history of disease.

#### Predictors of Response

This body of evidence provides limited evidence on predictors of response. Four of the six trials analyzed various predictors of hematologic responses to epoetin (Table 49). Serum concentration of endogenous erythropoietin (serum Epo) at study entry and the ratio of observed to expected (O/E) concentrations of serum erythropoietin (based on the severity of anemia) were the only hypothesized predictors of response found to be statistically significant in at least two trials.

### Adverse Events

Five of the six included studies (n=457) reported on adverse events. The number of patients with specific adverse events potentially related to epoetin treatment was collected for each of these studies. Table 50 lists the specific adverse events recorded and the percentage of patients with each adverse event (out of the total number of patients evaluated). Four studies also listed the total number of patients in each arm who experienced any adverse event, listed in the first row of Table 50. We used the chi-square and Fisher's exact tests (for calculations with one or more cell values <5) to determine if there were significant differences between treatment arms with respect to the frequency of adverse events.

Table 50. Adverse events reported by studies on patients with anemia due to malignancy and no concurrent therapy

Adverse Event | # Studies Reporting | N evaluated (controls+treated) | Percent Controls with Adverse Effects | Percent Treated with Adverse Effects | p Value ^1^
Any adverse effect (each patient counted once only) | 4 | 436 (146+290) | 34.3 | 32.8 | 0.839
Hypertension (highest freq. if systolic/diastolic separated) | 3 | 236 (91+145) | 1.1 | 9.7 | 0.011^2^
Deep vein thrombosis or thromboembolism | 1 | 144 (49+95) | 0 | 3.2 | 0.551^2^
Hemorrhage and/or thrombocytopenia | 0 | 0 | NR | NR
Skin rash, irritation, and/or pruritus | 3 | 290 (117+173) | 0.9 | 1.7 | 0.650^2^
Seizures | 0 | 0 | NR | NR
Injection site pain | 0 | 0 | NR | NR
Fatigue (separate from QoL reporting) | 0 | 0 | NR | NR
Withdrawals (due to adverse events) | 4 | 311 (128+183) | 14.8 | 11.5 | 0.483
Mortality (from any cause, while on study) | 3 | 361 (109+252) | 20.2 | 15.5 | 0.346

1 Chi-square test unless otherwise noted.

2 Fisher's exact 2-tailed test.

Except for hypertension and thromboembolic events, the reported frequency of adverse events does not appear to differ between epoetin-treated patients and controls. Although hypertension and thromboembolic events occurred more frequently in epoetin-treated patients than in controls, the difference was statistically significant only for hypertension. Note that none of the included studies reported on hemorrhage and/or thrombocytopenia, seizures, injection site pain, or fatigue.

## Conclusions

The literature search identified six controlled trials, all randomized, with a total enrollment of 693 patients that met inclusion criteria for this systematic review. Three trials were placebo controlled and double blinded (n=332; 48 percent). Of the 693 patients enrolled, 648 (93.5 percent) were reported as evaluable. Patients in this evidence base had diagnoses known to have a high occurrence of anemia of malignancy (multiple myeloma, non-Hodgkin's lymphoma, CLL, and MDSs). With the exception of one trial on patients with MDS, the preponderance of patients in these trials received concurrent therapy for their malignancy.

What are the outcomes of managing anemia with epoetin (plus transfusion when necessary) compared with transfusion alone? What are the relative effects of epoetin treatment when different hemoglobin thresholds are used to initiate treatment?

There is consistent evidence that use of epoetin results in statistically significant increases in the percentage of patients with anemia due to malignancy who meet criteria for a hematologic response. However, evidence on transfusion outcomes is sparse. Of the three studies that reported transfusion outcomes, one unblinded study (n=121) reported a statistically significant reduction in the percentage of patients who required RBC transfusions (Osterborg, Boogaerts, Cimino, et al., 1996). The other two trials reported differences in favor of epoetin use that were not statistically significant, possibly because of inadequate sample size or low risk of transfusion in the study population. In one of these trials, epoetin significantly reduced the RBC units per patient in the subpopulation of patients who had a history of prior transfusion.

Patients in the trials of disease-related anemia entered with Hb levels <10 g/dL. In Chapter 3, we found robust evidence that in populations with mean Hb <10 g/dL epoetin reduces the percentage of patients transfused. Those in the epoetin arms of the six trials included for this chapter experienced an increase in Hb levels comparable to similar patients in the Chapter 3 studies, which are of sufficient magnitude to reduce the percentage of patients transfused.

The only report on measurements of quality of life is an abstract that does not provide sufficient detail for interpretation of the results.

All patients included in these studies had baseline HB <10 g/dL. The evidence does not address alternative thresholds for initiating epoetin treatment.

In the studies included in this review, does varying the characteristics of the administration of epoetin affect the outcomes of treatment? The characteristics of epoetin administration are dose, route, dosing regimen (fixed, increasing, or decreasing dose), and treatment duration. Are the characteristics of epoetin administration likely to confound the interpretation of the evidence on the relative effects of epoitin treatment when different Hb thresholds are used to initiate epoetin treatment?

The studies suggest that starting doses in the 200 to 450 U/kg per week range are adequate to achieve hematologic response. Hematologic responses were achieved at this starting dose using fixed, decreasing, and increasing dose regimens. The evidence from these six trials does not suggest that any of these starting dosages or regimens is superior to another. However, the only study of patients with MDS used a much higher dose, 1,050 U/kg per week, yet obtained a smaller increase in response rate. The distinct mechanism of anemia in this clonal disorder probably contributes to the reduced response rate.

Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment? Are there laboratory measurements that can either predict or permit early identification of patients whose anemia is likely to respond to epoetin?

### Malignant Disease

Included studies reported on four hematologic malignancies: multiple myeloma, non-Hodgkin's lymphoma, CLL, and MDS. A statistically significant hematologic response in the epoetin arm was reported for all of these hematologic malignancies. However, the limited evidence available suggests that hematologic response rates are lower for patients with MDS.

### Age

All studies are of adults; there are no studies of pediatric patients or that separately report on geriatric patients.

### Iron status

All studies used iron supplementation or did not specify whether iron was supplemented. No studies reported results of patients known not to have received iron supplementation.

### Prior Transfusion

Epoetin increases hematologic responses or Hb levels for patients with either multiple myeloma or NHL, irrespective of history of prior transfusion. A single study of MDS patients reported that epoetin increases hematologic responses for patients without previous history of transfusion but not for those previously transfused. However history of prior transfusion may be associated with other characteristics, such as duration and progression of disease, which may affect erythropoiesis in MDS patients.

### Predictors of Response

This group of studies does not provide sufficient evidence to draw conclusions on predictors of response. Only the serum concentration of endogenous erythropoietin at baseline and the ratio of observed to expected concentrations of serum erythropoietin (based on the severity of anemia) were reported as significant predictors of response in at least two trials.

What are the incidence and severity of adverse effects associated with the use of epoetin and how do these compare with the adverse effects of transfusion alone?

Except for hypertension and thromboembolic events, the reported frequency of adverse events does not appear to differ between epoetin-treated patients and controls. Although hypertension and thromboembolic events occurred more frequently in epoetin-treated patients than in controls, the difference was statistically significant only for hypertension.