# Results and Conclusions I: Anemia Resulting Primarily From Cancer Therapy

## Objective

This systematic review compares the outcomes of the following alternatives for managing anemia in patients who are being treated for malignancy with chemotherapy, radiation, or chemotherapy and radiation:

1. Initiating epoetin when the level of Hb decreases to a specified threshold:
  - Hb >12 g/dL
  - Hb >10 and <12 g/dL
  - Hb <10 g/dL or requiring blood transfusions.
2. Managing anemia without epoetin, using transfusion (usually initiated when Hb decreases to a threshold between 7 and 9 g/dL).
3. Initiating prophylactic epoetin treatment concurrent with cancer therapy even if Hb levels are above the anemic range. (Normal limits for Hb values are approximately 12.0 to 16.0 g/dL for women and 14.0 to 18.0 g/dL for men.)

## Key Questions

1. What are the outcomes of managing anemia with epoetin (plus transfusion when necessary) compared with transfusion alone? What are the relative effects of epoetin treatment when different Hb thresholds are used to initiate treatment?
2. In the studies included in this review, does varying the characteristics of the administration of epoetin affect the outcomes of treatment, particularly correction of anemia? The characteristics of epoetin administration are route, dose, dosing regimen (fixed, increasing, or decreasing dose) and treatment duration. Are the characteristics of epoetin administration likely to confound the interpretation of the evidence on the relative effects of epoetin treatment when different Hb thresholds are used to initiate treatment?
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment? Are there laboratory measurements that can either predict or permit early identification of patients whose anemia is likely to respond to epoetin?
4. What are the incidence and severity of adverse effects associated with the use of epoetin and how do these compare with the adverse affects of transfusion?

## Overview of the Evidence

Twenty-two controlled trials with a total enrollment of 1,927 patients met the study selection criteria for inclusion in this systematic review.^4^ All trials compared the outcomes of managing anemia with epoetin treatment plus transfusion if necessary with those of RBC transfusion alone in patients undergoing therapy for a malignancy. Evidence Tables I-1 to I-6 summarize the data abstracted from all 22 trials. Eighteen trials with a total of 1,698 enrolled patients (88 percent) were randomized, and seven randomized trials with a total of 853 patients (44 percent) were placebo controlled and double blinded. Of the four nonrandomized trials, two (n=103) used concurrent controls and two studies (n=126) used historical controls. Nine studies with a total of 1,278 enrolled patients (66 percent) were multicenter trials, and 13 were conducted at single institutions.

4 Recently, an additional study was published that enrolled 30 patients (Dunphy, Harrison, Dunleavy, et al., 1999). These data, which are summarized in a later footnote, do not change any conclusions of this review.

The number of patients reported as evaluable is 1,838, which is 95 percent of all enrolled patients. Throughout this "Overview of the Evidence" section, "n" refers to the total number of patients enrolled. In the "Results" section, "n" refers to the number of patients evaluable.

Two of the 22 trials were not published as full reports. One study (n=56) was published only as an abstract (Quirt, Couture, Pichette, et al., 1996). Data from the second unpublished study (n=375) were available from a published abstract and from slides presented at the May 1999 meeting of ASCO and generously provided by the investigators (Littlewood, Bajetta, Cella, et al., 1999).

We classified the 22 trials into 3 categories defined by the study patients' mean or median Hb at enrollment: Hb > 12 g/dL, Hb >10 and <12 g/dL, and Hb <10 g/dL. No trial directly compared the outcomes of initiating epoetin treatment at alternative Hb thresholds. All trials compared epoetin treatment initiated at study entry (plus transfusion if necessary) to transfusion of RBCs when the patient's Hb level fell below a defined threshold or at the discretion of the treating physician. Thus, only inferences based on indirect comparison are possible as to whether initiating epoetin at one or another Hb threshold (e.g., 10 g/dL versus 12 g/dL) results in superior outcomes.

Most of the trials in this evidence base are small and may lack adequate statistical power to detect a difference between study arms. Of the 22 trials, only 4 (n=891, 46 percent) enrolled more than 100 patients (range 132 to 375) and had >50 patients in each study arm. Pooled analysis can be helpful when an evidence base includes a large number of small trials. To supplement this systematic review, we conducted a meta-analysis of the odds of transfusion; 17 of 22 studies (n=1,703, 88 percent) reported transfusion frequency, a clinically important outcome. All randomized trials that reported the percentage of patients transfused were eligible for meta-analysis. Fourteen trials (n=1,439, 75 percent) were included in an initial meta-analysis; subsequent analyses were restricted to the 12 trials (n=1,390, 72 percent) that administered epoetin subcutaneously.

### Patient Populations

#### Baseline Hemoglobin

We classified studies into three categories defined by mean or median Hb at enrollment. Fourteen trials (n=1,175) reported mean Hb at enrollment. Six trials (n=642) reported only median Hb (Dusenberry, McGuire, Holt, et al., 1994; Markman, Reichman, Hakes, et al., 1993; Oberhoff, Neri, Amadori, et al., 1998; Porter, Leahy, Polise, et al., 1996; ten Bokkel Huinink, de Swart, van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999). One trial (n=56) did not report whether the baseline Hb value was a mean or median (Quirt, Couture, Pichette, et al., 1996); and one trial (n=54) was classified based on the Hb level specified as the upper limit for eligibility, which was 8.1 g/dL (Silvestris, Romito, Fanelli, et al., 1995).

The largest body of evidence is from trials enrolling patients with mean or median Hb <10 g/dL at study entry; all three of the pediatric trials included in this analysis also were in this category. Of 1,927 patients enrolled in the 22 trials analyzed here, 1,188 (62 percent) were in the category Hb <10 g/dL; 431 (22 percent) were in the category Hb >10 and <12 g/dL; and 308 (16 percent) were in the category Hb < 12 g/dL.

Five studies sought to investigate prophylaxis of anemia by administering epoetin concurrent with cancer therapy regardless of baseline Hb. However, none enrolled a homogeneous population of patients all of whom had baseline Hb levels within the normal range (12 to 16 g/dL for females and 14 to 18 g/dL for males). Therefore, we classified these trials based on the mean or median Hb at baseline for the study population.

##### Hb <10 g/dL

Seven studies of adults enrolled 1,080 patients of whom 1,009 (93 percent) were evaluable. All trials were randomized, and all but two (Oberhoff, Neri, Amadori, et al., 1998; Silvestris, Romito, Fanelli, et al., 1995;) were of higher quality. Seventy-four percent of adult patients with baseline Hb <10 g/dL (n=799) were enrolled in the five higher quality trials. One study did not report baseline Hb but excluded patients with Hb >8 g/dL (Silvestris, Romito, Fanelli, et al., 1995). The trial by Oberhoff and colleagues (1998) reported only median Hb at baseline. The five higher quality trials reported mean Hb at baseline, and all but one (n=157; Case, Bukowski, Carey, et al., 1993) reported the standard deviation (SD) of the mean baseline Hb.

Three pediatric trials enrolled a total of 108 patients, 104 of whom (96 percent) were evaluable. Two of these trials, enrolling 58 patients, were randomized (Varan, Buyukpamukcu, Kutluk, et al., 1999; Porter, Leahhey, Polise, et al., 1996); neither was of higher quality. The randomized trial by Varan and colleagues (1999) and a nonrandomized trial by Leon, Jiminez, Barona, et al., (1998) reported mean Hb and SD at baseline. The randomized trial by Porter and coworkers (1996) reported only median Hb at baseline.

##### Hb >10 and <12 g/dL

The seven trials in this category enrolled a total of 431 patients of whom 419 (97 percent) were evaluable. Four trials were randomized and included 58 percent (n=252) of enrolled patients with Hb >10 and <12 g/dL. There was one higher quality trial, which enrolled 30 patients (Wurnig, Windhager, Schwameis, et al., 1996). Three trials (n=114) reported mean Hb at baseline, and two of these (n=70) reported the SD (Lavey and Dempsey, 1993; Wurnig, Windhager, Schwameis, et al., 1996). Three trials reported only median baseline Hb (Dusenbery, McGuire, Holt, et al., 1994; Markman, Reichman, Hakes, et al., 1993; ten Bokkel Huinink, de Swart, van Toorn, et al., 1998). One trial, published only as an abstract, did not report whether the baseline Hb value was the mean or median (Quirt, Couture, Pichette, et al., 1996).

##### Hb >12 g/dL

The five studies in this category enrolled 308 patients, of whom 306 (99 percent) were evaluable. All were randomized controlled trials; none was of higher quality. Four of the trials reported mean Hb, and two (n=100) also reported SD (Del Mastro, Venturini, Lionetto, et al., 1997; Gamucci, Thorel, Frasca, et al., 1993). One trial (n=130) reported only median Hb (Thatcher, De Campos, Bell, et al., 1999).

#### Comparability of Study Arms

We examined included studies for potential imbalances between study arms as described in the methods section. Sixteen studies were judged to have comparable study arms (Table 6); of these, only three actually reported a statistical comparison. Six randomized controlled trials did not report sufficient data for the reviewers to assess comparability of study arms. Note that any nonrandomized trials without sufficient data to assess comparability of study arms were excluded from this systematic review.

Table 6. Study arm comparability

Study Arms Comparable? | How Assessed? | Number of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
Insufficient data | Estimated by reviewers | 6 | 256 (112+144) | 249 (109+140)
Yes | Reported statistical tests | 13 | 1,538 (687+851) | 1,458 (640+818)
Yes | Estimated by reviewers | 3 | 133 (61+72) | 131 (61+70)
Totals | | 22 | 1,927 (860+1,067) | 1,838 (810+1,028)

The specific elements reported to address comparability of study arms varied considerably from study to study. Table 7 lists the elements sought to assess study arm balance, in decreasing order of frequency for the number of studies that reported each element.

Table 7. Reporting on Elements of Study Arm Comparability

Element | Number | Element | Number
Type of malignancy(ies) | 19 | No. patients with bone marrow metastases | 2
Baseline Hb value | 17 | No. previous chemotherapy regimens | 2
Patient age | 16 | No. radiotherapy cycles during study | 2
Chemotherapy dose intensity (by platelet or neutrophil count) | 11 | No. patients with previous platinum-based chemotherapy | 1
No. transfusion-dependent patients | 10 | No. previous chemotherapy cycles | 1
No. patients with platinum-based regimen(s) during study | 7 | No. patients with previous radiotherapy | 0
No. chemotherapy regimens during study | 6 | No. patients with previous total body irradiation | 0
Performance score | 5 | No. patients with total body irradiation during study | 0
No. chemotherapy cycles during study | 4

Despite incomplete reporting of details, it is unlikely that imbalances in the study arms pose a threat to validity for this analysis. The evidence base consists largely of randomized controlled trials, with 1,690 patients (88 percent of the total patients) randomized into 18 trials.

#### Subpopulations of Interest

Table 8 shows the number of studies and patients included in this systematic review relevant to the subpopulations of interest. In this table, analyses of stratified subgroups within a single study are tabulated with studies that were homogeneous for the same characteristic.

Table 8. Evidence on subpopulations

Characteristic | Subpopulations | Number of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
Tumor type (studies counted twice if outcomes stratified) | Hematologic | 2 | 221 (78+143) | 216 (76+140)
Tumor type (studies counted twice if outcomes stratified) | Solid organs and tissues | 15 | 1,221 (542+679) | 1,166 (510+656)
Tumor type (studies counted twice if outcomes stratified) | Mixed | 7 | 844 (355+489) | 815 (339+476)
Therapy regimen | Radiotherapy only | 3 | 132 (55+77) | 130 (55+75)
Therapy regimen | Nonplatinum chemotherapy, no or unknown radiotherapy | 3 | 586 (224+362) | 561 (211+350)
Therapy regimen | Nonplatinum chemotherapy and radiotherapy | 2 | 86 (43+43) | 82 (41+41)
Therapy regimen | Platinum chemotherapy, no or unknown radiotherapy | 9 | 777 (363+414) | 721 (329+392)
Therapy regimen | Platinum chemotherapy and radiotherapy | 3 | 240 (122+118) | 240 (122+118)
Therapy regimen | Unknown chemotherapy type, no or unknown radiotherapy | 2 | 106 (53+53) | 104 (52+52)
Patient age | Adults ^1^ | 18 | 1,763 (778+985) | 1,680 (731+949)
Patient age | Pediatric | 3 | 108 (54+54) | 104 (52+52)
Patient age | Geriatric | 0 | 0 | 0
Patient age | Unspecified | 1 | 56 (28+28) | 54 (27+27)
Transfusion history | <20% previously transfused | 3 | 204 (75+129) | 200 (74+126)
Transfusion history | >80% previously transfused | 1 | 50 (25+25) | 50 (25+25)
Transfusion history | Unknown or 21-79% | 18 | 1,673 (760+913) | 1,588 (711+877)
Iron supplementation | Both arms supplemented | 9 | 449 (229+220) | 444 (226+218)
Iron supplementation | Neither arm supplemented | 3 | 194 (75+119) | 193 (75+118)
Iron supplementation | EPO arm only ^2^ | 3 | 152 (73+79) | 145 (71+74)
Iron supplementation | Neither arm specified | 7 | 1,132 (483+649) | 1,056 (438+618)

1 Includes 2 assumed to be all adults, based on included malignancies.

2 Controls: 2 trials, not supplemented; 1 trial, not specified.

##### Type of malignancy

Two studies (n=221 enrolled) restricted enrollment to patients with hematologic malignancies, and 15 studies (n=1,221 enrolled) restricted enrollment to patients with tumors of solid organs or tissues. In seven of the latter 15 studies (n=513 enrolled), all patients had one type of solid tumor (Evidence Table I-1). This included three trials on ovarian cancer (n=215) and one trial each on breast cancer (n=62), small cell lung cancer (n=130), Ewing's and osteosarcoma (n=30), and cervical cancer (n=76). Seven trials (n=844) enrolled patients with either hematologic or nonhematologic malignancies.

##### Cancer treatment regimens

Of the 19 studies of patients receiving chemotherapy, 12 (n=1,017 enrolled) used regimens that included either cisplatin or carboplatin and 5 trials (n=672 enrolled) used regimens that did not include platinum. Two studies (n=106 enrolled) did not provide information on the cancer treatment regimens utilized. Seven trials (n=384 enrolled) used chemotherapy alone, three trials (n=132 enrolled) used radiation therapy alone, and five trials (n=326 enrolled) used chemotherapy plus radiation therapy. Seven trials (n=1,085 enrolled) did not provide information on use of radiation therapy.

##### Age

Three small trials (n=108 enrolled) were limited to pediatric patients. Although many trials included patients older than 65 years, and some even included patients in their eighties and nineties, none of the included trials provided data separately for geriatric populations.

##### Transfusion history

Most trials did not provide information on the previous transfusion history of the patients enrolled. Furthermore, for most trials with data, the percentage of previously transfused patients was between 21 percent and 79 percent and outcomes were not reported separately based on previous transfusion history. Only three studies (n=204 enrolled) reported outcomes for patient groups in which <20 percent were previously transfused, and only one study (n=50 enrolled) reported on patients of whom >80 percent were previously transfused.

##### Iron supplementation

Nine trials (n=449 enrolled) supplemented both epoetin-treated and control arms with iron, and three trials (n=194 enrolled) did not supplement either arm.

##### Predictors of response

Ten studies (n=955) reported information on factors thought to predict response to epoetin treatment. Table 33, presented in the Results section of this chapter, reports the results on any factor that was analyzed as a potential predictor of response in at least two papers.

Table 33. Results for any potential predictor reported by two or more studies

Predictor | Number of Studies Reporting | Number of Studies with Significant Result | Comment
Baseline serum erythropoietin level | 6 | 0
Observed/predicted serum erythropoietin ratio (O/P) | 2 | 0 | ten Bokkel Huinink, de Swart, van Toorn, et al., (1998) reported nonsignificant trend for O/P <0.8, p=0.147 (chi-square)
Type of malignancy | 4 | 0
Presence of metastases | 2 | 0
Disease severity | 4 | 0
Platelet count | 2 | 0
Ferritin | 3 | ~1 | Henke, Guttenberger, Barke, et al., (1999) reported a correlation between serum ferritin and the Hb increment at week (r^2^=0.34)
Serum iron | 3 | 0
Total iron-binding capacity | 2 | 0
Type of chemotherapy | 2 | 0
Patient age | 2 | 0

### Interventions

All trials compared the outcomes of managing anemia with epoetin treatment (plus transfusion if necessary) to those obtained with RBC transfusion alone in patients undergoing therapy for a malignancy.

#### Epoetin

The characteristics of epoetin administration of interest to this analysis are route of administration, dose, dosing regimen, and duration of treatment. Patients in the epoetin arms were transfused if necessary, generally under the same conditions as for control patients (see Red Blood Cell Transfusion, following).

##### Route

Seventeen of the trials in this evidence review are two-arm trials comparing subcutaneous epoetin with transfusion alone. Table 9 summarizes the dosages, dosage regimens, and treatment durations used in these studies. Two three-arm trials (n=252) compared subcutaneous epoetin at two different doses with transfusion alone (ten Bokkel Huinink, de Swart, van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999); these are summarized in Table 10.

Table 9. Two-Arm Studies of Subcutaneous Epoetin

Range of Weekly Epoetin Dose | Epoetin Treatment Regimen | Treatment Duration | No. of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
300-450 U/kg | Fixed dose and continuous treatment | <10 weeks | 1 | 34 (17+17) | 34 (17+17)
300-450 U/kg | Fixed dose and continuous treatment | 2-16 weeks | 2 | 265 (127+138) | 227 (105+122)
300-450 U/kg | Fixed dose and continuous treatment | >20 weeks | 1 | 63 (46+17) | 56 (40+16)
300-450 U/kg | Fixed dose and continuous treatment | Subtotals | 4 | 362 (190+172) | 317 (162+155)
300-450 U/kg | Decreasing doses at Hb > specified thresholds | < 10 weeks | 1 | 100 (50+50) | 99 (49+50)
300-450 U/kg | Decreasing doses at Hb > specified thresholds | 12-16 weeks | 3 | 351 (172+179) | 340 (166+174)
300-450 U/kg | Decreasing doses at Hb > specified thresholds | Subtotals | 4 | 451 (222+229) | 439 (215+224)
300-450 U/kg | Increasing doses for nonresponders | 12-16 weeks | 2 | 91 (40+51) | 89 (39+50)
300-450 U/kg | Increasing doses for nonresponders | >20 weeks | 2 | 429 (148+281) | 408 (137+271)
300-450 U/kg | Increasing doses for nonresponders | Subtotals | 4 | 520 (188+332) | 497 (176+321)
300-450 U/kg | Totals for all low-dose studies | | 12 | 1,333 (600+733) | 1,253 (553+700)
750-1,000 U/kg | Fixed & continuous | 12-16 weeks | 1 | 50 (25+25) | 50 (25+25)
750-1,000 U/kg | Decreasing doses | < 10 weeks | 3 | 164 (105+59) | 162 (105+57)
750-1,000 U/kg | Decreasing doses | >20 weeks | 1 | 30 (15+15) | 30 (15+15)
750-1,000 U/kg | Totals for all high-dose studies | | 5 | 244 (145+99) | 242 (145+97)

Table 10. Three-arm subcutaneous studies -- direct comparison of dosage

Study | Epoetin Treatment Regimen | Epoetin Treatment Duration | Weekly Dose (units per kg per week) | N Enrolled | N Evaluable
Thatcher, De Campos, Bell, et al., 1999 | Stop/start or decreasing doses | >20 weeks | 0 | 44 | 44
Thatcher, De Campos, Bell, et al., 1999 | Stop/start or decreasing doses | >20 weeks | 450 sc | 42 | 42
Thatcher, De Campos, Bell, et al., 1999 | Stop/start or decreasing doses | >20 weeks | 900 sc | 44 | 44
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Stop/start or decreasing doses | >20 weeks | 0 | 34 | 33
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Stop/start or decreasing doses | >20 weeks | 450 sc | 46 | 45
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Stop/start or decreasing doses | >20 weeks | 900 sc | 42 | 42

Three studies (n=98 enrolled) used intravenous administration (Table 11). Because the biological effectiveness of intravenous epoetin is less, relative to the same dose administered subcutaneously, we did not compare outcomes of intravenous with those of subcutaneous epoetin.

Table 11. Studies of intravenous epoetin

Weekly Dose of Epoetin | Epoetin Treatment Regimen | Treatment Duration | No. of Studies | N Enrolled (controls+treated) | N Evaluable (controls+treated)
450 U/kg | Increasing | 12-16 weeks | 1 | 24 (12+12) | 20 (10+10)
1,200 U/kg | Decreasing | >20 weeks | 1 | 30 (14+16) | 29 (14+15)
450/900 U/kg | Decreasing | < 10 weeks | 1 | 44 (11+19+14) | 44 (11+19+14)

##### Dose

In studies using the subcutaneous route of administration, the most common initial dose was 150 units/kg administered three times weekly; when a higher dose was used, the most common was 300 units/kg administered three times weekly. A few studies used different dosages and frequencies. To facilitate comparison, dosages were calculated as units/kg per week and classified into one of two categories: 300 to 450 and 700 to 1,000 units/kg per week. We assumed that, for the range of doses and frequencies in these categories, differences in frequency of administration would have a negligible effect on the bioavailability of the dose. Twelve two-arm trials (n=1,333) used the lower dose range and five trials (n=544) used the higher dose range. Two three-arm trials (n=252) compared initial doses of 450 to 900 units/kg per week.

One study (Oberhoff, Neri, Amadori, et al., 1998) treated all patients with the same total dose, 5,000 units daily, regardless of weight or body size. This trial (n=217) was omitted from the comparison of interventions since dosage could not be classified as described.

##### Dosing regimen

Among studies using subcutaneous epoetin in the lower dose range, four (n=520) increased the initial dose for nonresponders after a fixed period of time; four (n=451) decreased the dose for responders; and four (n=362) used a fixed and continuous dose throughout the treatment period. The two trials (n=252) that compared initial doses of 450 to 900 units/kg per week used decreasing dose regimens.

##### Duration of treatment

Treatment duration was grouped into three classes: >20 weeks, 12 to 16 weeks, and <10 weeks. In two trials, treatment duration was not reported, but a minimum duration of treatment could be ascertained and was used to group the study into one of the three classes. Of studies using epoetin subcutaneously, treatment duration was >20 weeks in six trials (n=774), 12 to 16 weeks in eight trials (n=757), and <10 weeks in five trials (n=298).

#### Red Blood Cell Transfusion

All included studies managed anemia in control patients (and also as necessary in epoetin-treated patients) by transfusion of packed RBCs. Ten of the trials specified transfusion at Hb levels that ranged from 6.0 to 9.7 g/dL across the studies (Evidence Table I-1). Three studies reported that patients were transfused at the discretion of the investigator or treating physician (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Thatcher, De Campos, Bell, et al., 1999). Presumably, transfusion also was at the physician's discretion in the remaining studies. Only one report (Wurnig, Windhager, Schwameis, et al., 1996) specified a protocol for determining the number of RBC units transfused at each instance of transfusion: a minimum of two units given at once. No other details were provided on transfusion methods.

Only six studies mentioned symptomatic anemia as an indication for RBC transfusion. Three of the six did not specify symptoms indicating a need for RBC transfusion (Leon, Jimenez, Barona, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; Varan, Buyukpamukcu, Kutluk, et al., 1999). The other three listed dyspnea, tachycardia, severe asthenia, and/or severe reduction of physical activity not attributable to disease progression (Cascinu, Fedeli, Del Ferro, et al., 1994; Del Mastro, Venturini, Lionetto, et al., 1997; Kurz, Marth, Windbichler, et al., 1997).

#### Placebo

Seven of 22 trials gave placebo to patients in the control arm (Evidence Table I-1), using the identical route of administration as for epoetin in the experimental arm. When described, placebo was a sterile saline solution with or without buffer and with or without human serum albumin. One report described the use of identical vials for epoetin and placebo (Kurz, Marth, Windbichler, et al., 1997), whereas a second described identical sets of prefilled syringes (Cascinu, Fedeli, Del Ferro, et al., 1994). No other information was available on the composition, packaging, or administration of placebo.

### Outcomes of Interest

#### Efficacy Outcomes

Table 12 summarizes the evidence available from studies included in this systematic review on the outcomes of interest, grouped by mean or median Hb at study entry.

- Change in Hb levels (or data to calculate Hb change) was reported in 16 trials (n=1,407 enrolled).
- Percentage of patients demonstrating hematologic response was reported in 11 studies (n=1,361 enrolled). Response was defined as an increase in Hb level either by a specified amount (usually 2 g/dL; see Evidence Table I-1) or to a specified target, without use of RBC transfusion.
- Percentage of patients transfused was reported in 17 trials (n=1,703 enrolled).
- The number of RBC units transfused per patient was reported in 12 trials (n=1,093).
- Quality of life was reported in nine trials (n=981).

Table 12. Evidence to compare outcomes by baseline mean or median hemoglobin

Outcome | Hb Level at Baseline | No. of Studies | N Enrolled (controls+treated) | N Evaluated (controls+treated)
Percent of patients responding | Not specified | 1 | 54 (24+30) | 49 (22+27)
Percent of patients responding | < 10 g/dL | 6 | 1,026 (437+589) | 960 (399+561)
Percent of patients responding | >10 and <12 g/dl | 2 | 103 (66+37) | 96 (60+36)
Percent of patients responding | >12 g/dL | 2 | 178 (68+110) | 176 (68+108)
Percent of patients responding | TOTALS | 11 | 1,361 (595+766) | 1,281 (549+732)
Change in Hb levels | < 10 g/dL | 7 | 883 (369+514) | 855 (353+502)
Change in Hb levels | >10 and <12 g/dl | 4 | 216 (120+96) | 214 (119+95)
Change in Hb levels | >12 g/dl | 5 | 308 (131+177) | 306 (131+175)
Change in Hb levels | TOTALS | 16 | 1,407 (620+787) | 1,375 (603+772)
Percent of patients transfused | < 10 g/dL | 9 | 1,134 (491+643) | 1,064 (451+613)
Percent of patients transfused | >10 and <12 g/dl | 5 | 347 (183+164) | 335 (175+160)
Percent of patients transfused | >12 g/dl | 3 | 222 (90+132) | 222 (90+132)
Percent of patients transfused | TOTALS | 17 | 1,703 (764+939) | 1,621 (716+905)
RBC units per patient | < 10 g/dL | 7 | 725 (350+375) | 671 (319+352)
RBC units per patient | >10 and <12 g/dl | 3 | 208 (76+132) | 203 (74+129)
RBC units per patient | >12 g/dl | 2 | 160 (59+101) | 160 (59+101)
RBC units per patient | TOTALS | 12 | 1,093 (485+608) | 1,034 (452+582)
Quality of life | < 10 g/dL | 5 | 749 (302+447) | 722 (287+435)
Quality of life | >10 and <12 g/dl | 0 | 0 | 0
Quality of life | >12 g/dl | 4 | 232 (97+135) | 230 (97+133)
Quality of life | TOTALS | 9 | 981 (399+582) | 952 (384+568)

That all outcomes were not reported by all studies raises the possibility of reporting bias. For example, 9 of 10 studies with baseline Hb <10 g/dL reported percentage of patients transfused, but 4 of 12 studies (33 percent) with baseline Hb >10g/dL did not. Thus, studies of patients at lower baseline risk of transfusion reported percentage of patients transfused less frequently than studies of patients who had higher risk of transfusion.

None of the trials reported on symptoms of anemia (including shortness of breath, dyspnea on exertion, or angina) or number of days in hospital. The only trial to report on changes in performance status used Karnovsky performance status as a quality-of-life surrogate (Leon, Jimenez, Barona, et al., 1998).

#### Reporting of Statistical Significance

Most of the trials in this evidence base are small. Of the 22 trials, only 4 (n=891) enrolled more than 100 patients (range 132 to 375) with >50 in each epoetin arm. The remaining trials, which consisted of 15 two-arm trials and 3 three-arm trials, included 53 percent of all patients in this evidence base. Among these smaller studies, the mean number of patients per arm was 26.5 (range 12 to 50).

It is likely that many of these trials lacked adequate statistical power. For example, we calculated that detection of a 50 percent reduction in the percentage of patients transfused at 80 percent power would require 58 patients per study arm. In the only two trials that provided calculations of necessary sample size and assumptions about reductions in transfusion requirements, reductions of 70 percent and 80 percent were assumed (Del Mastro, Venturini, Lionetto, et al., 1997; Porter, Leahey, Polisse, et al., 1996). Therefore, the sample size in these trials was insufficient to detect smaller reductions in the percentage of patients transfused.

Studies were not consistent in reporting the statistical significance or p value for differences in outcomes between epoetin and control arms. Unfortunately, most studies that did not report P values also did not provide sufficient information to calculate p-values. However, where information was available, p values were calculated; these are indicated in the evidence tables. In this analysis, studies that report a p value of <0.05 are considered to have a statistically significant difference in outcome between the study arms. Some studies also reported that results were not significant, without providing p values. For five studies, we determined by calculations for our meta-analysis whether the result reported for the percentage of patients transfused was statistically significant. (An odds ratio for transfusion with a 95 percent confidence interval that did not include 1.0 was considered significant.)

Eleven studies reported p values or described the statistical significance for differences in some, but not all, outcomes on which they provided data (Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Del Mastro, Venturini, Lionetto, et al., 1997; Dusenbery, McGuire, Holt, et al., 1994; Kurz, Marth, Windbichler, et al. 1997; Littlewood, Bajetta, Cella, et al., 1999; Oberhoff, Neri, Amadori, et al., 1998; Sweeney, Nicolae, Ignacio, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; Varan, Buyukpamukcu, Kutluk, et al., 1999; Welch, James, Wilkinson, et al., 1995). It is possible, although by no means certain, that failure to report a p value indicates that the result was not statistically significant. In one case, our meta-analysis confirmed that percentage of patients transfused was not significant (Case, Bukowski, Carey, et al., 1993), but in another case we found it was significant (Oberhoff, Neri, Amadori, et al., 1998).

Three studies did not report p values for any outcomes of interest to this systematic review (Quirt, Couture, Pichette, et al., 1996; Silvestris, Romito, Fanelli, et al., 1995; ten Bokkel Huinink, deSwart, van Toorn, et al., 1998). However, our meta-analysis found that one of these had a significant result (ten Bokkel Huinink, de Swart, van Toorn, et al., 1998).

In some cases, the trial did not report an outcome in the specific format sought for this systematic review (e.g., change in Hb levels), but did provide sufficient data for us to calculate the outcome (e.g., Hb at entry and Hb at end of study). In such cases, where sufficient data were reported we also tested for statistical significance.

#### Adverse Events

Table 13 summarizes reporting on adverse events by the studies included in this review.

Table 13. Adverse events reported by studies on patients being treated for malignancy

Adverse Event | No. of Studies Reporting | N Evaluated (controls+treated)
Any adverse effect (each patient counted once only) | 10 | 1155 (473+682)
Hypertension (highest freq. if systolic/diastolic separated) | 9 | 722 (285+437)
Deep vein thrombosis or thromboembolism | 6 | 580 (238+342)
Hemorrhage and/or thrombocytopenia | 2 | 161 (80+81)
Skin rash, irritation, and/or pruritus | 6 | 372 (121+251)
Seizures | 4 | 408 (200+208)
Injection site pain | 3 | 177 (77+100)
Fatigue (separate from quality-of-life reporting) | 4 | 699 (264+435)
Withdrawals (due to adverse events) | 8 | 846 (387+459)
Mortality (from any cause, while on study) | 2 | 338 (137+201)

### Study Quality

Quality of study design and conduct was assessed as described in Chapter 2, Methodology. The objective was to identify a group of higher quality trials for purposes of sensitivity analysis. Table 14 displays the results of our assessment; trials classified as higher quality are shown by the use of bold font and nonrandomized trials are indicated in italics. Higher quality trials were randomized controlled trials, were double blinded, and met the condition for percentage of patients excluded from the analysis for having a baseline Hb below the specified threshold.

Table 14. Assessment of study quality^1^

Citation | Blinding (required) | Percentage of Excluded Subjects Below Specified Threshold? ^2^ (required) | Accounted for Excluded Patients? | Allocation Concealed? | Transfusion Trigger? | R/O Other Anemia Causes? ^3^ | Fe Status confirmed? ^4^ | Patients blinded to Hb levels? ^5^
Mean/Median Baseline Hb <10 g/dL; Adult Patients
Silvestris, Romito, Fanelli, et al., 1995 ^6^ | Unblinded | Yes | No/NS | Yes | NA ^7^ | No | Yes
Oberhoff, Neri, Amadori, et al., 1998 | Unblinded | No | No/NS | No/NS | No | No | No
Case, Bukowski, Carey, et al., 1993 | Double blinded | Yes | No | No/NS | Yes | Yes | No | No/NS
Henry, Brooks, Case, et al., 1995 | Double blinded | Yes | No | No/NS | Yes | Yes | No | No/NS
Cascinu, Fedeli, Del Ferro, et al., 1994 | Double blinded | Yes | Yes | Yes | Yes | No | Yes
Kurz, Marth, Windbichler, et al., 1997 | Double blinded | Yes | No | Yes | Yes | No | Yes | No/NS
Littlewood, Bajetta, Cella, et al., 1999 (Abstract/Slides) | Double blinded | Yes | No/NS | No/NS | Yes | No | No | No/NS
Mean/Median Baseline Hb <10 g/dL; Pediatric Patients
Varan, Buyukpamukcu, Kutluk, et al., 1999 | Unblinded | Yes | Yes | No/NS | Yes | No | No
Leon, Jimenez, Barona, et al., 1998 | Unblinded^8^ | Yes | Yes | No/NS | Yes | Yes | Yes | No/NS
Porter, Leahey, Polise, et al., 1996 | Double blinded | No | No/NS | Yes | Yes | No | Yes
Mean/Median Baseline Hb >10 and <12 g/dL; Adult Patients
Markman, Reichman, Hakes, et al., 1993 | Unblinded | No | No | No/NS | Yes | N/A^9^ | No
Dusenbery, McGuire, Holt, et al., 1994 | Unblinded^8^ | Yes | Yes | No/NS | Yes | No | Yes
Lavey and Dempsey, 1993 | Unblinded | Yes | Yes | No/NS | NA^7^ | No | Yes
Wurnig, Windhager, Schwameis, et al., 1996 | Double blinded | Yes | Yes | No/NS | Yes | Yes | No
Henke, Guttenberger, Barke, et al., 1999 | Unblinded | Yes | Yes | No/NS | NA ^7^ | No | Yes
Quirt, Couture, Pichette, et al., 1996 (Abstract) | Single blinded | Yes | No/NS | No/NS | No | No | No | No/NS
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | Unblinded | Yes | Yes | Yes | Yes | No | No
Mean/Median Baseline Hb >12 g/dL; Adult Patients
Gamucci, Thorel, Frasca, et al., 1993 | Unblinded | Yes | No/NS | No/NS | NA ^7^ | N/A ^9^ | Yes
Sweeney, Nicolae, Ignacio, et al., 1998 | Unblinded | Yes | Yes | No/NS | NA ^7^ | Yes | Yes | No/NS
Del Mastro, Venturini, Lionetto, et al., 1997 | Unblinded | Yes | Yes | Yes | Yes | N/A | Yes | No/NS
Thatcher, De Campos, Bell, et al., 1999 | Unblinded | Yes | Yes | No/NS | Yes | Yes | No | No
Welch, James, Wilkinson, et al., 1995 | Unblinded | Yes | Yes | No/NS | Yes | N/A | Yes | No/NS

^1^1"Higher quality" trials in bold font; nonrandomized studies in italics

2 <5 percent of subjects were excluded in each study arm OR <10 percent of subjects were excluded in each study arm AND the ratio between arms for the percentage of subjects excluded from the analysis was <2:1.

3 Ruled out all of the following: iron, B12, and folate deficiencies, occult bleeding, and hemolytic anemia.

4 Epoetin arm supplemented OR serum Fe, ferritin, and transferrin saturation all monitored and reported in results.

5 Only evaluated for studies reporting quality-of-life outcomes.

6 Mean/median baseline Hb not specified, but excluded patients with baseline Hb >10 g/dL.

7 NA=Not applicable because transfusion outcomes were not reported.

8 Historical controls only; all other nonrandomized studies used concurrent controls.

9 N/A=Not applicable because enrollment limited to nonanemic patients.

NS=not specified.

Six of the 22 trials were identified as higher quality for purposes of sensitivity analysis. Five of these (n=799) were studies of patients with baseline Hb levels <10 g/dL (Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Kurz, Marth, Windbichler, et al., 1997; Littlewood, Bajetta, Cella, et al., 1999). The sixth study (n=30) was in the category with baseline Hb >10 and <12 g/dL (Wurnig, Windhager, Schwameis, et al., 1996). With two exceptions, lesser quality trials were all unblinded. Quirt, Couture, Pichette, et al., (1996) used placebo, but only published an abstract and did not report additional detail on blinding. The trial reported by Porter, Leahey, Polise, et al. (1996) was double blinded but did not meet the criterion for percentage of patients excluded from analysis. Three additional studies also failed to meet the criterion for percentage of patients excluded from analysis (Markman, Reichman, Hakes, et al., 1993; Oberhoff, Neri, Amadori, et al., 1998; Quirt, Couture, Pichette, et al., 1996). However, taken as a whole, the studies included in this systematic review retained a high proportion of enrolled patients for efficacy analysis (95 percent).

Adequate statistical power was more likely to be a feature of higher quality trials than lesser quality trials. Three of the four studies with more than 100 patients enrolled were higher quality studies (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Littlewood, Bajetta, Cella, et al., 1999).

We also assessed studies for additional quality domains and features to control for specific confounders. Of the higher quality studies, three reported adequate concealment of treatment allocation (Case, Bukowski, Carey, et al., 1993; Cascinu, Fedeli, Del Ferro, et al., 1994; Kurz, Marth, Windbichler, et al., 1997). Adequate concealment of allocation was also reported in four lesser quality studies, including the double-blinded trial by Porter (Silvestris, Romito, Fanelli, et al., 1995; Porter, Leahey, Polisse, et al., 1996: ten Bokkel Huinink, de Swart, vanToorn, et al., 1998; Del Mastro, Venturini, Lionetto, et al.. 1997). Five of the six higher quality studies adequately accounted for the reasons subjects were excluded from the analysis of study results. The sixth study by Littlewood, Bajetta, Cella, et al. (1999) is unpublished, and a full report is not yet available. Of the 16 lesser quality studies, 11 were judged to adequately account for patients excluded from analysis; 5 did not.

Of the higher quality studies, all but the one by Littlewood and coworkers (1999), for which a full report is not yet available, reported a transfusion trigger or provided data to demonstrate that Hb at transfusion was comparable for all study arms. Two lesser quality studies reported transfusion outcomes but did not specify a transfusion trigger or show that the mean Hb at transfusion was comparable for epoetin-treated patients and controls. One of these only published an abstract (Quirt, Couture, Pichette, et al., 1996), whereas the second published a more detailed report (Oberhoff, Neri, Amadori, et al., 1998). The question of a transfusion trigger was not applicable to five studies that did not report transfusion outcomes since they could not be included in either the meta-analysis or the sensitivity analysis.

The presence of treatable other causes of anemia might lead to underestimating the effects of epoetin. Three of the higher quality studies reported ruling out anemia caused by iron deficiency, vitamin B_12_ deficiency, folate deficiency, occult bleeding, and hemolytic anemia prior to randomization (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Wurnig, Windhager, Schwameis, et al., 1996). Two lesser quality studies also reported ruling out all these causes of anemia (Leon, Jimenez, Barona, et al., 1998; Sweeney, Nicolae, Ignacio, et al., 1998). Thirteen additional studies reported ruling out at least one of these treatable causes of anemia but did not specify that each of the five potential causes had been ruled out.

We applied a rather stringent requirement to assess the adequacy of measures utilized to verify patients' iron status. We required trials that did not supplement patients in the epoetin arm with iron to report levels of serum iron, ferritin, and transferrin saturation as evidence that their iron stores were adequate. Five of the 10 studies that did not meet this requirement (see Table 14) stated that one or more parameters of iron metabolism was monitored during the study; however, the results were not reported (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Oberhoff, Neri, Amadori, et al., 1998; Thatcher De Campos, Bell, et al., 1999; Wurnig, Windhager, Schwameis, et al., 1996).

In higher quality studies that reported quality-of-life outcomes, the proportion of missing data was much greater for quality-of-life outcomes than for hematologic or transfusion outcomes. Only the study by Kurz, Marth, Windbichler, et al. (1997) reported the same number of patients evaluable for quality-of-life outcomes as were evaluable for transfusion and hematologic outcomes. In all other higher quality studies, data on quality-of-life outcomes were missing for 10 percent or more of enrolled patients from one or both study arms. Thus, with respect to quality-of-life outcomes, double blinding is the only attribute that distinguishes the group of higher quality studies from the lesser quality studies, all of which were unblinded. Moreover, no published studies reported on features known to be important in minimizing bias in assessment of quality-of-life outcomes, including:

- Procedures to minimize the impact of other factors on responses to quality-of-life instruments (e.g., blinding patients to Hb levels or cell counts until after completion of questionnaires);
- Handling of missing data in the analysis; and
- Prospectively defining the minimum differences in quality-of-life scores to be considered clinically significant.

## Results

### Key Question 1 Results

This section analyzes efficacy outcomes across studies grouped by baseline Hb level. We examine hematologic outcomes, transfusion outcomes, and health-related quality-of-life outcomes. For hematologic and transfusion outcomes, we calculated the difference between the treatment and control arm of each trial, and we report the range of difference for each outcome. For transfusion outcomes, we also conducted a meta-analysis of the odds of transfusion.

Throughout this Results section, "n" refers to the number of patients evaluable. Outcomes tables show higher quality trials in bold font; nonrandomized trials are indicated in italics.

The conclusion to this section addresses two questions:

1. What are the outcomes of managing anemia with epoetin (plus transfusion if necessary) compared with transfusion alone?
2. What are the relative effects of epoetin treatment when different Hb thresholds are used to initiate treatment?

#### Hematologic Outcomes

Table 15 summarizes hematologic outcomes: the percentage of patients with a hematologic response and the mean change in Hb level (median if no mean was reported). Our description of results focuses on the percentage of patients responding, which incorporates a minimum level or target Hb change and the proportion of patients achieving it. (See Evidence Table I-1 for each study's definition of response.) Mean change in Hb level is noted for studies where this outcome was statistically significant but percentage of patients responding was not.

Table 15. Hematologic outcomes for studies grouped by baseline Hb levels^1^

Citation | Transf. Trigger or mn Hb @ transf. ^2^ | Baseline Hb | Study Arm | N Enrolled | N Evaluable | EPO Dose (units/kg/week) | | % Response | p Value | Difference in % response (epo-control) | Hb Change (± SD) | p Value | Difference in Hb Change (epo-control)
Citation | Transf. Trigger or mn Hb @ transf. ^2^ | Baseline Hb | Study Arm | N Enrolled | N Evaluable | Start | Final | % Response | p Value | Difference in % response (epo-control) | Hb Change (± SD) | p Value | Difference in Hb Change (epo-control)
Mean/Median Baseline Hb <10 g/dL; Adult Patients
Silvestris, Romito, Fanelli, et al., 1995 | NA | ^3^ | Control | 24 | 22 | 0 | | 0.0
Silvestris, Romito, Fanelli, et al., 1995 | NA | ^3^ | Epoetin | 30 | 27 | 450 | 900 | 77.8 | | 77.8
Oberhoff, Neri, Amadori, et al., 1998 | NA | 10.3 ^4^ | Control | 110 | 88 | 0 | | 6.8
Oberhoff, Neri, Amadori, et al., 1998 | NA | 9.6 ^4^ | Epoetin | 117 | 101 | ~450 | | 34.7 | 0.0001 | 27.9
Case, Bukowski, Carey, et al., 1993 | 8.2 | 9.8 | Control | 76 | 74 | 0 | | 13.5 | | | 0.33
Case, Bukowski, Carey, et al., 1993 | 8.2 | 9.5 | Epoetin | 81 | 79 | 450 | | 58.2 | | 44.7 | 2.3 | 0.0001 | 1.97
Henry, Brooks, Case, et al., 1995 | 8.5 | 9.5 | Control | 65 | 61 | 0 | | 6.6 | | | 0.4^5^±1.7
Henry, Brooks, Case, et al., 1995 | 8.2 | 9.8 | Epoetin | 67 | 64 | 450 | | 48.4 | <0.0001 | 41.8 | 2.0^5^±2.3 | <0.0001 | 1.60
Cascinu, Fedeli, Del Ferro, et al., 1994 | 8.0 | 8.7 | Control | 50 | 49 | 0 | | 2.0 | | | −0.6
Cascinu, Fedeli, Del Ferro, et al., 1994 | 8.0 | 8.6 | Epoetin | 50 | 50 | 300 | | 82.0 | | 80.0 | 1.9 | | 2.5
Kurz, Marth, Windbichler, et al., 1997 | 8.0 | 9.85 | Control | 12 | 12 | 0 | | 0.0 | | | 0.22
Kurz, Marth, Windbichler, et al., 1997 | 8.0 | 9.88 | Epoetin | 23 | 23 | 450 | 900 | 56.5 | 0.001 | 56.5 | 3.3 | | 3.08
Littlewood, Bajetta, Cella, et al., 1999 (Abstract/slides) | NA | 9.7 | Control | 124 | 115 | 0 | | 19.1 | | | 0.9
Littlewood, Bajetta, Cella, et al., 1999 (Abstract/slides) | NA | 9.9 | Epoetin | 251 | 244 | 450 | 900 | 70.5 | 0.001 | 51.4 | 2.5 | | 1.60
Mean/Median Baseline Hb <10 g/dL; Pediatric Patients
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 6.0 | 8.48 | Control | 17 | 17 | 0 | | | | | −0.07
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 6.0 | 8.5 | Epoetin | 17 | 17 | 450 | | | | | 1.71 | | 1.78
Leon, Jimenez, Barona, et al., 1998 | 6.0 | 9.5 | Control | 25 | 25 | 0 | | | | | 0.1
Leon, Jimenez, Barona, et al., 1998 | 6.0 | 9.8 | Epoetin | 25 | 25 | 750 | | 72.0 | | | 2.6 | <0.001 | 2.5
Porter, Leahey, Polise, et al., 1996 | 8.0 | 9.4 ^4^ | Control | 12 | 10 | 0
Porter, Leahey, Polise, et al., 1996 | 8.0 | 9.7 ^4^ | Epoetin | 12 | 10 | 450 | 900
Mean/Median Baseline Hb >10 and <12 g/dL; Adult Patients
Markman, Reichman, Hakes, et al., 1993 | 8.0 | 11.1^4^ | Control | 46 | 40 | 0 | | 40.0
Markman, Reichman, Hakes, et al., 1993 | 8.0 | 11.5^4^ | Epoetin | 17 | 16 | 350 | | 87.5 | <0.005 | 47.5
Dusenbery, McGuire, Holt, et al., 1994 | 9.5 | 11.1^4^ | Control | 61 | 61 | 0 | | | | | −0.8
Dusenbery, McGuire, Holt, et al., 1994 | 9.5 | 10.3^4^ | Epoetin | 15 | 15 | 1000 | 500 | | | | 2.9 | 0.001 | 3.70
Lavey and Dempsey, 1993 | NA | 11.8 | Control | 20 | 20 | 0 | | 5.0 | | | 0.0±0.7
Lavey and Dempsey, 1993 | NA | 11.9 | Epoetin | 20 | 20 | 900 | 450 | 80.0 | <0.001 | 75.0 | 3.2±1.78 | <0.001 | 3.2
Wurnig, Windhager, Schwameis, et al., 1996 | 8.5 | 10.5 | Control | 14 | 14 | 0
Wurnig, Windhager, Schwameis, et al., 1996 | 8.5 | 11 | Epoetin | 16 | 15 | 1200 | | | | | | NS
Henke, Guttenberger, Barke, et al., 1999 | NA | 12.3 | Control | 11 | 11 | 0 | | | | | 0.6±1.4
Henke, Guttenberger, Barke, et al., 1999 | NA | 10.9 | Epoetin 1 | 19 | 19 | 450 | | | | | 3.2±1.6 | <0.0001 | 2.6
Henke, Guttenberger, Barke, et al., 1999 | NA | 11.4 | Epoetin 2 | 14 | 14 | 900 | | | | | 3.5±1.2 | <0.0001 | 2.9
Quirt, Couture, Pichette, et al., 1996 (Abstract) | NA | 10.7 ^6^ | Control | 28 | 27 | 0 | | | | | 0.6
Quirt, Couture, Pichette, et al., 1996 (Abstract) | NA | 10.9 ^6^ | Epoetin | 28 | 27 | 450 | 900 | | | | 1.6 | | 1.0
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 9.7 | 11.8 ^4^ | Control | 34 | 33 | 0
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 9.7 | 12.0 ^4^ | Epoetin 1 | 46 | 45 | 450 | 225
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 9.7 | 11.6 ^4^ | Epoetin 2 | 42 | 42 | 900 | 450
Mean/Median Baseline Hb >12; Adult Patients
Gamucci, Thorel, Frasca, et al., 1993 | NA | 12.7 | Control | 17 | 17 | 0 | | | | | −1.5±1.67
Gamucci, Thorel, Frasca, et al., 1993 | NA | 12.2 | Epoetin | 21 | 21 | 450 | | | | | 0.9±1.32 | <0.005 | 2.4
Sweeney, Nicolae, Ignacio, et al., 1998 | NA | 10.7 | Control | 24 | 24 | 0 | | 0.0 | | | 0.29
Sweeney, Nicolae, Ignacio, et al., 1998 | NA | 12.1 | Epoetin | 24 | 22 | 1000 | 500 | 45.5 | | 45.5 | 1.55 | 0.0012 | 1.26
Del Mastro, Venturini, Lionetto, et al., 1997 | 8.0 | 13.1 | Control | 31 | 31 | 0 | | | | | −3.1±1
Del Mastro, Venturini, Lionetto, et al., 1997 | 8.0 | 13 | Epoetin | 31 | 31 | 450 | | | | | −0.8±1.4 | <0.005 | 2.3
Thatcher, De Campos, Bell, et al., 1999 | 8.5 | 13.4 ^4^ | Control | 44 | 44 | 0 | | 34.1 | | | −3.4
Thatcher, De Campos, Bell, et al., 1999 | 8.6 | 13.7 ^4^ | Epoetin 1 | 42 | 42 | 450 | 225 | 52.4 | <0.05 | 18.3 | −3.2 | | 0.2
Thatcher, De Campos, Bell, et al., 1999 | 8.0 | 13.6 ^4^ | Epoetin 2 | 44 | 44 | 900 | 450 | 61.4 | 0.005 | 27.3 | −3.3 | | 0.1
Welch, James, Wilkinson, et al., 1995 | 8.5 | 12.8 | Control | 15 | 15 | 0 | | | | | −2.1
Welch, James, Wilkinson, et al., 1995 | 8.3 | 13 | Epoetin | 15 | 15 | 900 | 450 | | | | −1.3 | | 0.8

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 Single entry = transfusion trigger; multiple entries = mean Hb levels at transfusion.

3 Mean/median Hb level at baseline not specified, but enrollment limited to patients with Hb ≤10 g/dL.

4 The report provided only a median value, not a mean.

5 Change in Hb level calculated as change in hematocrit divided by 3.

6 Did not specify whether reported value is mean or median.

##### Baseline Hb <10 g/dL

Five of seven trials in adults reported a statistically significant hematologic outcome favoring the epoetin arm. All seven trials reported the percentage of patients with a hematologic response. Four trials (n=708), including three of the five higher quality trials (n=519), observed significantly more responses in the epoetin arms than in controls (Henry, Brooks, Case, et al., 1995; Kurz, Marth, Windbichler, et al., 1997; Littlewood, Bajetta, Cella, et al., 1999; Oberhoff, Neri, Amadori, et al., 1998). In addition, a fifth trial, of higher quality, reported a statistically significantly greater change in Hb levels in the epoetin arm than in controls (Case, Bukowski, Carey, et al., 1993). The remaining studies did not report on statistical significance for either hematologic outcome (Cascinu, Fedeli, Del Ferro, et al., 1994; Silvestris, Romito, Fanelli, et al., 1995;). The range of differences between epoetin and control arms for the percentage of patients responding was 28 percent to 80 percent The range of differences was 1.60 to 3.08 g/dL for mean change in Hb levels.

Among the three pediatric trials, Leon, Jiminez, Barona, et al. (1998) reported a statistically significant change in Hb level. However, this trial reported percent of patients responding only in the epoetin arm. Varan, Buyukpamukcu, Kutluk, et al. (1999) reported an increase in Hb level in the epoetin arm but did not report on statistical significance. In the two trials, the differences between arms for change in mean Hb level were 1.78 and 2.5 g/dL. The pediatric trials did not report any other hematologic outcomes.

##### Baseline Hb >10 and <12 g/dL

Four of seven studies reported a statistically significant hematologic outcome favoring the epoetin arm. Two nonrandomized trials (n=96) reported percentage of patients responding, and the epoetin arm was significantly favored in each (Lavey and Dempsey, 1993; Markman, Reichman, Hakes, et al., 1993). Two additional trials (n=120) reported a significantly greater increase in Hb level (Dusenbery, McGuire, Holt, et al., 1994; Henke, Guttenberger, Barke, et al., 1999). Quirt, Couture, Pichette, et al. (1996) reported a greater increase in the Hb level in the epoetin arm compared with that in the control arm but did not report on significance.

The only higher quality trial (n=29) in this group reported only that there was no significant difference in change in Hb level (Wurnig, Windhager, Schwameis, et al., 1996). The trial by ten Bokkel and colleagues (1998) did not report hematologic outcomes.

In the two studies reporting percentage of patients responding, the differences between epoetin and control arms were 48 percent and 75 percent. For four studies reporting mean Hb change, the range of differences was 1.0 to 3.7 g/dL.

##### Baseline Hb >12 g/dL

Of the five trials in this group, four (n=276) reported a statistically significant hematologic outcome favoring epoetin. The largest study (n=130; Thatcher, De Campos, Bell, et al., 1999) reported a significantly greater percentage of patients responding in the epoetin-treated arm. Three trials reported a significant difference between study arms for the change in Hb level (Del Mastro, Venturini, Lionetto, et al., 1997; Gamucci, Thorel, Frasca, et al., 1993; Sweeney, Nicolae, Ignacio, et al., 1998). The fifth trial reported a smaller decrease in Hb level in the epoetin arm but did not report on significance (Welch, James, Wilkinson, et al, 1995).

In the two studies reporting percentage of patients responding, the differences between epoetin and control arms were 18 percent and 46 percent. For mean Hb change, the range of differences was 0.1 to 2.4 g/dL.

##### Summary

We found adequate and consistent evidence that epoetin increases Hb levels and percentage of patients achieving a hematologic response when compared with controls managed by transfusion alone. The percentage of patients achieving a hematologic response and the magnitude of change in Hb levels produced by epoetin does not appear to differ substantially as a function of the baseline Hb level for initiating epoetin treatment. In trials of adult patients where baseline Hb was <10 g/dL, the range of differences between epoetin and control arms for percentage of patients responding was 28 percent to 80 percent. For baseline Hb >10 and <12 g/dL, the differences were 48 percent and 75 percent, and the range of differences was 18 percent to 46 percent for baseline Hb >12 g/dL. For change in mean Hb levels, the range of differences for the three groups of studies was 1.60 to 3.08 g/dL, 1.0 to 3.7 g/dL, and 0.1 to g/dL. Two pediatric studies on patients with baseline Hb <10 g/dL reported change in mean Hb levels; the differences between the epoetin and control arms were similar (1.78 and 2.5 g/dL).

#### Transfusion Outcomes

Table 16 summarizes transfusion outcomes: the percentage of patients transfused, and the number of RBC units transfused per patient (normalized to 4 weeks on study whenever possible).

Table 16. Transfusion outcomes for studies grouped by baseline Hb levels^1^

Citation | Transf. Trigger or Mn Hb @ Transf. ^2^ | Baseline Hb | Study Arm | N Enrolled | N Evaluable | EPO Dose (units/kg/week) | | % Transfused | p Value | Difference in % Transfused (control-Epo) | RBC Units per Patient ± SD | p Value | RBC Units per Patient per 4 Weeks | Difference in RBC Units per Patient per 4 Weeks (control-Epo)
Citation | Transf. Trigger or Mn Hb @ Transf. ^2^ | Baseline Hb | Study Arm | N Enrolled | N Evaluable | Start | Final | % Transfused | p Value | Difference in % Transfused (control-Epo) | RBC Units per Patient ± SD | p Value | RBC Units per Patient per 4 Weeks | Difference in RBC Units per Patient per 4 Weeks (control-Epo)
Mean/Median Baseline Hb <10 g/dL; Adult Patients
Silvestris, Romito, Fanelli, et al., 1995 | NA | ^3^ | Control | 24 | 22 | 0
Silvestris, Romito, Fanelli, et al., 1995 | NA | ^3^ | Epoetin | 30 | 27 | 450 | 900
Oberhoff, Neri, Amadori, et al., 1998 | NA | 10.3 ^4^ | Control | 110 | 88 | 0 | | 40.9 | | | 0.6 | | 0.6
Oberhoff, Neri, Amadori, et al., 1998 | NA | 9.6 ^4^ | Epoetin | 117 | 101 | ~450 | | 25.7 | ^5^ | 15.2 | 0.5 | 0.044 | 0.5 | 0.1
Case, Bukowski, Carey, et al., 1993 | 8.2 | 9.8 | Control | 76 | 74 | 0 | | 36.8^6^ | | | 1.6±0.3 | | 0.8
Case, Bukowski, Carey, et al., 1993 | 8.2 | 9.5 | Epoetin | 81 | 79 | 450 | | 28.6^6^ | NS^7^ | 8.5^6^ | 0.9±0.3 | NS | 0.5 | 0.3
Henry, Brooks, Case, et al., 1995 | 8.5 | 9.5 | Control | 65 | 61 | 0 | | 68.9 | | | 4.0±0.8 | | 2.0
Henry, Brooks, Case, et al., 1995 | 8.2 | 9.8 | Epoetin | 67 | 64 | 450 | | 53.1 | NS | 15.8 | 4.0±0.9 | NS | 2.0 | 0
Cascinu, Fedeli, Del Ferro, et al., 1994 | 8.0 | 8.7 | Control | 50 | 49 | 0 | | 57.1 | | | 1.8 | | 0.8
Cascinu, Fedeli, Del Ferro, et al., 1994 | 8.0 | 8.6 | Epoetin | 50 | 50 | 300 | | 20.0 | 0.01 | 37.1 | 0.3 | 0.01 | 0.1 | 0.7
Kurz, Marth, Windbichler, et al., 1997 | 8.0 | 9.85 | Control | 12 | 12 | 0 | | 66.7 | | | 3.6 | | 1.2
Kurz, Marth, Windbichler, et al., 1997 | 8.0 | 9.88 | Epoetin | 23 | 23 | 450 | 900 | 21.7 | 0.009 | 45.0 | 1.4 | | 0.5 | 0.7
Littlewood, Bajetta, Cella, et al., 1999 (Abstract/slides) | NA | 9.7 | Control | 124 | 115 | 0 | | 35.7^6^
Littlewood, Bajetta, Cella, et al., 1999 (Abstract/slides) | NA | 9.9 | Epoetin | 251 | 244 | 450 | 900 | 23^6^ | 0.0168 | 12.7^6^
Mean/Median Baseline Hb <10 g/dL; Pediatric Patients
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 6.0 | 8.48 | Control | 17 | 17 | 0 | | 47.1
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 6.0 | 8.5 | Epoetin | 17 | 17 | 450 | | 5.9 | 0.008 | 41.2
Leon, Jimenez, Barona, et al., 1998 | 6.0 | 9.5 | Control | 25 | 25 | 0 | | 96 | | | 3.6 | | 1.2
Leon, Jimenez, Barona, et al., 1998 | 6.0 | 9.8 | Epoetin | 25 | 25 | 450 | | 16 | <0.001 | 80.0 | 0.3 | <0.001 | 0.1 | 1.1
Porter, Leahey, Polise, et al., 1996 | 8.0 | 9.4 ^4^ | Control | 12 | 10 | 0 | | 100 | | | 13.0 ^4^ | | 3.3
Porter, Leahey, Polise, et al., 1996 | 8.0 | 9.7 ^4^ | Epoetin | 12 | 10 | 450 | 900 | 90 | NS | 10.0 | 4.5 ^4^ | 0.01 | 1.1 | 2.2
Mean/Median Baseline Hb >10 and <12 g/dL; Adult Patients
Markman, Reichman, Hakes, et al., 1993 | 8.0 | 11.1 ^4^ | Control | 46 | 40 | 0 | | 22.5
Markman, Reichman, Hakes, et al., 1993 | 8.0 | 11.5 ^4^ | Epoetin | 17 | 16 | 350 | | 6.3 | NS | 16.2
Dusenbery, McGuire, Holt, et al., 1994 | 9.5 | 11.1 ^4^ | Control | 61 | 61 | 0 | | 6.6
Dusenbery, McGuire, Holt, et al., 1994 | 9.5 | 10.3 ^4^ | Epoetin | 15 | 15 | 1000 | 500 | 0.0 | | 6.6
Lavey and Dempsey, 1993 | NA | 11.8 | Control | 20 | 20 | 0
Lavey and Dempsey, 1993 | NA | 11.9 | Epoetin | 20 | 20 | 900 | 450
Wurnig, Windhager, Schwameis, et al., 1996 | 8.5 | 10.5 | Control | 14 | 14 | 0 | | 100 | | | 8.4 | | 1.7
Wurnig, Windhager, Schwameis, et al., 1996 | 8.5 | 11 | Epoetin | 16 | 15 | 1200 | | 53.3 | NS | 46.7 | 2.1 | <0.01 | 0.4 | 1.3
Henke, Guttenberger, Barke, et al., 1999 | NA | 12.3 | Control | 11 | 11 | 0
Henke, Guttenberger, Barke, et al., 1999 | NA | 10.9 | Epoetin 1 | 19 | 19 | 450
Henke, Guttenberger, Barke, et al., 1999 | NA | 11.4 | Epoetin 2 | 14 | 14 | 900
Quirt, Couture, Pichette, et al., 1996 (Abstract) | NA | 10.7 ^8^ | Control | 28 | 27 | 0 | | 29.6 | | | 0.7
Quirt, Couture, Pichette, et al., 1996 (Abstract) | NA | 10.9 ^8^ | Epoetin | 28 | 27 | 450 | 900 | 14.8 | NS ^7^ | 14.8 | 0.2
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 9.7 | 11.8 ^4^ | Control | 34 | 33 | 0 | | 39.4 | | | 1.2 | | 0.2
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 9.7 | 12.0 ^4^ | Epoetin 1 | 46 | 45 | 450 | 225 | 4.4 | ^5^ | 35.0 | 0.3 | | 0.1 | 0.1
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 9.7 | 11.6 ^4^ | Epoetin 2 | 42 | 42 | 900 | 450 | 14.3 | ^5^ | 25.1 | 0.4 | | 0.1 | 0.1
Mean/Median Baseline Hb >12; Adult Patients
Gamucci, Thorel, Frasca, et al., 1993 | NA | 12.7 | Control | 17 | 17 | 0
Gamucci, Thorel, Frasca, et al., 1993 | NA | 12.2 | Epoetin | 21 | 21 | 450
Sweeney, Nicolae, Ignacio, et al., 1998 | NA | 10.7 | Control | 24 | 24 | 0
Sweeney, Nicolae, Ignacio, et al., 1998 | NA | 12.1 | Epoetin | 24 | 22 | 1000 | 500
Del Mastro, Venturini, Lionetto, et al., 1997 | 8.0 | 13.1 | Control | 31 | 31 | 0 | | 6.5
Del Mastro, Venturini, Lionetto, et al., 1997 | 8.0 | 13 | Epoetin | 31 | 31 | 450 | | 0 | NS ^7^ | 6.5
Thatcher, De Campos, Bell, et al., 1999 | 8.5 | 13.4 ^4^ | Control | 44 | 44 | 0 | | 59.1 | | | 6.1 | | 0.9
Thatcher, De Campos, Bell, et al., 1999 | 8.6 | 13.7 ^4^ | Epoetin 1 | 42 | 42 | 450 | 225 | 45.2 | <0.05 | 13.9 | 3.8 | <0.01 | 0.6 | 0.3
Thatcher, De Campos, Bell, et al., 1999 | 8.0 | 13.6 ^4^ | Epoetin 2 | 44 | 44 | 900 | 450 | 20.5 | <0.001 | 38.6 | 2.1 | <0.001 | 0.3 | 0.6
Thatcher, De Campos, Bell, et al., 1999 | 8.5 | 12.8 | Control | 15 | 15 | 0 | | 53.3 | | | 5.4
Welch, James, Wilkinson, et al., 1995 | 8.3 | 13 | Epoetin | 15 | 15 | 900 | 450 | 26.7 | NS | 26.6 | 4.0 | NS

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 Single entry = transfusion trigger; multiple entries = mean Hb levels at transfusion.

3 Mean/median Hb level at baseline not specified, but enrollment limited to patients with Hb ≤10 g/dL.

4 The report provided only a median value, not a mean.

5 Calculated odds ratio for transfusion suggests a significant difference, as upper limit of 95 percent confidence interval is <1.0 (see Meta-Analysis).

6 Measured from day 28 to end of study.

7 Calculated odds ratio for transfusion suggests no significant difference, as upper limit of 95 percent confidence interval is <1.0 (see Meta-Analysis).

8 Did not specify whether reported value is mean or median.

##### Baseline Hb <10 g/dL

Six of seven adult trials, five of which were of higher quality, reported the percentage of patients transfused. All except the trials by Littlewood and colleagues (1999) and Silvestris and colleagues (1995) also reported the number of RBC units transfused per patient, which we normalized to units transfused per patient per 4 weeks for comparative purposes.

In four trials (n=682), including three of higher quality (n=493), significantly fewer patients were transfused in the epoetin arms than in controls (Cascinu, Fedeli, Del Ferro, et al., 1994; Kurz, Marth, Windbichler, et al., 1997; Littlewood, Bajetta, Cella, et al., 1999; Oberhoff, Neri, Amadori, et al., 1998). Oberhoff and colleagues (1998) and Cascinu and colleagues (1994) also reported transfusing significantly fewer RBC units per patient with epoetin treatment. Kurz and colleagues (1997) reported using fewer RBC units per patient in the epoetin arm, but did not report statistical significance. Two trials (n=278), both of higher quality (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995), found no significant difference in percentage of patients or RBC units transfused per patient.

Because the response to epoetin takes several (2 to 4) weeks, and because chemotherapy-related decreases in Hb levels are related to the timing and duration of chemotherapy cycles, the time period selected for reporting can affect whether studies observe significant differences for transfusion outcomes. We believe that outcomes reported from study entry are most useful because reporting in this way facilitates comparison across trials and also gives the best picture of the results of initiating treatment at different baseline Hb levels. Of the 22 trials included in this systematic review of evidence, only three studies reported transfusion outcomes from the 28^th^ day of epoetin treatment. Henry, Brooks, Case, et al. (1995) reported that the difference in percentage of patients transfused was significant over the 2^nd^ and 3^rd^ months of the trial (26 percent versus 56 percent, p<0.005), even though it was not significant over the entire 3-month duration of the trial. Case, Bukowski, Carey, et al. (1993) reported the percentage of patients transfused at month 1 and at months 2 and 3, but the difference between the epoetin and control arms was not significant for either time interval. To date, Littlewood, Bajetta, Cella, et al. (1999) have reported transfusion outcomes only after the 28^th^ day of epoetin administration; thus, it is not known whether the difference was significant over the entire length of the study.

In the adult trials of higher quality, the range of differences between epoetin and control arms for percentage of patients transfused was 9 percent to 45 percent; the lesser quality study by Oberhoff and colleagues (1998) fell within this range (15 percent). The range of differences for RBC units transfused per patient per 4 weeks was 0 to 0.7.

Two of the three pediatric trials reported that significantly fewer epoetin-treated patients were transfused than were controls (Leon, Jimenez, Barona, et al., 1998; Varan, Buyukpamukcu, Kutluk, et al., 1999). The third trial, by Porter, Leahy, Polise, et al. (1996), had an unusually high percentage of patients transfused in each arm, and there was no significant difference between arms in the percentage of patients transfused. The trials by Leon, Jiminez, Barone, et al. (1998) and Porter and colleagues (1996) each reported a significant reduction in RBC units transfused per patient; Varan, Buyukpamukcu, Kutluk, et al. (1999) did not report on this outcome. The range of differences between epoetin and control arms for percentage of patients transfused was 10 percent to 80 percent. The differences between arms for RBC units transfused per patient per 4 weeks were 1.1 and 2.2 units; note that 2.2 units, from the Porter study, is the difference in median (not mean) units transfused.

##### Baseline Hb >10 to <12 g/dL

Five of seven trials (n=335), including one of higher quality and two nonrandomized trials, reported the percentage of patients transfused. Three of these studies also reported RBC units transfused per patient.

ten Bokkel Huinink, de Swart, van Toorn, et al. (1998; n=120) observed a significant reduction in the percentage of patients transfused for the epoetin-treated study arm but did not report whether the difference in RBC units transfused per patient was significant. A second trial (n=29), the only one of higher quality, reported that epoetin significantly reduced the number of RBC units transfused per patient (Wurnig, Windhager, Schwameis, et al., 1996). However, the difference between arms in percentage of patients transfused was not significant.

Of the remaining three trials, two (n=110) found nonsignificant differences between arms in percentage of patients transfused (Markman, Reichman, Hakes, et al., 1993; Quirt, Couture, Pichette, et al., 1996). Quirt and colleagues (1996) also reported RBC units transfused per patient but did not report on significance. The third study (n=76) did not report whether the difference in percentage of patients transfused was significant (Dusenbery, McGuire, Holt, et al., 1994).

Among these trials, the range of differences between epoetin and control arms for percentage of patients transfused was 7 percent to 47 percent. The differences for RBC units transfused per patient per 4 weeks were 0.1 and 1.3 units.

##### Baseline Hb >12 g/dL

Three (n=222) of five studies reported transfusion outcomes.^5^ The trial by Thatcher, De Campos, Bell, et al. (1999) reported significantly fewer patients transfused in the epoetin-treated arm than in controls; the other two trials found no significant differences. The number of RBC units per patient was also significantly lower for the epoetin arm in the Thatcher trial, but differences were not significant in the trial by Welch, James, Wilkinson, et al. (1995). Among these trials, the range of differences between epoetin and control arms for percentage of patients transfused was 7 percent to 39 percent. The difference for RBC units transfused per patient per 4 weeks was 0.3 units and 0.6 units in the lower and higher dose epoetin arms of the Thatcher trial.

5 Recently, a sixth study (n=27 evaluable) with baseline Hb >12 g/dL was published (Dunphy, Harrison, Dunleavy, et al., 1999). Mean baseline Hb levels were 14.1g/dL for each arm. The percentage of patients transfused was 36 percent for controls and 15 percent for epoetin-treated patients (p=0.38 by Fisher's exact test). The number of RBC units transfused per patient over four cycles of chemotherapy (12 weeks) was 1.0 units for controls and 0.46 units in the epoetin arm. These data do not change any conclusions of this review.

The study by Thatcher and coworkers (1999) is noteworthy because patients in all three arms experienced the greatest decrease in Hb levels among all studies included in this systematic review of evidence. Most notably, this is the only study with baseline Hb >10 g/dL in which the epoetin arms approached Hb=10 g/dL during the course of the study. Patients in this study were undergoing platinum-based chemotherapy for small cell lung cancer, a population selected by the authors as being at high risk of transfusion. However, the authors also noted that the tendency of physicians in this unblinded trial to undertransfuse the patients in the arm with the higher epoetin dose may overestimate the magnitude of effect.

##### Summary

The most robust evidence that epoetin reduces transfusions for patients undergoing therapy for malignancy comes from trials in patient groups with baseline Hb <10 g/dL. Four trials in adults (n=682), including three of higher quality (n=493), reported that significantly fewer patients were transfused in the epoetin arms than in control arms. The three pediatric trials all reported a significant reduction in either percentage of patients transfused or RBC units transfused per patient or both.

Among trials of patients with baseline Hb >10 g/dL, two of eight reported that significantly fewer epoetin-treated patients were transfused, and a third reported a significant reduction in RBC units transfused per patient. The total number of patients in these studies is much smaller than in the Hb <10 g/dL group, individual trials are small in size, and the patients' risk of transfusion may be lower. It is likely that most of these trials lack adequate statistical power to detect a difference. However, of these 12 trials, only 1 was double blinded, and 3 were nonrandomized; these study designs may overestimate the magnitude of effect of epoetin treatment. Thus, bias inherent in the weaker design of these studies may somewhat offset inadequate power because of small sample size.

#### Relative Effects of the Hemoglobin Threshold for Initiating Treatment on Transfusion Outcomes

No trial directly compared the outcomes of initiating epoetin treatment at alternative Hb thresholds. Thus, only inferences based on indirect comparison are possible as to whether initiating epoetin at one or another Hb threshold results in superior outcomes. Transfusion outcomes do not appear to be superior in trials where epoetin treatment is initiated in groups of patients who have mean Hb >10 g/dL compared with trials where mean Hb is <10 g/dL.

Although it is possible that adequately powered comparative trials might demonstrate the superiority of earlier epoetin intervention, our examination of this evidence base suggests why that may not necessarily prove to be true. First, patients whose baseline Hb level is well below the mean may account for a substantial proportion of transfusions in epoetin-treated patients in trials where baseline Hb is <10 g/dL. Second, in all trials, patients who do not respond to epoetin may account for a substantial proportion of transfusions irrespective of the Hb level at which epoetin treatment is initiated. If these two patient groups account for a substantial proportion of epoetin-treated patients who are transfused, then the greatest yield for reducing the number of patients transfused might come from preventing the Hb level from falling well below 10 g/dL, rather than from setting an Hb threshold well above 10 g/dL for initiating epoetin treatment.

##### Indirect comparisons

The range of reduction reported in patients transfused and RBC units per patient does not appear to be greater in trials where epoetin treatment was initiated when mean Hb was >10 g/dL compared with trials where mean Hb at epoetin initiation was <10 g/dL. Among trials of adults where baseline Hb was <10 g/dL, the range of differences between epoetin and control arms for percentage of patients transfused was 9 percent to 45 percent. For baseline Hb >10 to <12 g/dL, the range was 7 percent to 47 percent; the range was 7 percent to 39 percent for baseline Hb >12 g/dL. For RBC units per patient per 4 weeks, the differences for the three groups of studies were 0 to 0.7, 0.1 and 1.3, and 0.3 and 0.6.

##### Distribution of baseline Hb in studies with mean <10 g/dL

Classification of studies by mean Hb at baseline might obscure clinically important variance around that mean within studies in each category. A particular concern is whether, in the group of studies for which baseline Hb was <10 g/dL, the classification might underestimate the benefit of epoetin to patients who had baseline Hb levels >10g/dL. The most useful evidence to address this concern would be data on the likelihood of transfusion as a function of baseline Hb for patients in each study. However no study reported such data; the best available data are from trials that reported SD in addition to mean Hb at study entry.

These trials are summarized in Table 17. Of the eight trials in this evidence base that reported SD in addition to mean Hb at study entry, there are six trials in adults and two trials in pediatric patients. Of the trials in adults, four are in the baseline Hb <10 g/dL category, and there is one each of the higher baseline Hb classifications. Five of the trials in adults are of higher quality. All trials in pediatric patients had baseline Hb <10 g/dL.

Table 17. Transfusion rates of epoetin-treated patients and variance in baseline hemoglobin^1^

Study (N evaluable, epoetin arm) | Hb Cutoff for Eligibility (g/dL) | Mean Hb (g/dL) at Study Entry (± SD) | Transf. Trigger or Mean Hb at Transf. (g/dL) | Mean Hb at Entry−1 SD (g/dL) | Mean Hb at Entry +1 SD (g/dL) | Final Hb Level (g/dL, ±SD) | % Transfused | Δ % Transfused (control-Epo)
Baseline Hb >10 g/dL; Adult Patients
Cascinu, Fedeli, Del Ferro, et al., 1994 (50) | >11.0 before, <9.0 during chemotherapy | 8.6 ± 0.62 | <8.0 | 7.98 | 9.22 | 10.5 ± 0.9 | 20% | 38%
Henry, Brooks, Case, et al., 1995 (64) | <10.67 | 9.8 ± 1.3 | 8.2 | 8.5 | 11.1 | 11.8 ± 2.3 | 53.1% (mo 1-3) 26.8% (mo 2-3) | 15.8% (mo 1-3) 29.6% (mo 2-3)
Kurz, Marth, Windbichler, et al., 1997 (23) | <11.0 | 9.88 ± 0.8 | <8.0 (or clinical symptoms) | 9.08 | 10.68 | 13.1 | 21.7% | 45%
Littlewood, Bajetta, Cella, et al., 1999 (244) | <10.5 or (Hb decrease >1.5 and Hb <12) | 9.9 ± 1.14 | NA (8.2 ± 0.91 before study entry) | 8.76 | 11.04 | 12.4 ± 0.6 | 23.0% (after day 28) | 12.7% (after day 28)
Baseline Hb <10 g/dL; Pediatric Patients
Varan, Buyukpamukcu, Kutluk, et al., 1999 (17) | <10.0 | 8.5 ± 0.85 | <6.0 | 7.65 | 9.35 | 10.21 ± 2.14 | 5.9% | 41.2%
Leon, Jimenez, Barona, et al., 1998 (25) | <10.5 | 9.8 ± 0.6 | <9.0 | 9.20 | 10.4 | 12.4 ± 1.7 | 16.0% | 80%
Baseline Hb >10 g/dL; Adult Patients
Wurnig, Windhager, Schwameis, et al., 1996 (15) | <11.0 | 11.0 ± 1.5 | <8.5 | 9.5 | 12.5 | ?? | 53.3% | 46.7%
Del Mastro, Venturini, Lionetto, et al., 1997 (31) | >12.0 | 13 ± 0.7 | <8.0 (or clinical symptoms) | 12.3 | 13.7 | 12.2 ± 1.2 | 0% | 6.5%

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

In two of the four adult studies with mean Hb at study entry <10 g/dL, patients had baseline Hb one SD or more below the mean border on the Hb level that triggers transfusion. Henry and colleagues (Henry, Brooks, Case, et al., 1995) reported that patients in their trial were transfused at a mean Hb of 8.2 g/dL, while 1 SD below the mean Hb at entry was 8.5 g/dL. In the trial by Cascinu and colleagues (1994), 1 SD below the mean Hb at entry was less than the transfusion trigger (7.98 vs. <8.0 g/dL). The largest difference between the transfusion trigger and 1 SD below the mean Hb at entry is <8.0 versus 9.08 g/dL in the study by Henry and coworkers (1995). Littlewood and colleagues (1999) only report mean Hb at transfusion for those given prior to study entry (8.2 +/− 0.91 g/dL); this can be compared with 1 SD below the mean Hb at entry of 8.76 g/dL. The percentage of epoetin-treated patients transfused in these studies ranged from 20 percent to 53 percent. This suggests, but does not demonstrate, that patients entering these trials with Hb levels well below the mean could largely or entirely account for transfusions in the epoetin-treated arm.

##### Nonresponders and transfusion

Table 18 compares the percentage of epoetin-treated patients who failed to achieve a hematologic response with the percentage of epoetin-treated patients transfused. Nine trials reported data on both outcomes. Definitions of hematologic response were consistent among these studies. Six of the nine trials defined response as an increase in Hb level >2 g/dL. Two studies defined response as achievement of Hb levels >10 g/dL without transfusion (Cascinu, Fedeli, Del Ferro, et al., 1994; Thatcher, De Campos, Bell, et al., 1999) and one gave no definition (Markman, Reichman, Hakes, et al., 1993).

Table 18. Comparison of nonresponse rates and transfusion rates of epoetin-treated patients^1^

Citation | Transf. Trigger or Mean Hb @ Transf. | Baseline Hb | N Enrolled | N Evaluable | Percent Not Responding | Percent Transfused | Difference (% not responding - % transfused)
Baseline Hb <10 g/dL
Oberhoff, Neri, Amadori, et al., 1998 | NA | 9.6 | 117 | 101 | 65.3 | 25.7 | 39.6
Case, Bukowski, Carey, et al., 1993 | 8.2 | 9.5 | 81 | 79 | 41.8 | 25.3 | 16.5
Henry, Brooks, Case, et al., 1995 | 8.2 | 9.8 | 67 | 64 | 51.6 | 53.1 | −1.5
Cascinu, Fedeli, Del Ferro, et al., 1994 | 8.0 | 8.6 | 50 | 50 | 18.0 | 20.0 | −2.0
Kurz, Marth, Windbichler, et al., 1997 | 8.0 | 9.88 | 23 | 23 | 43.5 | 21.7 | 21.8
Littlewood, Bajetta, Cella, et al., 1999 (Abstract/slides) | NA | 9.9 | 251 | 244 | 29.5 | 23.0 | 6.5
Leon, Jimenez, Barona, et al., 1998 (pediatric patients) | 6.0 | 9.8 | 25 | 25 | 28.0 | 16.0 | 12.0
Baseline Hb >10 g/dL
Markman, Reichman, Hakes, et al., 1993 | 8.0 | 11.5 | 17 | 16 | 12.5 | 6.3 | 6.2
Thatcher, De Campos, Bell, et al., 1999 (3-arm study) | 8.6 | 13.7 | 42 | 42 | 47.6 | 45.2 | 2.4
Thatcher, De Campos, Bell, et al., 1999 (3-arm study) | 8.0 | 13.6 | 44 | 44 | 38.6 | 20.5 | 18.1

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

The data displayed in Table 18 suggest, but do not demonstrate, that patients who are unresponsive to epoetin may account for a substantial proportion of epoetin-treated patients transfused irrespective of the Hb level at which epoetin treatment is initiated. Only two of the nine trials reported that the percentage of patients transfused was greater than the percentage of patients failing to achieve a hematologic response, and the differences are quite small (1.5 percent and 2 percent) (Cascinu, Fedeli, Del Ferro, et al., 1994; Henry, Brooks, Case, et al., 1995;). Seven of the nine trials reported that the percentage of nonresponding patients was greater than the percentage of patients transfused in the epoetin-treated arm; the range of the differences was 2.4 percent to 39.6 percent.

One limitation of this comparison is that seven of the nine trials that reported on both the outcomes of interest were studies of patients with baseline Hb <10 g/dL. It is possible that Hb levels were too low at study entry, or that the study duration was too short, to adequately demonstrate hematologic response to epoetin. If this were the case, the trials would overestimate the percentage of patients failing to achieve hematologic response. However, the two trials that reported that the percentage of epoetin-treated patients transfused was greater than the percentage of nonresponders also were among the baseline Hb <10 g/dL group of studies. Thus, we believe our point is germane despite the limitations of the available data.

##### Summary

While it is possible that adequately powered comparative trials might demonstrate the superiority of epoetin intervention at the higher Hb levels, our examination of this evidence base suggests why that may not prove to be true. First, patients whose baseline Hb is below the mean may account for a substantial proportion of transfusions in epoetin-treated patients in trials where baseline Hb is <10 g/dL. Thus the greatest yield for reducing the number of patients transfused in this population might come from initiating epoetin before the Hb level falls substantially below 10 g/dL, rather than by initiating epoetin treatment at a level substantially above 10 g/dL. Second, in all trials, patients who are unresponsive to epoetin may account for a substantial proportion of patients transfused. Initiating epoetin treatment at a higher Hb level is not expected to reduce transfusions in this subgroup of patients.

#### Meta-Analysis of Odds of Transfusion

##### Odds of transfusion

The effect of epoetin on the risk of RBC transfusion in patients with anemia resulting from cancer therapy was estimated using the meta-analysis methods described in Chapter 2, Methodology. To obtain the most accurate estimate of the odds of transfusion, we selected from the 22 studies included in this systematic review only randomized, controlled studies that reported numbers of patients transfused (n=1,439; Table 19).

Table 19. Studies selected for meta-analysis of the risk of transfusion^1^

Citation | Baseline Hb (Control/Treated) | Epoetin Weekly Dose (U/kg) | Odds Ratio ^2^
Studies of sc epoetin administration
Quirt, Couture, Pichette, et al., 1996 | 10.7/10.9 | 450 | 0.414
Oberhoff, Neri, Amadori, et al., 1998 | 10.3/9.6 | ~450 | 0.501
Kurz, Marth, Windbichler, et al., 1997^3^ | 9.8/9.9 | 450 | 0.139
Del Mastro, Venturini, Lionetto, et al., 1997 | 13.1/13 | 450 | 0.0
Thatcher, De Campos, Bell, et al., 1999 | 13.4/13.7/13.6 | 450/900 | 0.334
Case, Bukowski, Carey, et al., 1993^3^ | 9.8/9.5 | 450 | 0.664
Henry, Brooks, Case, et al., 1995^3^ | 9.5/9.8 | 450 | 0.513
Welch, James, Wilkinson, et al., 1995 | 12.8/13 | 900 | 0.319
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 8.5/8.5 | 450 | 0.073
Littlewood, Bajetta, Cella, et al., 1999^3^ | 9.7/9.9 | 450 | 0.538
Cascinu, Fedeli, Del Ferro, et al., 1994^3^ | 8.7/8.6 | 300 | 0.188
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 11.8/12/11.6 | 450/900 | 0.156
Studies of iv epoetin administration
Porter, Leahey, Polise, et al., 1996 ^4^ | 9.4/9.7 | 450 | 0.122
Wurnig, Windhager, Schwameis et al., 1996^4^ | 10.5/11 | 1200 | 0.011

1 "Higher quality" trials in bold font; randomized trials only.

2 Odds of transfusion for epoetin-treated patients relative to the odds of transfusion for control patients.

3 Met the criteria for higher quality studies (see Methodology, Assessing Study Quality, and following discussion).

4 Used intravenous epoetin delivery; all other studies used subcutaneous epoetin delivery.

The results from each study were summarized as ratios of the odds of transfusion for epoetin-treated patients relative to the odds of transfusion for control patients (Table 19). The study odds ratios were combined into a summary estimate using an empirical Bayesian random effects model. The combined odds ratio was 0.370 (95 percent CI, 0.273 to 0.502) in favor of epoetin treatment. The odds ratio is an expression of the relative likelihood that epoetin-treated patients will be transfused compared with the likelihood for control patients. Because most of the included randomized, controlled trials (12 of 14) used the subcutaneous route of delivery and only two randomized, controlled trials used intravenous delivery, data were insufficient to evaluate potential differences as a function of route. The meta-analysis was restricted to studies that delivered epoetin subcutaneously (n=1,390).

A test for homogeneity (DerSimonian and Laird, 1986) indicated that the studies are somewhat heterogeneous (chi-square of 17.306 for 11 degrees of freedom, p=0.0991). Meta-analysis using the same empirical Bayesian random effects model resulted in a combined odds ratio of 0.380 (95 percent CI, 0.282 to 0.513), indicating that the intravenous studies had little effect on the summary estimate, and the results are shown in Figure 1.

Figure 1. Effect of Epoetin on the Odds of Transfusion in Patients with Anemia due to Cancer Therapy

##### Sensitivity analysis by study quality

A sensitivity analysis was performed using only the studies that met our criteria for higher quality (see Chapter 2, Methodology). All five higher quality studies (Table 19; n=771) that administered epoetin subcutaneously and reported the number of patients transfused used a weekly epoetin dose between 300 and 450 U/kg. The estimate of epoetin effect on transfusion risk in studies using subcutaneous administration and a weekly epoetin dose of 300 to 450 U/kg (n=503) was calculated for higher quality studies and separately for the remaining studies. The results of this analysis are shown in Table 20 and Figure 2. Higher quality studies show a significantly smaller effect of epoetin on the risk of transfusion than do lower quality studies; 95 percent confidence intervals for the odds ratios do not overlap.

Table 20. Effect of study quality on the risk of transfusion: 450 Weekly Dose Category

Factor | Coefficient | Standard Error | Odds Ratio ^1^ | 95% Confidence Interval
Lower quality: 300-450 dose | −1.985 | 0.420 | 0.137 | 0.060, 0.313
Higher quality: 300-450 dose | −0.793 | 0.161 | 0.453 | 0.330, 0.621

1 Odds of transfusion for epoetin-treated patients relative to the odds of transfusion for control patients.

Figure 2. Effect of Study Quality on the Odds Ratio of Transfusion

##### Effects of baseline Hb

We also wished to determine if the effect of epoetin on the odds of transfusion depended on the patients' mean baseline Hb. However, evaluating the effect of baseline Hb on the odds ratio for transfusion could be confounded by differences in study quality. Analyzing the effect of baseline Hb level within higher quality studies was not possible because all higher quality studies that gave epoetin subcutaneously enrolled patient groups with mean baseline Hb <10 g/dL. Therefore, the evidence does not allow us to test for an effect of baseline Hb level on the odds of transfusion or to determine by meta-analysis whether there is greater benefit from initiating epoetin treatment at higher Hb levels.

##### Summary

Estimates of the odds of transfusion for epoetin-treated patients relative to the odds of transfusion for control patients for different groups of studies are summarized in Table 21. For all randomized trials that delivered epoetin subcutaneously, the odds of transfusion for epoetin-treated patients was reduced by a factor of 0.380 compared with patients supported with transfusion alone.

Table 21. Summary: Meta-Analysis of the effect of epoetin on transfusion

Analysis of: | Odds Ratio ^1^ | 95% Confidence Interval | Number Needed to Treat | 95% Confidence Interval
All randomized studies, subcutaneous epoetin delivery | 0.380 | 0.282, 0.513 | 4.4 | 3.6, 6.1
All randomized studies, subcutaneous epoetin delivery, higher quality (300-450 weekly dose) | 0.453 | 0.330, 0.621 | 5.2 | 3.8, 8.4
All randomized studies, subcutaneous epoetin delivery, lower quality (300-450 weekly dose) | 0.137 | 0.060, 0.313 | 2.6 | 2.1, 3.8

1 Odds of transfusion for epoetin-treated patients relative to the odds of transfusion for control patients.

The estimated magnitude of effect was smaller when we analyzed only the higher quality studies that used subcutaneous delivery. Since higher quality studies all delivered weekly epoetin doses of 300 to 450 U/kg, the estimated odds ratio was compared to those lower quality studies that used epoetin doses within the same range. The odds of transfusion for epoetin-treated patients was reduced by a factor of 0.453 for higher quality studies compared with a reduction by a factor of 0.137 for lower quality studies. Lack of double-blinding in the lesser quality trials could bias results toward a larger intervention effect.

To express the absolute effectiveness of epoetin, for each estimate, we also calculated the number of patients that would need to be treated to prevent one patient from being transfused (number needed to treat, NNT). The overall NNT calculated for this group of studies is 4.4 (95 percent CI, 3.6 to 6.1; Table 20).^6^ Therefore, four to five patients would need to receive epoetin for one patient to avoid transfusion. For higher quality studies, the calculated NNT is 5.2 (95 percent CI, 3.8-8.4); and for lower quality studies, the calculated NNT is 2.6 (95 percent CI, 2.1-3.8). Thus, the higher quality studies predict one patient would avoid transfusion for every five to six patients treated with epoetin, whereas the lesser quality studies predict one for every two to three treated.

6 The odds of transfusion for the combined control study arms (from those studies with a known followup duration) was estimated using a logistic normal model and the point estimate for a 12-week followup duration (Hasselblad, 1998). For the NNT for all randomized studies that delivered epoetin subcutaneously, the estimate was 0.99, corresponding to a probability of 0.498 (odds=probability of transfusion/(1-probability of transfusion)). From this and the summary odds ratio, the odds of transfusion for the combined epoetin-treated study arms was calculated as 0.380*0.99 or 0.376, corresponding to a probability of 0.273. NNT is equal to the reciprocal of the absolute risk reduction (Laupacis, Sackett, Roberts, 1988) or 1/(0.498 to 0.273)=4.44. The 95 percent confidence limits are 1/(0.498 to 0.216) = 3.55 to 1/(0.498 to 0.335) = 6.13.

The effect of baseline Hb level may also be confounded by study quality, and there is insufficient evidence to separately determine whether or not there is greater benefit from epoetin therapy depending on the Hb level at the time epoetin treatment is initiated.

#### Quality of Life

Nine trials reported on quality of life. Table 22 summarizes the seven studies (three of four higher quality studies) that compared differences in pre- and posttreatment quality-of-life scores between treatment and control study arms. In addition, two studies (Case, Bukowski, Carey, et al, 1993; Thatcher, De Campos, Bell, et al., 1999) only compared pre- and posttreatment results within each study arm, so that the results of epoetin versus no epoetin treatment are not directly compared. One study (Henry, Brooks, Case, et al., 1995) reported both within and between arm comparisons. Table 23 summarizes the three studies that compare pre- and posttreatment results within study arms.

Table 22. Quality of life outcomes for studies grouped by baseline Hb levels: Comparisons between control and epoetin-treated study arms

Study | Treatment Arm | N Evaluable for Transfusion | N Evaluable for Quality of Life | % Change: Overall QoL | p Value: Overall QoL | % Change: Energy Level | p Value: Energy Level | % Change: Daily Activities | p Value: Daily Activities | Other QoL Measure ^2^ | % Change: Other QoL | p Value: Other QoL
Mean/Median Baseline Hb < 10g dL
Kurz, Marth, Windbichler, et al., 1997 | Control | 12 | 12 | | | | | −14.5 | | Well-being | 4.0
Kurz, Marth, Windbichler, et al., 1997 | Epoetin | 23 | 23 | | | | | −6.5 | NS | Well-being | −0.1 | NS
Kurz, Marth, Windbichler, et al., 1997 | Control | 12 | 12 | | | | | | | Physical ability | 8.0
Kurz, Marth, Windbichler, et al., 1997 | Epoetin | 23 | 23 | | | | | | | Physical ability | 8.3 | NS
Kurz, Marth, Windbichler, et al., 1997 | Control | 12 | 12 | | | | | | | Social activities | 12.8
Kurz, Marth, Windbichler, et al., 1997 | Epoetin | 23 | 23 | | | | | | | Social activities | 1.0 | NS
Henry, Brooks, Case, et al., 1995 | Control | 61 | 40 | 0.2 | | 6.2 | | 0.7
Henry, Brooks, Case, et al., 1995 | Epoetin | 64 | 46 | 11.0 | 0.013 | 8.8 | NS | 8.2 | NS
Littlewood, Bajetta, Cella, et al., 1999 | Control | 115 | 108 | NA | | −5.8 | | −6.0
Littlewood, Bajetta, Cella, et al., 1999 | Epoetin | 244 | 227 | NA | <0.01 | 7.8 | <0.001 | 7.3 | <0.01
Littlewood, Bajetta, Cella, et al., 1999 | Control | 115 | 90 | | | | | | | Fact-An: Anemia | −9.4
Littlewood, Bajetta, Cella, et al., 1999 | Epoetin | 244 | 200 | | | | | | | Fact-An: Anemia | 14.4 | <0.01
Littlewood, Bajetta, Cella, et al., 1999 | Control | 115 | 90 | | | | | | | Fact-An: Fatigue | −4.2
Littlewood, Bajetta, Cella, et al., 1999 | Epoetin | 244 | 200 | | | | | | | Fact-An: Fatigue | 5.7 | <0.01
Littlewood, Bajetta, Cella, et al., 1999 | Control | 115 | ? | | | | | | | SF-36 | NA
Littlewood, Bajetta, Cella, et al., 1999 | Epoetin | 244 | ? | | | | | | | SF-36 | NA | NS
Leon, Jimenez, Barona, et al., 1998 | Control | 25 | 25 | | | | | | | Karnovsky PS | 1.4
Leon, Jimenez, Barona, et al., 1998 | Epoetin | 25 | 25 | | | | | | | Karnovsky PS | 8.6 | <0.05
Mean/Median Baseline Hb >12 g/dL
Sweeney, Nicolae, Ignacio, et al., 1998 | Control | 24 | 24 | 6.3
Sweeney, Nicolae, Ignacio, et al., 1998 | Epoetin | 22 | 22 | 19.1 | 0.15, NS
Welch, James, Wilkinson, et al., 1995 | Control | 15 | ?15 | NA | | NA | | NA
Welch, James, Wilkinson, et al., 1995 | Epoetin | 15 | ?15 | NA | NS | NA | NS | NA | NS
Del Mastro, Venturini, Lionetto, et al., 1997 | Control | 31 | 26 | | | | | | | PDI score | 2.3
Del Mastro, Venturini, Lionetto, et al., 1997 | Epoetin | 31 | 27 | | | | | | | PDI score | 6.0 | NS

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 In order to accommodate several "Other" QoL instruments or different statistical testing results, study control and treatment arms may be listed more than once.

Table 23. Quality of life outcomes for studies grouped by baseline Hb levels: Within-arm comparisons ofbaseline to final values^1^

Study | Treatment Arm | N Evaluable for Transfusion | N Evaluable for Quality of Life | % Change: Overall QoL | p Value: Overall QoL | % Change: Energy Level | p Value: Energy Level | % Change: Daily Activities | p Value: Daily Activities
Mean/Median Baseline Hb < 10g dL
Case, Bukowski, Carey, et al., 1993 | Control | 74 | 61 | −1.0 | NS | 3.0 | NS | 1.6 | NS
Case, Bukowski, Carey, et al., 1993 | Epoetin | 79 | 63 | 5.6 | 0.09, NS | 10.0 | <0.05 | 8.0 | <0.05
Henry, Brooks, Case, et al., 1995 | Control | 61 | 40 | 0.2 | NS | 6.2 | < 0.05 | 0.7 | NS
Henry, Brooks, Case, et al., 1995 | Epoetin | 64 | 46 | 11.0 | < 0.05 | 8.8 | < 0.05 | 8.2 | < 0.05
Mean/Median Baseline Hb >12 g/dL
Thatcher, De Campos, Bell, et al., 1999 | Control | 44 | 27 | 7.5 | NS | 1.6 | NS | 10.8 | NS
Thatcher, De Campos, Bell, et al., 1999 | Epoetin | 42 | 33 | 11.7 | <0.05 | −2.3 | NS | 3.0 | NS
Thatcher, De Campos, Bell, et al., 1999 | Epoetin | 44 | 32 | 6.0 | NS | 3.2 | NS | 4.9 | NS

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

No published studies reported on features known to be important in minimizing bias in assessment of quality-of-life outcomes, including: procedures to minimize the impact of other factors on responses to quality-of-life instruments, handling of missing data in the analysis, and prospectively defining the minimum differences in quality of life scores to be considered clinically significant.

LASA scales are the most frequently used quality-of-life instruments, reported in seven trials. The trial by Littlewood, Bajetta, Cella, et al. (1999) used the FACT-An instrument in addition to LASA scales. Of the two trials that did not use LASA scales, one used Karnovsky performance scales (Leon, Jimenez, Barona, et al., 1998) and one used the Psychological Distress Inventory (Del Mastro, Venturini, Lionetto, et al., 1999). The LASA scale results most frequently reported in these studies are: overall quality of life;, energy level, and daily activities. Kurz, Marth, Windbichler, et al. (1997) used a 10-question LASA scale, which included a question on daily activities. Three other LASA results, considered most important by the authors, were also reported for this study in Table 22. Because the LASA scales are unidimensional instruments, the results of various scales cannot be combined; thus the overall quality-of-life score is not a summary score and is only one of three or more separate dimensions.

Five of the nine studies (n=630 patients evaluable for quality-of-life outcomes) enrolled patient groups with a mean or median Hb level <10 g/dL at baseline; four studies (n=221) enrolled patient groups with a mean or median Hb level >12 g/dL at baseline. There were no studies reporting quality-of-life outcomes that enrolled patient groups with mean or median baseline Hb levels >10 and <12 g/dL.

##### Baseline Hb >12 g/dL

The three studies that compared the epoetin-treated and control arms with respect to change in quality of life from baseline to final evaluation found no significant differences. Neither Sweeney, Nicolae, Ignacio, et al. and coworkers (1998) nor Welch, James, Wilkinson, et al. (1995) detected significant differences between arms in the magnitude of change in overall quality of life measured on a visual analog scale. Nor were changes in energy level or daily activities significant in the Welch and colleagues (1995) study. Del Mastro, Venturini, Lionetto, et al. (1997) found no significant differences using the Psychological Distress Index.

Thatcher, De Campos, Bell, et al. (1999) used visual analog scales to evaluate the changes between baseline and final evaluation within study arms but did not compare changes between study arms. The only significant difference reported was for overall quality of life in the study arm treated with epoetin at 450 U/kg per week; however, the change in the epoetin arm treated at 900 U/kg per week was not significant. Changes from baseline within each study arm were not significant for energy level and daily activities. By visual inspection of results, it appears unlikely that there are significant differences for any quality-of-life measures between control and treatment arms.

The four studies that reported on quality-of-life outcomes in patient groups with an average baseline Hb of >12 were relatively small, mainly used visual analog scales to assess quality of life, and reported no significant differences in quality-of-life change between control and epoetin-treated study arms. Thus, for studies of patient populations with baseline Hb >12, no conclusions can be drawn with respect to the effect of epoetin treatment on quality of life.

##### Baseline Hb <10 g/dL

Four of five studies in this group that reported quality-of-life outcomes were considered higher quality studies according to criteria described in Chapter 2, Methodology. However, of the four higher quality studies, three reported fewer evaluable patients for quality-of-life outcomes than for hematologic or transfusion outcomes (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Littlewood, Bajetta, Cella, et al., 1999). Ten to 40 percent of enrolled patients were not evaluable for quality of life; therefore, these studies would fail our study quality criterion of <10 percent nonevaluable patients per study arm. Particularly with quality-of-life outcomes, missing data may not be distributed randomly and may be related to the quality-of-life outcome. For example, patients who are most severely ill or who have the worst quality of life may be most likely to have missing quality-of-life data, potentially biasing the analysis of study results.

One of these studies, which enrolled 375 patients with a variety of hematologic and solid tumors who were receiving nonplatinum-based chemotherapy, is the largest study included in this systematic review and is likely to offer the most robust data on quality of life (Littlewood, Bajetta, Cella, et al., 1999). However, as of this writing, the Littlewood study is unpublished and information is available only in an abstract and in copies of a slide presentation from the May 1999 ASCO meeting (generously supplied by the authors).

Littlewood and coworkers (1999) report consistent and statistically significant differences between study arms, favoring the epoetin-treated arm, on each of several instruments, including the visual analog scales on overall quality of life, energy level, and daily activity employed in other studies. In addition, the overall FACT-An scale and FACT-F subscale, which specifically target issues related to anemia and cancer, showed significant differences between study arms. The SF-36 scale, a widely used tool for functional health status, however, did not reveal significant differences between study arms according to the study abstract.

As of this writing, a complete report of the Littlewood trial is not available, so a meaningful interpretation of the results is not possible. Although quality-of-life data using the LASA instrument are missing for relatively few patients (10 percent of the epoetin arm and 13 percent of controls), data are missing for twice as many patients for the FACT-An instrument (20 percent of the epoetin arm and 27 percent of control). No sensitivity analysis or discussion of the implications of the missing data is available. Nor is the complete study protocol available to allow evaluation of the methods used to minimize bias in the collection of quality-of-life data. Interpretation of the clinical significance of changes in quality-of-life scores in the various instruments in this trial also awaits study publication. For example, the information to calculate effect sizes is not given in the published meeting abstract or presentation slides. Further analysis of the FACT-An results in relation to the SF-36 results would also be useful.

Henry, Brooks, Case, et al. (1995), reporting on a subset of patients with a variety of hematologic and solid tumors receiving platinum-based chemotherapy, compared study arms using responses to three questions on independent 100-point visual analog scales. In this study, quality-of-life data were missing for 43 percent and 40 percent of patients in the epoetin-treated and control arms, respectively. Possible bias as a result of missing data was not explored in the publication. From the available data, the control and epoetin-treated arms differed significantly in the magnitude of change for response scores only for the question on overall quality of life but not for the questions on energy level or daily activity. Interestingly, for the questions on overall quality of life and daily activities, baseline and final value within a study arm differed significantly for the epoetin-treated arm but not for the control arm. Thus, significance for comparison between study arms cannot be inferred from within-arm comparisons.

Case, Bukowski, Carey, et al. (1993) reported on the same study for those patients receiving nonplatinum-based chemotherapy, but compared only baseline and final evaluations within study arms and did not compare changes between study arms. Of enrolled patients, data were missing for 22 percent and 20 percent of epoetin-treated and control patients, respectively. The study publication did not include an evaluation of the possibility that nonrandom distribution of the missing data might bias the analysis of results on quality-of-life outcomes. For the available data, the epoetin-treated arm showed a significant difference in baseline to final value for questions on energy level and daily activities. None of the changes in the control arm was statistically significant.

Kurz, Marth, Windbichler, et al. (1997) compared the change from baseline to final quality-of-life evaluation between study arms using patient responses to a five-point visual analog scale for several different questions; those considered most important by the authors are reported in Table 22. All enrolled patients were evaluated; none of the differences was significant. The last study (Leon, Jimenez, Barona, et al., 1998), a nonrandomized trial of 50 pediatric patients, reported only Karnovsky performance scores comparing changes between baseline and final evaluations across study arms for all enrolled patients and found a significant difference.

##### Summary

The strongest evidence to date on quality-of-life outcomes with epoetin treatment is an unpublished study by Littlewood, Bajetta, Cella, et al (1999), which enrolled patient populations with baseline Hb levels <10 g/dL. This large, randomized controlled trial compared the change in quality-of-life scores between control and epoetin-treated study arms from visual analog scales and from the FACT-An and found positive, significant differences. Results from the SF-36 were in the same direction but not significant. Interpretation of the clinical significance of these findings awaits publication of a complete report. As of this writing, information is not available assessing the key features for evaluation of a quality-of-life study, including adequacy of methods used to minimize bias in the collection of quality-of-life data, the impact of missing quality-of-life data, and the clinical significance of the reported changes in quality-of-life scores.

Of the three other published studies in patient populations with baseline Hb levels <10 g/dL, only Henry, Brooks, Case, et al. (1995) reported a significant between-arm difference favoring epoetin. This study reported significantly improved results on overall quality-of-life visual analog scale but not on energy level or daily activities scales.

Studies enrolling patient populations with average baseline Hb levels >12 are small and unblinded and do not present consistent evidence of improved quality-of-life scores. There were no studies reporting quality-of-life outcomes that enrolled patient groups with mean or median Hb levels >10 and <12 g/dL at baseline.

### Key Question 1 Conclusions

What are the outcomes of managing anemia with epoetin compared with transfusion alone?

We found adequate and consistent evidence that epoetin increases Hb levels and the percentage of patients achieving a hematologic response when compared with controls managed by transfusion alone. This was true for pediatric patients as well as adults. For all trials, the range of differences between epoetin and control arms for percent of patients responding was 18 percent to 80 percent. The range of differences for mean Hb change was 0.1 to 3.7 g/dL.

Based on data from the 12 randomized studies that administered epoetin subcutaneously, the odds of transfusion for epoetin-treated patients is reduced by a factor of 0.380 relative to the odds of transfusion for control patients. The calculated NNT to prevent one patient from being transfused for all studies is 4.4 (95 percent CI, 3.6 to 6.1), which suggests four to five patients must be treated to prevent one patient from being transfused. The estimated magnitude of effect is smaller when the analysis is limited to only higher quality studies. The odds of transfusion for epoetin-treated patients is reduced by a factor of 0.453 for higher quality studies compared with reduction by a factor of 0.137 for lower quality studies. For higher quality studies, the calculated NNT is 5.2 (95 percent CI, 3.8 to 8.4), or five to six patients treated for each who avoids transfusion. For lower quality studies, the calculated NNT is 2.6 (95 percent CI, 2.1 to 3.8), or two to three patients treated for each who avoids transfusion.

The strongest evidence to date for an effect of epoetin on quality-of-life outcomes is from an unpublished randomized double-blinded trial by Littlewood, Bajetta, Cella, et al. (1999) in a patient population with mean baseline Hb level <10 g/dL. There were statistically significant differences in score changes on visual analog scales (n=335 evaluable) for three questions and on the FACT-An (n=290 evaluable) that favored the epoetin-treated arm. Results from the SF-36 were not significant. As of this writing, no information is available to assess the study protocol for methods used to minimize bias in the collection of quality-of-life data, the impact of missing quality-of-life data, or the clinical significance of the reported changes in quality-of-life scores. Eight other published studies, which included a total of 516 patients evaluable for quality-of-life outcomes, do not provide consistent evidence that epoetin improves quality-of-life outcomes.

What are the relative effects of epoetin treatment when different Hb thresholds are used to initiate treatment?

No trial directly compared the outcomes of initiating epoetin treatment at alternative Hb thresholds. Only inferences based on indirect comparison are possible as to whether initiating epoetin at one or another Hb threshold results in superior outcomes. The most robust evidence that epoetin improves transfusion outcomes for patients undergoing therapy for malignancy compared with transfusion alone comes from trials in patient groups with baseline Hb <10 g/dL. Four trials in adults (n=682), including three of higher quality (n=493), reported significantly fewer patients transfused in the epoetin arms than in control arms.

Transfusion outcomes do not appear to be superior in trials where epoetin treatment is initiated in groups of patients with mean Hb >10 g/dL compared with the outcomes in trials where mean Hb is <10 g/dL. Among trials on adults with mean baseline Hb <10 g/dL, the range of differences in the percentage of patients transfused between epoetin and control arms was 9 percent to 45 percent. For mean baseline Hb >10 but <12 g/dL, the range was 7 percent to 47 percent; and for baseline Hb >12 g/dL, 7 percent to 39 percent. For RBC units per patient per 4 weeks, the differences for the three groups of studies were 0 to 0.7, 0.1 and 1.3, and 0.3 and 0.6. Because of insufficient data, we were unable to determine by meta-analysis whether or not initiating epoetin therapy at higher baseline Hb levels reduces the odds of transfusion.

Although it is possible that adequately powered comparative trials might demonstrate the superiority of epoetin intervention at the higher Hb levels, our examination of this evidence base suggests why that may not prove to be true. First, patients whose entry level Hb is well below the mean may account for a substantial proportion of transfusions in epoetin-treated patients in trials where baseline Hb is <10 g/dL. Thus the greatest yield for reducing the number of patients transfused in this population might come from initiating epoetin before the Hb level falls substantially below 10, rather than by initiating epoetin treatment at a level substantially above 10. Second, in all trials, patients who are unresponsive to epoetin may account for a substantial proportion of transfusions irrespective of the Hb level at which epoetin treatment is initiated. Initiating epoetin treatment at a higher Hb level is not expected to reduce transfusions in this subgroup of patients.

In conclusion, the available evidence is not adequate to determine whether outcomes of epoetin treatment are superior when treatment is initiated in groups of patients who have mean Hb> 10 g/dL compared with treatment in patient groups where mean Hb is <10 g/dL. Randomized controlled trials, double blinded and adequately powered, are needed to answer this question. Inferences from indirect comparison of the results of the available trials do not provide compelling evidence to resolve this issue.

#### Characteristics of Epoetin Administration on Outcomes

The characteristics of epoetin administration of interest to this analysis are dose, dosing regimen, and duration of treatment. The evidence base for this systematic review did not have adequate comparative studies to assess whether any dosage, dosing regimen, or treatment duration used was superior to another. Thus, the main focus of this section is to determine whether these characteristics of epoetin administration might confound the results of our meta-analysis on the effect of epoetin on the odds of transfusion. A second concern is whether these characteristics of epoetin administration might confound our interpretation of the evidence on the relative effects of epoetin treatment when treatment is initiated at different Hb thresholds.

The meta-analysis conducted on the effect of epoetin on transfusion outcomes also examined whether the characteristics of epoetin administration (dosing regimen, treatment duration, and dose range) have an effect on the estimate of the point estimate for the odds ratio for transfusion. Only epoetin dose appeared to have an independent effect on transfusion outcomes. However, this relationship potentially is confounded by study quality. Moreover, the two trials that directly compared lower and higher doses of epoetin do not provide strong support for the hypothesis that starting doses in the higher range are more effective in preventing transfusions.

##### Meta-Analysis Findings

The meta-analysis compares the ratio of the odds of transfusion for the epoetin-treated and control arms of each study and is therefore independent of followup duration. However, the components of epoetin treatment (dose, route of delivery, dosing regimen, duration of treatment) are not constant across studies and could confound the summary estimate of effect. Dose and route of delivery are related, since the intravenous and subcutaneous routes are likely to deliver different absolute doses, even when the administered doses are the same. Because most of the included RCTs used the subcutaneous route of delivery (12 of 14) and only 2 intravenous delivery RCTs were available to determine the effect, further analysis was restricted to studies that delivered epoetin subcutaneously (n=1,390).

We examined the effects of the single categorical variables dosing regimen, treatment duration, and dose range on the estimate of the summary odds ratio for transfusion. Results are summarized in Table 24.

Table 24. Effect of duration of epoetin treatment, dosing regimen, and dose category on the risk of transfusion

Factor | Odds Ratio ^1^ | 95% Confidence Interval
Analysis by duration of treatment
Duration of <10 weeks | 0.291 | 0.144, 0.587
Duration of 12-16 weeks | 0.488 | 0.309, 0.769
Duration of >20 weeks | 0.365 | 0.229, 0.580
Analysis by epoetin dosing regimen
Fixed dose | 0.423 | 0.227, 0.789
Decreasing dose | 0.343 | 0.222, 0.529
Increasing dose | 0.461 | 0.292, 0.728
Analysis by epoetin weekly dose category
Dose of 300-450 U/kg | 0.413 | 0.304, 0.561
Dose of 700-1000 U/kg | 0.178 | 0.069, 0.459

1 Odds of transfusion for epoetin-treated patients relative to the odds of transfusion for control patients.

Duration of treatment was grouped into three categories: <10 weeks, 12 to 16 weeks, and >20 weeks. The estimated odds ratios for the likelihood of transfusion at each treatment duration are somewhat different. However, 95 percent confidence intervals for the odds ratios are widely overlapping, and therefore the differences are not significant. Thus, it seems unlikely that duration of treatment has a significant effect on number of patients transfused.

Dosing regimen was grouped into three categories: fixed dose, decreasing dose, and increasing dose. The odds ratios for the likelihood of transfusion for different dosing regimens are similar, and 95 percent confidence intervals are again overlapping, indicating no effect of this parameter on the summary estimate.

Epoetin weekly dose was grouped into two categories: 300 to 450 U/kg and 700 to 1,000 U/kg. The odds ratios for the likelihood of transfusion are significantly different, with confidence intervals that do not overlap. Thus, dose is the only component of epoetin intervention that requires further consideration as a potential confounder. Although it appears that increasing the dose of epoetin decreases the likelihood of transfusion, further analysis casts doubt on this interpretation.

Analysis of the effect of study quality within a single dose range of 300 to 450 U/kg per week indicated a significant effect of study quality (see Figure 2). However, it is not possible to additionally evaluate the effect of dose within higher quality studies, since only one higher quality study administered a dose within the 700 to 1,000 U/kg weekly dose category, and this study used an intravenous route of delivery (Wurnig, Windhager, Schwameis, et al., 1996). Therefore, the available evidence cannot distinguish between the effect of study quality and epoetin dose, and it is possible that higher epoetin doses have no greater effect than do lower epoetin doses.

#### Direct Comparisons of Dose

As shown in Table 25, two three-arm studies (n=250) directly compared patients administered subcutaneous epoetin at either 450 U/kg per week (n=87) or 900 U/kg per week (n=86) with controls managed by transfusion (n=77) (ten Bokkel Huinink, de Swart, van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999). In each study, only the epoetin dosage differed between arms. Both used a decreasing dose regimen and treatment duration of >20 weeks. Mean baseline Hb was >10 but <12 g/dL in the ten Bokkel study, whereas mean baseline Hb in the Thatcher study was >12 g/dL. The results of these trials do not demonstrate better outcomes from the higher dose.

Table 25. Direct comparison of epoetin doses in three-arm studies, subcutaneous administration

Citation | Dose (U/kg per week) | Epo Regimen Class | Epo Tx Duration | N Enrolled | N Evaluable | % Response | p Value | Hb Change ±S.D. | p Value | % Transfused | p Value | RBC Units per Patient | p Value | RBC Units per Patient per 4 Weeks
Thatcher, De Campos, Bell, et al., 1999 | 0 | 2 | 3 | 44 | 44 | 34.1 | | −3.4 | | 59.1 | | 6.1 | | 0.9
Thatcher, De Campos, Bell, et al., 1999 | 450 sc | 2 | 3 | 42 | 42 | 52.4 | <0.05 | −3.2 | | 45.2 | <0.05 | 3.8 | <0.01 | 0.6
Thatcher, De Campos, Bell, et al., 1999 | 900 sc | 2 | 3 | 44 | 44 | 61.4 | 0.005 | −3.3 | | 20.5 | <0.001 | 2.1 | <0.001 | 0.3
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 0 | 2 | 3 | 34 | 33 | | | | | 39.4 | | 1.2 | | 0.2
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 450 sc | 2 | 3 | 46 | 45 | | | | | 4.4 | ^1^ | 0.3 | | 0.1
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 900 sc | 2 | 3 | 42 | 42 | | | | | 14.3 | | 0.4 | | 0.1

1 Calculated odds ratio for transfusion suggests a significant difference, as upper limit of 95 percent confidence interval is <1.0 (see Meta-Analysis).

Thatcher and colleagues (1999) reported a significant difference between the two epoetin doses with respect to the percentage of patients transfused and the number of units transfused per patient (Thatcher, De Campos, Bell, et al., 1999). There appeared to be no significant difference between the epoetin dosages with respect to percentage of patients responding or the magnitude of change in Hb level. However, in this unblinded study, the participating centers varied in the mean Hb at which they initiated transfusion. Of particular concern, the range was markedly lower for the higher dose group than the lower dose group (8.7 to 10.8 g/dL versus 8.4 to 12.9 g/dL). Mean Hb for the 7 days prior to transfusion was also lower for the higher dose than for either the lower dose or control arms (8.0 g/dL versus 8.6 and 8.5 g/dL, respectively). The authors note that the higher dose group may have been somewhat undertransfused, possibly exaggerating the effect of the 900 compared with the 450 units/kg per week dose.

In contrast, the trial by ten Bokkel Huinink, de Swart, van Toorn, et al (1998) found no significant difference in percentage of patients transfused and number of RBC units transfused per patient. This unblinded study, which had a transfusion trigger of <9.7 g/dL, reported that the average Hb level at which transfusion actually was initiated was lower and consistent for all three arms (6.8 g/dL). The percentage of patients transfused was slightly higher in the 900 than in the 450 units/kg per week arm (14.3 percent vs. 4.4 percent, respectively), demonstrating no advantage for the higher dose arm. In this decreasing dose regimen, by the third cycle of chemotherapy the median dose of epoetin was reduced by approximately 50 percent in the higher dose arm (900 U/kg to 447 U/kg), compared with about 4 percent in the lower dose arm (450 U/kg to 432 U/kg). However, no hematologic outcomes were reported. The study authors concluded that the higher starting dose was not more effective than the lower starting dose.

#### Dosage and Dosing Regimen in Two-Arm Studies

Tables 26 and 27 summarize data from patients in 17 two-arm trials of subcutaneously administered epoetin compared with data from a control group managed without epoetin; Table 26 reports on hematologic outcomes, and Table 27 reports on transfusion outcomes. Twelve trials (n=1,253) used epoetin doses from 300 to 450 U/kg per week and five trials (n=242) used doses from 750 to 1,000 units/kg per week. Of 1,134 patients enrolled in studies with baseline Hb <10 g/dL, the patient group for which the most robust evidence of transfusion prevention exists, all but 50 were treated with epoetin doses in the 300 to 450 U/kg per week range. This body of evidence clearly demonstrates that doses in the 300 to 450 U/kg per week range are adequate to increase Hb and reduce percentage of patients transfused.

Table 26. Hematologic outcomes by weekly dose, two-arm studies of subcutaneous epoetin^1^

Citation | Initial EPO Dose (U/kg per week) | EPO Regimen Class ^2^ | EPO Tx Duration ^3^ | N Enrolled | N Evaluable | % Response | p Value | Difference in % Response (Epo-control) | Hb Change ±SD | p Value | Difference in Hb Change (Epo-control)
Weekly doses from 300 to 450 U/kg (lower doses)
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 0 | 1 | 1 | 17 | 17 | | | | −0.07
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 450 | 1 | 1 | 17 | 17 | | | | 1.71 | | 1.78
Gamucci, Thorel, Frasca, et al., 1993 | 0 | 1 | 2 | 17 | 17 | | | | −1.5±1.67
Gamucci, Thorel, Frasca, et al., 1993 | 450 | 1 | 2 | 21 | 21 | | | | 0.9±1.32 | <0.005 | 2.40
Oberhoff, Neri, Amadori, et al., 1998 | 0 | 1 | 2 | 110 | 88 | 6.8
Oberhoff, Neri, Amadori, et al., 1998 | ~450 | 1 | 2 | 117 | 101 | 34.7 | 0.0001 | 27.9
Markman, Reichman, Hakes, et al., 1993 | 0 | 1 | 3 | 46 | 40 | 40.0
Markman, Reichman, Hakes, et al., 1993 | 350 | 1 | 3 | 17 | 16 | 87.5 | <0.005 | 47.5
Cascinu, Fedeli, Del Ferro, et al., 1994 | 0 | 2 | 1 | 50 | 49 | 2.0 | | | −0.6
Cascinu, Fedeli, Del Ferro, et al., 1994 | 300 | 2 | 1 | 50 | 50 | 82.0 | | 80.0 | 1.9 | | 2.50
Del Mastro, Venturini, Lionetto, et al., 1997 | 0 | 2 | 2 | 31 | 31 | | | | −3.1±1
Del Mastro, Venturini, Lionetto, et al., 1997 | 450 | 2 | 2 | 31 | 31 | | | | −0.8±1.4 | <0.005 | 2.30
Case, Bukowski, Carey, et al., 1993 | 0 | 2 | 2 | 76 | 74 | 13.5 | | | 0.33
Case, Bukowski, Carey, et al., 1993 | 450 | 2 | 2 | 81 | 79 | 58.2 | | 44.7 | 2.3 | 0.0001 | 1.97
Henry, Brooks, Case, et al., 1995 | 0 | 2 | 2 | 65 | 61 | 6.6 | | | 0.4*±1.7
Henry, Brooks, Case, et al., 1995 | 450 | 2 | 2 | 67 | 64 | 48.4 | <0.0001 | 41.8 | 2.0*±2.3 | <0.0001 | 1.60
Kurz, Marth, Windbichler, et al., 1997 | 0 | 3 | 2 | 12 | 12 | 0.0 | | | 0.22
Kurz, Marth, Windbichler, et al., 1997 | 450 | 3 | 2 | 23 | 23 | 56.5 | 0.001 | 56.5 | 3.3 | | 3.08
Quirt, Couture, Pichette, et al., 1996 | 0 | 3 | 2 | 28 | 27 | | | | 0.6
Quirt, Couture, Pichette, et al., 1996 | 450 | 3 | 2 | 28 | 27 | | | | 1.6 | | 1.00
Silvestris, Romito, Fanelli, et al., 1995 | 0 | 3 | 3 | 24 | 22 | 0.0
Silvestris, Romito, Fanelli, et al., 1995 | 450 | 3 | 3 | 30 | 27 | 77.8 | | 77.8
Littlewood, Bajetta, Cella, et al., 1999 | 0 | 3 | 3 | 124 | 115 | 19.1 | | | 0.9
Littlewood, Bajetta, Cella, et al., 1999 | 450 | 3 | 3 | 251 | 244 | 70.5 | 0.001 | 51.4 | 2.5 | | 1.60
Weekly doses from 750 to 1,000 U/kg (higher doses)
Leon, Jimenez, Barona, et al., 1998 | 0 | 1 | 2 | 25 | 25 | | | | 0.1
Leon, Jimenez, Barona, et al., 1998 | 750 | 1 | 2 | 25 | 25 | 72.0 | | | 2.6 | <0.001 | 2.50
Sweeney, Nicolae, Ignacio, et al., 1998 | 0 | 2 | 1 | 24 | 24 | 0.0 | | | 0.29
Sweeney, Nicolae, Ignacio, et al., 1998 | 1000 | 2 | 1 | 24 | 22 | 45.5 | | 45.5 | 1.55 | 0.0012 | 1.26
Dusenbery, McGuire, Holt, et al., 1994 | 0 | 2 | 1 | 61 | 61 | | | | −0.8
Dusenbery, McGuire, Holt, et al., 1994 | 1000 | 2 | 1 | 15 | 15 | | | | 2.9 | 0.001 | 3.70
Lavey and Dempsey, 1993 | 0 | 2 | 1 | 20 | 20 | 5.0 | | | 0.0±0.7
Lavey and Dempsey, 1993 | 900 | 2 | 1 | 20 | 20 | 80.0 | <0.001 | 75.0 | 3.2±1.78 | <0.001 | 3.20
Welch, James, Wilkinson, et al., 1995 | 0 900 | 2 2 | 3 3 | 15 15 | 15 15 | | | | −2.1 −1.3 | | 0.80

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 Treatment regimen: 1 = fixed dose; 2 = decreasing dose; 3 = increasing dose.

3 Treatment duration: 1 =≤10 weeks; 2 = 12 to 16 weeks; 3 =≥20 weeks.

Table 27. Transfusion outcomes by weekly dose, two-arm studies of subcutaneous epoetin^1^

Citation | Dose (U/kg per week) | EPO Regimen Class ^2^ | EPO Tx Duration ^3^ | N Enrolled | N Evaluable | % Transfused | p Value | Difference in % Transfused (control-EPO) | RBC Units per Patient | p Value | RBC Units per Patient per 4 Weeks | Difference in RBC units per Patient per 4 Weeks (control-EPO)
Weekly doses from 300 to 450 U/kg (lower doses)
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 0 | 1 | 1 | 17 | 17 | 47.1
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 450 | 1 | 1 | 17 | 17 | 5.9 | 0.008 | 41.2
Gamucci, Thorel, Frasca, et al., 1993 | 0 | 1 | 2 | 17 | 17
Gamucci, Thorel, Frasca, et al., 1993 | 450 | 1 | 2 | 21 | 21
Oberhoff, Neri, Amadori, et al., 1998 | 0 | 1 | 2 | 110 | 88 | 40.9 | | | 0.6 | | 0.6
Oberhoff, Neri, Amadori, et al., 1998 | ~450 | 1 | 2 | 117 | 101 | 25.7 | ^4^ | 15.2 | 0.5 | 0.044 | 0.5 | 0.1
Markman, Reichman, Hakes, et al., 1993 | 0 | 1 | 3 | 46 | 40 | 22.5
Markman, Reichman, Hakes, et al., 1993 | 350 | 1 | 3 | 17 | 16 | 6.3 | NS | 16.2
Cascinu, Fedeli, Del Ferro, et al., 1994 | 0 | 2 | 1 | 50 | 49 | 57.1 | | | 1.8 | | 0.8
Cascinu, Fedeli, Del Ferro, et al., 1994 | 300 | 2 | 1 | 50 | 50 | 20 | 0.01 | 37.1 | 0.3 | 0.01 | 0.1 | 0.7
Del Mastro, Venturini, Lionetto, et al., 1997 | 0 | 2 | 2 | 31 | 31 | 6.5
Del Mastro, Venturini, Lionetto, et al., 1997 | 450 | 2 | 2 | 31 | 31 | 0.0 | NS ^5^ | 6.5
Case, Bukowski, Carey, et al., 1993 | 0 | 2 | 2 | 76 | 74 | 33.8^6^ | | | 1.6± 0.3 | | 0.8
Case, Bukowski, Carey, et al., 1993 | 450 | 2 | 2 | 81 | 79 | 25.3^6^ | NS^5^ | 8.5^6^ | 0.9± 0.3 | NS | 0.5 | 0.3
Henry, Brooks, Case, et al., 1995 | 0 | 2 | 2 | 65 | 61 | 68.9 | | | 4.0+ 0.8 | | 2.0
Henry, Brooks, Case, et al., 1995 | 450 | 2 | 2 | 67 | 64 | 53.1 | NS | 15.8 | 4.0+ 0.9 | NS | 2.0 | 0.0
Kurz, Marth, Windbichler, et al., 1997 | 0 | 3 | 2 | 12 | 12 | 66.7 | | | 3.6 | | 1.2
Kurz, Marth, Windbichler, et al., 1997 | 450 | 3 | 2 | 23 | 23 | 21.7 | 0.009 | 45.0 | 1.4 | | 0.5 | 0.7
Quirt, Couture, Pichette, et al., 1996 | 0 | 3 | 2 | 28 | 27 | 29.6 | | | 0.7
Quirt, Couture, Pichette, et al., 1996 | 450 | 3 | 2 | 28 | 27 | 14.8 | NS ^5^ | 14.8 | 0.2
Silvestris, Romito, Fanelli, et al., 1995 | 0 | 3 | 3 | 24 | 22
Silvestris, Romito, Fanelli, et al., 1995 | 450 | 3 | 3 | 30 | 27
Littlewood, Bajetta, Cella, et al., 1999 | 0 | 3 | 3 | 124 | 115 | 35.7^6^
Littlewood, Bajetta, Cella, et al., 1999 | 450 | 3 | 3 | 251 | 244 | 23^6^ | 0.0168 | 12.7^6^
Weekly doses from 750 to 1000 U/kg (higher doses)
Leon, Jimenez, Barona, et al., 1998 | 0 | 1 | 2 | 25 | 25 | 96 | | | 3.6 | | 1.2
Leon, Jimenez, Barona, et al., 1998 | 750 | 1 | 2 | 25 | 25 | 16 | <0.001 | 80.0 | 0.3 | <0.001 | 0.1 | 1.1
Sweeney, Nicolae, Ignacio, et al., 1998 | 0 | 2 | 1 | 24 | 24
Sweeney, Nicolae, Ignacio, et al., 1998 | 1,000 | 2 | 1 | 24 | 22
Dusenbery, McGuire, Holt, et al., 1994 | 0 | 2 | 1 | 61 | 61 | 6.6
Dusenbery, McGuire, Holt, et al., 1994 | 1,000 | 2 | 1 | 15 | 15 | 0.0 | | 6.60
Lavey and Dempsey, 1993 | 0 | 2 | 1 | 20 | 20
Lavey and Dempsey, 1993 | 900 | 2 | 1 | 20 | 20
Welch, James, Wilkinson, et al., 1995 | 0 | 2 | 3 | 15 | 15 | 53.3 | | | 5.4
Welch, James, Wilkinson, et al., 1995 | 900 | 2 | 3 | 15 | 15 | 26.7 | NS | 26.6 | 4.0 | NS

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

2 Treatment regimen: 1 = fixed dose; 2 = decreasing dose; 3 = increasing dose.

3 Treatment duration: 1 =≤10 weeks; 2 = 12 to 16 weeks; 3 =≥20 weeks.

4 Calculated odds ratio for transfusion suggests a significant difference, as upper limit of 95 percent confidence interval is <1.0 (see Meta-Analysis).

5 Calculated odds ratio for transfusion suggests no significant difference, as upper limit of 95 percent confidence interval is <1.0 (see Meta-Analysis).

6 Measured from day 28 to end of study.

All but two of the trials in the lower dose range used the 450 U/kg per week doses. The results of these two trials show that epoetin can be effective at the lower doses in this range. Cascinu, Fedeli, Del Ferro, et al. (1994; n=100) used a 300 U/kg per week dose and reported a significant reduction in percentage of patients transfused and RBC units per patient. Markman, Reichman, Hakes, et al. (1993; n=63) used a 350 U/kg per week dose and reported a significant difference in percentage of patients demonstrating a hematologic response.

Within the 300 to 450 U/kg per week range, the effect of the dosing regimen is of interest. Using an increasing dose regimen, in which the dose increases for patients who fail to respond to the initial dose of epoetin, could increase the percentage of patients who achieve a hematologic response. Increasing the number of patients who achieve a hematologic response could in turn improve transfusion outcomes, resulting in fewer patients transfused and fewer RBC units per patient. However, no studies included in this review directly compared hematologic response rates according to dosing regimen. The results show no obvious advantages for an increasing dose regimen within the group of studies using an initial dose of 300 to 450 U/kg per week. The range of differences between the epoetin and control arms in the percentage of patients achieving hematologic response is 42 percent to 80 percent for the decreasing dose regimen and 51 percent to 78 percent for the increasing dose regimen. However, such indirect comparison is of little value unless an effect of very large magnitude exists; based on the available data, no conclusions can be drawn.

### Key Question 2 Results and Conclusions

Does varying the characteristics of the administration of epoetin affect the outcomes of treatment?

The meta-analysis conducted on the effect of epoetin on transfusion outcomes also examined whether the characteristics of epoetin administration (dosing regimen, treatment duration, and dose range) have an effect on the summary estimate of the odds ratio for transfusion. Only epoetin dose appeared to have an independent effect on transfusion outcomes. However, this potentially was confounded by study quality. The results of two randomized controlled trials that directly compared lower and higher doses of epoetin (450 versus 900 U/kg per week) strongly suggest that the apparent relationship between dose and transfusion outcomes found in the meta-analysis is explained by differences in study quality rather than a dose-response relationship.

Of 1,134 patients enrolled in studies with baseline Hb <10 g/dL, the patient group for which the most robust evidence of transfusion prevention exists, all but 50 were treated with epoetin doses in the 300 to 450 U/kg per week range. This body of evidence clearly demonstrates that doses in the 300 to 450 U/kg per week range are adequate to increase Hb and reduce the percentage of patients transfused.

### Key Question 3 Results and Conclusions

Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment? Are there laboratory measurements that can either predict or permit early identification of patients whose anemia is likely to respond to epoetin?

Tables 28 through 32 summarize the data available on outcomes of epoetin for management of anemia related to chemotherapy or radiation therapy in populations of interest. For each characteristic of interest, these tables combine evidence from studies that limited eligibility to a homogeneous population of patients with evidence from studies that reported stratified outcomes for homogeneous subpopulations.

#### Type of Malignancy: Hematologic Malignancies versus Tumors of Solid Organs or Tissues

Table 28 shows the evidence available from the only two studies that either limited enrollment to (Silvestris, Romito, Fanelli, et al., 1995) or provided stratified outcomes for (Littlewood, Bajetta, Cella, et al., 1999) patients with hematologic malignancies (nonmyeloid leukemias, lymphomas, myeloma, etc.). Six other trials included patients with either hematologic malignancies or solid tumors but did not stratify results by type of malignancy (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995; Lavey and Dempsey, 1993; Leon, Jimenez, Barona, et al., 1998; Quirt, Couture, Pichette, et al., 1996; Varan, Buyukpamukcu, Kutluk, et al., 1999).

Table 28. Outcomes for subpopulations differing by type of malignancy^1^

Citation | N Enrolled (controls+treated) | N Evaluable (controls+treated) | % Response p Value (controls vs. treated) | Hb Change, g/dL p Value (controls vs. treated) | %Transfused p Value (controls vs. treated) | RBC Units per Patient p Value (controls vs. treated)
Hematologic malignancies
Silvestris, Romito, Fanelli, et al., 1995 | 54 (24+30) | 49 (22+27) | (0 vs. 77.8) | NR | NR | NR
Littlewood, Bajetta, Cella, et al., 1999 (stratum) | | 167 (54+113) | <0.0001^2^ (16.7 vs. 75.2) | (0.3 vs. 2.2) | 0.054^2^ (40.7 vs. 24.8) | NR
Mixed solid tissue/organ and hematologic malignancies
Lavey and Dempsey, 1993 (<3% hematologic) | 40 (20+20) | 40 (20+20) | <0.001 (5.0 vs. 80) | <0.001 (0 vs. 3.2) | NR | NR
Case, Bukowski, Carey et al., 1993 (41% hematologic) | 157 (76+81) | 153 (74+79) | (13.5 vs. 58.2) | 0.0001 (0.33 vs. 2.3) | (33.8 vs. 25.3) | NS (0.056) (1.6 vs. 0.9)
Henry, Brooks, Case et al., 1995 (17% hematologic) | 132 (65+67) | 125 (61+64) | <0.0001 (6.6 vs. 48.4) | <0.0001 (0.4 vs. 2.0) | NS (68.9 vs. 53.1) | NS
Varan, Buyukpamukcu, Kutluk et al., 1999 (21% hematologic) | 34 (17+17) | 34 (17+17) | NR | NR | 0.008 (47.1 vs. 5.9) | NR
Leon, Jimenez, Barona et al., 1998 (8% hematologic) | 50 (25+25) | 50 (25+25) | NR | <0.001 (0.1 vs. 2.6) | <0.001 (96 vs. 16) | <0.001 (3.6 vs. 0.3)
Quirt, Couture, Pichette et al., 1996 (percentage not reported) | 56 (28+28) | 54 (27+27) | NR | NR | (29.6 vs. 14.8) | (0.7 vs. 0.2)
Solid tumors
Oberhoff, Neri, Amadori, et al., 1998 | 227 0110+117) | 189 (88+101) | 0.0001 (6.8 vs. 34.7) | NR | (40.9 vs. 25.7) | 0.044 (0.6 vs. 0.5)
Sweeney, Nicolae, Ignacio, et al., 1998 | 48 (24+24) | 46 (24+22) | (0 vs. 45.5) | 0.0012(0.29 vs. 1.55) | NR | NR
Gamucci, Thorel, Frasca, et al., 1993 | 38 (17+21) | 38 (17+21) | NR | <0.005 (−1.5 vs. 0.9) | NR | NR
Kurz, Marth, Windbichler, et al., 1997 | 35 (12+23) | 35(12+23) | 0.001 (0 vs. 56.5) | (0.22 vs. 3.3) | 0.009 (66.7 vs. 21.7) | (3.6 vs. 1.4)
Markman, Reichman, Hakes, et al., 1993 | 63 (46+17) | 56 (40+16) | <0.005 (40 vs. 87.5) | NR | NS (22.5 vs. 6.3) | NR
Dusenbery, McGuire, Holt, et al., 1994 | 76 (61+15) | 76 (61+15) | NR | 0.001 (−0.8 vs. 2.9) | (6.6 vs. 0) | NR
Del Mastro, Venturini, Lionetto, et al., 1997 | 62 (31+31) | 62 (31+31) | NR | <0.005 (−3.1 vs. −0.8) | (6.5 vs. 0) | NR
Thatcher, De Campos, Bell, et al., 1999 | 130 (44+42+44) | 130 (44+42+44) | <0.05, 0.005 (34.1 vs. 52.4, 61.4) | (−3.4 vs. −3.2, −3.3) | <0.05, <0.001 (59.1 vs. 45.2, 20.5) | <0.01, <0.001 (6.1 vs. 3.8, 2.1)
Porter, Leahey, Polise, et al., 1996 | 24 (12+12) | 20 (10+10) | NR | NR | NS (100 vs. 90) | 0.01 (13 vs. 4.5)
Wurnig, Windhager, Schwameis, et al., 1996 | 30 (14+16) | 29 (14+15) | NR | NS | NS (100 vs. 53.3) | <0.01 (8.4 vs. 2.1)
Welch, James, Wilkinson, et al., 1995 | 30 (15+15) | 30 (15+15) | NR | (−2.1 vs. −1.3) | NS (53.3 vs. 26.7) | NS (5.4 vs. 4.0)
Henke, Guttenberger, Barke, et al., 1999 | 44 (11+19+14) | 44 (11+19+14) | NR | <0.0001 (0.6 vs. 3.2, 3.5) | NR | NR
Cascinu, Fedeli, Del Ferro, et al., 1994 | 100 (50+50) | 99 (49+50) | (2 vs. 82) | (−0.6 vs. 1.9) | 0.01 (57.1 vs. 20) | 0.01 (1.8 vs. 0.3)
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 122 (34+46+42) | 120 (33+45+42) | NR | NR | (39.4 vs. 4.4, 14.3) | (1.2 vs. 0.3, 0.4)
Littlewood, Bajetta, Cella, et al., 1999 (stratum) | | 192 (61+131) | <0.0001^2^ (21.3 vs. 66.4) | (0.7 vs. 2.3) | 0.199^2^(31.1 vs. 21.4) | NR

1 "Higher quality" trials in bold font ; nonrandomized studies in italics.

2 Chi-square test (or Fisher's exact test when ≤5 in one or more cells) calculated for this review from reported data.

Fifteen studies restricted enrollment to patients with tumors of solid organs or tissues (Table 28). Seven of the 15 studied patients with one type of malignancy, including three on ovarian cancer (Markman, Reichman, Hakes, et al., 1993; ten Bokkel Huinink, de Swart, van Toorn, et al., 1998; Welch, James, Wilkinson, et al., 1995) and one each on breast cancer (Del Mastro, Venturini, Lionetto, et al., 1997), small cell lung cancer (Thatcher, De Campos, Bell, et al., 1999), Ewing's or osteosarcoma (Wurnig, Windhager, Schwameis, et al., 1996), and cervical cancer (Dusenbery, McGuire, Holt, et al., 1994. The remaining eight included patients with various types of malignancies of solid tissues or organs but did not provide stratified outcomes for different solid tumor types. The limited evidence from these 15 trials does not identify any obvious or systematic variation among tumors of different solid tissues or organs with respect to effects of epoetin on hematologic responses or transfusion use.

The data from Silvestris, Romito, Fanelli, et al. (1995) and Littlewood, Bajetta, Cella, et al. (1999) indicate that epoetin increases hematologic responses in patients with nonmyeloid hematologic malignancies to a similar degree as in patients with tumors of solid organs or tissues (see Table 28). Approximately 47 percent of the population studied by Littlewood and colleagues (1999) had a hematologic malignancy. The increased percentage of epoetin-treated patients achieving hematologic response was statistically significant for patients with hematologic malignancies and for those with solid tumors. Littlewood and colleagues (1999) reported a statistically significant difference favoring epoetin treatment in the percentage of all patients transfused (p=0.017). Although results did not actually reach statistical significance for either the subgroup of patients with hematologic malignancies (p=0.054) or the subgroup with solid tumors (p=0.199), taken together the results support the hypothesis that patients with nonmyeloid hematologic malignancies also benefit from epoetin treatment.

The absence of obvious differences in outcomes between patients in the 6 trials with mixed tumor populations and patients in the 15 trials that limited enrollment to patients with tumors of solid tissues and organs (see Table 28) further increases the likelihood that patients with both types of malignancies benefit from epoetin. Note, however, that myeloid malignancies were excluded from all eight trials with some or all patients bearing hematologic malignancies. This was likely because of concerns that epoetin might stimulate proliferation of the malignant myeloid cells. Consequently, no evidence is available regarding the outcomes of epoetin use in patients with myeloid malignancies.

#### Age

Table 29 summarizes the available data on outcomes of epoetin for managing anemia associated with treatment for malignancy in patients of different age groups. No studies provided data on outcomes specifically for geriatric populations. However, many of the studies on adults included substantial numbers of patients older than 65 years, and some even included patients in their eighties and nineties. There was no indication in any of the reports from trials that included such older adults that epoetin might be less effective at reducing the risk of transfusion or the number of RBC units transfused per patient in geriatric patients.

Table 29. Outcomes for subpopulations differing by age^1^

Citation | Mean or Median Age (controls/Epo) | N Enrolled (controls+Epo) | N Evaluable (controls+Epo) | % Response p Value (controls vs. Epo) | Hb Change, g/dL p Value (controls vs. Epo) | %Transfused p Value (controls vs. Epo) | RBC Units per Patient p Value (controls vs. Epo)
Adults
Oberhoff, Neri, Amadori, et al., 1998 | 56/53 | 227 (110+117) | 189 (88+101) | 0.0001 (6.8 vs. 34.7) | NR | (40.9 vs. 25.7) | 0.044 (0.6 vs. 0.5)
Sweeney, Nicolae, Ignacio, et al., 1998 | 62.7/62.3 | 48 (24+24) | 46 (24+22) | (0 vs. 45.5) | 0.0012 (0.29 vs. 1.55) | NR | NR
Gamucci, Thorel, Frasca, et al., 1993 | 54 | 38 (17+21) | 38 (17+21) | NR | <0.005 (−1.5 vs. 0.9) | NR | NR
Kurz, Marth, Windbichler, et al., 1997 | 52.7/54.4 | 35 (12+23) | 35 (12+23) | 0.001 (0 vs. 56.5) | (0.22 vs. 3.3) | 0.009 (66.7 vs. 21.7) | (3.6 vs. 1.4)
Markman, Reichman, Hakes, et al., 1993 | 52/57 | 63 (46+17) | 56 (40+16) | <0.005 (40 vs. 87.5) | NR | NS (22.5 vs. 6.3) | NR
Dusenbery, McGuire, Holt, et al., 1994 | 42/43 | 76 (61+15) | 76 (61+15) | NR | 0.001 (−0.8 vs. 2.9) | (6.6 vs. 0) | NR
Lavey and Dempsey, 1993 | 62/58 | 40 (20+20) | 40 (20+20) | <0.001 (5.0 vs. 80) | <0.001 (0 vs. 3.2) | NR | NR
Del Mastro, Venturini, Lionetto, et al., 1997 | 56/54 | 62 (31+31) | 62 (31+31) | NR | <0.005 (−3.1 vs. −0.8) | (6.5 vs. 0) | NR
Thatcher, De Campos, Bell, et al., 1999 | 60/59/58.5 | 130 (44+42+44) | 130 (44+42+44) | <0.05, 0.005 (34.1 vs. 52.4, 61.4) | (−3.4 vs. −3.2, −3.3) | <0.05, <0.001 (59.1 vs. 45.2, 20.5) | <0.01, <0.001 (6.1 vs. 3.8, 2.1)
Case, Bukowski, Carey, et al., 1993 | 64 | 157 (76+81) | 153 (74+79) | (13.5 vs. 58.2) | 0.0001 (0.33 vs. 2.3) | (33.8 vs. 25.3) | NS (0.056) (1.6 vs. 0.9)
Wurnig, Windhager, Schwameis, et al., 1996 | 28.5 | 30 (14+16) | 29 (14+15) | NR | NS | NS (100 vs. 53.3) | <0.01 (8.4 vs. 2.1)
Henry, Brooks, Case, et al., 1995 | 59/58 | 132 (65+67) | 125 (61+64) | <0.0001 (6.6 vs. 48.4) | <0.0001 (0.4 vs. 2.0) | NS (68.9 vs. 53.1) | NS
Littlewood, Bajetta, Cella, et al., 1999 | 59.6/58.3 | 375 (124+251) | 359 (115+244) | 0.001 (19.1 vs. 70.5) | (0.9 vs. 2.5) | 0.0168 (35.7 vs. 23.0) | NR
Cascinu, Fedeli, Del Ferro, et al., 1994 | 57/58 | 100 (50+50) | 99 (49+50) | (2 vs. 82) | (−0.6 vs. 1.9) | 0.01 (57.1 vs. 20) | 0.01 (1.8 vs. 0.3)
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 58.8/58.8/61 | 122 (34+46+42) | 120 (33+45+42) | NR | NR | (39.4 vs. 4.4, 14.3) | (1.2 vs. 0.3, 0.4)
Henke, Guttenberger, Barke, et al., 1999 | NR | 44 (11+19+14) | 44 (11+19+14) | NR | <0.0001 (0.6 vs. 3.2, 3.5) | NR | NR
Silvestris, Romito, Fanelli, et al., 1995 | NR | 54 (24+30) | 49 (22+27) | (0 vs. 77.8) | NR | NR | NR
Welch, James, Wilkinson, et al., 1995 | NR | 30 (15+15) | 30 (15+15) | NR | (−2.1 vs. −1.3) | NS (53.3 vs. 26.7) | NS (5.4 vs. 4.0)
Pediatric
Porter, Leahey, Polise, et al., 1996 | 13/14 | 24 (12+12) | 20 (10+10) | NR | NR | NS (100 vs. 90) | 0.01 (13 vs. 4.5)
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 5 | 34 (17+17) | 34 (17+17) | NR | NR | 0.008 (47.1 vs. 5.9) | NR
Leon, Jimenez, Barona, et al., 1998 | 11.8/12.6 | 50 (25+25) | 50 (25+25) | NR | <0.001 (0.1 vs. 2.6) | <0.001 (96 vs. 16) | <0.001 (3.6 vs. 0.3)
Unknown
Quirt, Couture, Pichette, et al., 1996 | | 56 (28+28) | 54 (27+27) | NR | NR | (29.6 vs. 14.8) | (0.7 vs. 0.2)

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

Three trials (n=104 evaluable) focused specifically on pediatric patients (Leon, Jimenez, Barona, et al., 1998; Porter, Leahey, Polise, et al., 1996; Varan, Buyukpamukcu, Kutluk, et al., 1999). As reviewed in greater detail in Key Question 1 above, the data from these trials suggest that children as well as adults benefit from epoetin use. Baseline Hb was <10 g/dL in all three studies. Statistically significant effects favoring the epoetin arms were reported by two of three trials for the percentage of patients transfused (Leon, Jimenez, Barona, et al., 1998; Varan, Buyukpamukcu, Kutluk, et al., 1999). The third trial reported a significant difference for the number of RBC units transfused per patient (Porter, Leahey, Polise, et al., 1996).

#### Iron Supplementation

As shown in Table 30, only 3 of 22 trials specified that patients in both control and epoetin-treated arms were not supplemented with iron (Thatcher, De Campos, Bell, et al., 1999; Varan, Buyukpamukcu, Kutluk, et al., 1999; Wurnig, Windhager, Schwameis, et al., 1996). For each transfusion outcome, two of the three trials without iron supplementation reported statistically significant differences in favor of the study arms treated with epoetin. These results suggest routine iron supplementation of all patients irrespective of iron status is probably unnecessary.

Table 30. Outcomes for subpopulations differing by iron supplementation^1^

Citation | N Enrolled (controls+Epo) | N Evaluable (controls+Epo) | % Response p Value (controls vs. Epo) | Hb Change, g/dL p Value (controls vs. Epo) | %Transfused p Value (controls vs. Epo) | RBC Units per patient p Value (controls vs. Epo)
No iron supplementation
Thatcher, De Campos, Bell, et al., 1999 | 130 (44+42+44) | 130 (44+42+44) | <0.05, 0.005 (34.1 vs. 52.4, 61.4) | (−3.4 vs. −3.2, −3.3) | <0.05, <0.001 (59.1 vs. 45.2, 20.5) | <0.01, <0.001 (6.1 vs. 3.8, 2.1)
Wurnig, Windhager, Schwameis, et al., 1996 | 30 (14+16) | 29 (14+15) | NR | NS | NS (100 vs. 53.3) | <0.01 (8.4 vs. 2.1)
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 34 (17+17) | 34 (17+17) | NR | NR | 0.008 (47.1 vs. 5.9) | NR
Iron supplementation not specified
Oberhoff, Neri, Amadori, et al., 1998 | 227 (110+117) | 189 (88+101) | 0.0001 (6.8 vs. 34.7) | NR | (40.9 vs. 25.7) | 0.044 (0.6 vs. 0.5)
Markman, Reichman, Hakes, et al., 1993 | 63 (46+17) | 56 (40+16) | <0.005 (40 vs. 87.5) | NR | NS (22.5 vs. 6.3) | NR
Case, Bukowski, Carey, et al., 1993 | 157 (76+81) | 153 (74+79) | (13.5 vs. 58.2) | 0.0001 (0.33 vs. 2.3) | (33.8 vs. 25.3) | NS (0.056) (1.6 vs. 0.9)
Henry, Brooks, Case, et al., 1995 | 132 (65+67) | 125 (61+64) | <0.0001 (6.6 vs. 48.4) | <0.0001 (0.4 vs. 2.0) | NS (68.9 vs. 53.1) | NS
Littlewood, Bajetta, Cella, et al., 1999 | 375 (124+251) | 359 (115+244) | 0.001 (19.1 vs. 70.5) | (0.9 vs. 2.5) | 0.0168 (35.7 vs. 23.0) | NR
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 122 (34+46+42) | 120 (33+45+42) | NR | NR | (39.4 vs. 4.4, 14.3) | (1.2 vs. 0.3, 0.4)
Quirt, Couture, Pichette, et al., 1996 | 56 (28+28) | 54 (27+27) | NR | NR | (29.6 vs. 14.8) | (0.7 vs. 0.2)
Epoetin or epoetin and control arm iron supplementation
Silvestris, Romito, Fanelli, et al., 1995 | 54 (24+30) | 49 (22+27) | (0 vs. 77.8) | NR | NR | NR
Sweeney, Nicolae, Ignacio, et al., 1998 | 48 (24+24) | 46 (24+22) | (0 vs. 45.5) | 0.0012 (0.29 vs. 1.55) | NR | NR
Gamucci, Thorel, Frasca, et al., 1993 | 38 (17+21) | 38 (17+21) | NR | <0.005 (−1.5 vs. 0.9) | NR | NR
Kurz, Marth, Windbichler, et al., 1997 | 35 (12+23) | 35 (12+23) | 0.001 (0 vs. 56.5) | (0.22 vs. 3.3) | 0.009 (66.7 vs. 21.7) | (3.6 vs. 1.4)
Dusenbery, McGuire, Holt, et al., 1994 | 76 (61+15) | 76 (61+15) | NR | 0.001 (−0.8 vs. 2.9) | (6.6 vs. 0) | NR
Lavey and Dempsey, 1993 | 40 (20+20) | 40 (20+20) | <0.001 (5.0 vs. 80) | <0.001 (0 vs. 3.2) | NR | NR
Del Mastro, Venturini, Lionetto, et al., 1997 | 62 (31+31) | 62 (31+31) | NR | <0.005 (−3.1 vs. −0.8) | (6.5 vs. 0) | NR
Porter, Leahey, Polise, et al., 1996 | 24 (12+12) | 20 (10+10) | NR | NR | NS (100 vs. 90) | 0.01 (13 vs. 4.5)
Welch, James, Wilkinson et al., 1995 | 30 (15+15) | 30 (15+15) | NR | (−2.1 vs. −1.3) | NS (53.3 vs. 26.7) | NS (5.4 vs. 4.0)
Henke, Guttenberger, Barke, et al., 1999 | 44 (11+19+14) | 44 (11+19+14) | NR | <0.0001 (0.6 vs. 3.2, 3.5) | NR | NR
Leon, Jimenez, Barona, et al., 1998 | 50 (25+25) | 50 (25+25) | NR | <0.001 (0.1 vs. 2.6) | <0.001 (96 vs. 16) | <0.001 (3.6 vs. 0.3)
Cascinu, Fedeli, Del Ferro, et al., 1994 | 100 (50+50) | 99 (49+50) | (2 vs. 82) | (−0.6 vs. 1.9) | 0.01 (57.1 vs. 20) | 0.01 (1.8 vs. 0.3)

1 "Higher quality" trials in bold font ; nonrandomized studies in italics.

Note, however, that only one of these three trials (Thatcher, De Campos, Bell, et al., 1999) reported a significant effect of epoetin on a hematologic outcome (percent response). The study by Varan and coworkers (1999) did not report a test for significance of the difference between arms in Hb change, and the study by Wurnig and colleagues (1996) reported that the difference was not significant but did not report the data (see Table 15). Data from the Thatcher and coworkers (1999) study on the percentage of patients with Hb <10 g/dL in each chemotherapy cycle suggest that the major benefit from epoetin occurred in the earlier part of the trial (chemotherapy cycles two through four). Furthermore, a second of the trials that specified no iron supplementation was among those of shortest duration (<10 weeks; Varan, Buyukpamukcu, Kutluk, et al., 1999). Thus, these results do not rule out the possibility that when epoetin use is extended for longer treatment durations, iron stores might gradually limit responses in patients with inadequate iron intake.

#### Therapeutic Regimen

Table 31 summarizes the data available to address whether outcomes of epoetin may vary for different therapy regimens for malignancy. Three studies showed that epoetin increases Hb levels for patients managed with radiotherapy alone (Henke, Guttenberger, Barke, et al., 1999; Lavey and Dempsey, 1993; Sweeney, Nicolae, Ignacio. et al., 1998). However, mean Hb levels of control patients did not decrease from baseline values (10.7 to 12.3 g/dL) over the course of these three trials. Thus, the radiotherapy regimens utilized apparently did not contribute to or exacerbate preexisting mild anemia. Note also that none of these trials provided data on transfusion outcomes, possibly because the mild anemia was not associated with a sufficient risk of transfusion.

Table 31. Outcomes for subpopulations differing by treatment for malignancy^1^

Citation | N Enrolled (controls+EPO) | N Evaluable (controls+Epo) | % Response p Value (controls vs. Epo) | Hb Change, g/dL p Value (controls vs. Epo) | %Transfused p Value (controls vs. Epo) | RBC Units per patient p Value (controls vs. Epo)
Radiotherapy only
Lavey and Dempsey, 1993 | 40 (20+20) | 40 (20+20) | <0.001 (5.0 vs. 80) | <0.001 (0 vs. 3.2) | NR | NR
Henke, Guttenberger, Barke, et al., 1999 | 44 (11+19+14) | 44 (11+19+14) | NR | <0.0001 (0.6 vs. 3.2, 3.5) | NR | NR
Sweeney, Nicolae, Ignacio, et al., 1998 | 48 (24+24) | 46 (24+22) | (0 vs. 45.5) | 0.0012 (0.29 vs. 1.55) | NR | NR
Nonplatinum chemotherapy, no or unknown radiotherapy
Silvestris, Romito, Fanelli, et al., 1995 | 54 (24+30) | 49 (22+27) | (0 vs. 77.8) | NR | NR | NR
Case, Bukowski, Carey, et al., 1993 | 157 (76+81) | 153 (74+79) | (13.5 vs. 58.2) | 0.0001 (0.33 vs. 2.3) | (33.8 vs. 25.3) | NS (0.056) (1.6 vs. 0.9)
Littlewood, Bajetta, Cella, et al., 1999 | 375 (124+251) | 359 (115+244) | 0.001 (19.1 vs. 70.5) | (0.9 vs. 2.5) | 0.0168 (35.7 vs. 23.0) | NR
Nonplatinum chemotherapy and radiotherapy
Del Mastro, Venturini, Lionetto, et al., 1997 | 62 (31+31) | 62 (31+31) | NR | <0.005 (−3.1 vs. −0.8) | (6.5 vs. 0) | NR
Porter, Leahey, Polise, et al., 1996 | 24 (12+12) | 20 (10+10) | NR | NR | NS (100 vs. 90) | 0.01 (13 vs. 4.5)
Platinum chemotherapy, no or unknown radiotherapy
Kurz, Marth, Windbichler, et al., 1997 | 35 (12+23) | 35 (12+23) | 0.001 (0 vs. 56.5) | (0.22 vs. 3.3) | 0.009 (66.7 vs. 21.7) | (3.6 vs. 1.4)
Markman, Reichman, Hakes, et al., 1993 | 63 (46+17) | 56 (40+16) | <0.005 (40 vs. 87.5) | NR | NS (22.5 vs. 6.3) | NR
Wurnig, Windhager, Schwameis, et al., 1996 | 30 (14+16) | 29 (14+15) | NR | NS | NS (100 vs. 53.3) | <0.01 (8.4 vs. 2.1)
Welch, James, Wilkinson, et al., 1995 | 30 (15+15) | 30 (15+15) | NR | (−2.1 vs. −1.3) | NS (53.3 vs. 26.7) | NS (5.4 vs. 4.0)
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 122 (34+46+42) | 120 (33+45+42) | NR | NR | (39.4 vs. 4.4, 14.3) | (1.2 vs. 0.3, 0.4)
Oberhoff, Neri, Amadori, et al., 1998 | 227 (110+117) | 189 (88+101) | 0.0001 (6.8 vs. 34.7) | NR | (40.9 vs. 25.7) | 0.044 (0.6 vs. 0.5)
Gamucci, Thorel, Frasca, et al., 1993 | 38 (17+21) | 38 (17+21) | NR | <0.005 (−1.5 vs. 0.9) | NR | NR
Henry, Brooks, Case, et al., 1995 | 132 (65+67) | 125 (61+64) | <0.0001 (6.6 vs. 48.4) | <0.0001 (0.4 vs. 2.0) | NS (68.9 vs. 53.1) | NS
Cascinu, Fedeli, Del Ferro, et al., 1994 | 100 (50+50) | 99 (49+50) | (2 vs. 82) | (−0.6 vs. 1.9) | 0.01 (57.1 vs. 20) | 0.01 (1.8 vs. 0.3)
Platinum chemotherapy and radiotherapy
Dusenbery, McGuire, Holt, et al., 1994 | 76 (61+15) | 76 (61+15) | NR | 0.001 (−0.8 vs. 2.9) | (6.6 vs. 0) | NR
Thatcher, De Campos, Bell, et al., 1999 | 130 (44+42+44) | 130 (44+42+44) | <0.05, 0.005 (34.1 vs. 52.4, 61.4) | (−3.4 vs. −3.2, −3.3) | <0.05, <0.001 (59.1 vs. 45.2, 20.5) | <0.01, <0.001 (6.1 vs. 3.8, 2.1)
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 34 (17+17) | 34 (17+17) | NR | NR | 0.008 (47.1 vs. 5.9) | NR
Unknown chemotherapy type, no or unknown radiotherapy
Leon, Jimenez, Barona, et al., 1998 | 50 (25+25) | 50 (25+25) | NR | <0.001 (0.1 vs. 2.6) | <0.001 (96 vs. 16) | <0.001 (3.6 vs. 0.3)
Quirt, Couture, Pichette, et al., 1996 | 56 (28+28) | 54 (27+27) | NR | NR | (29.6 vs. 14.8) | (0.7 vs. 0.2)

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

An additional goal of these three studies was to test the hypothesis that correcting anemia and increasing tumor oxygenation might enhance the effectiveness of radiation therapy. As discussed in the Background section, the rationale for this hypothesis is based on the role of oxygen in the mechanism by which radiation exerts its cytocidal effects. Only one of the three trials (Henke, Guttenberger, Barke, et al., 1999) briefly discussed clinical outcomes of radiation therapy (local tumor control). Thus, these studies provide insufficient evidence to address this hypothesis.

The largest number of trials included substantial percentages of patients receiving either cisplatin or carboplatin as part of their treatment regimen (12 trials; n=961 evaluable patients; Table 31). In three of these studies (n=262), all patients received cisplatin (Cascinu, Fedeli, Del Ferro, et al., 1994; Gamucci, Thorel, Frasca, et al., 1993; Henry, Brooks, Case, et al., 1995). Epoetin significantly improved hematologic responses in two of these trials and significantly decreased transfusion risk in the third (see Table 31). Only one study (n=56) used carboplatin for all patients (Markman, Reichman, Hakes, et al., 1993), whereas three others (n=280) used carboplatin in 57 percent, 66 percent, and 82 percent of patients, respectively (ten Bokkel Huinink, de Swart, van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; Welch, James, Wilkinson, et al., 1995). Epoetin significantly increased hematologic responses in two of these four trials (Markman, Reichman, Hakes, et al., 1993; Thatcher, De Campos, Bell, et al., 1999) and also significantly reduced transfusion risk in one study (Thatcher, De Campos, Bell, et al., 1999). Thus, the studies included in this review report evidence to demonstrate benefit from epoetin for patients receiving chemotherapy regimens that include either cisplatin or carboplatin.

Five trials (n=643; Table 31) used chemotherapy regimens that did not include either cisplatin or carboplatin. Three (n=574) of the five reported that epoetin significantly increased either the percentage of hematologic responses (Littlewood, Bajetta, Cella, et al., 1999) or the mean change in Hb levels (Case, Bukowski, Carey, et al., 1993; Del Mastro, Venturini, Lionetto, et al., 1997). One of these trials also reported a significant reduction in the risk of transfusion (Littlewood, Bajetta, Cella, et al., 1999). Thus, the included studies also provide evidence for clinical benefit from epoetin in patients given chemotherapy regimens that do not include a platinum compound.

#### Prior Transfusion

Table 32 summarizes the limited data available to compare the benefits from epoetin use in patients who either were or were not previously transfused. One study (n=46) in which < 20 percent of patients were previously transfused reported that epoetin significantly increased the mean change in Hb levels (Sweeney, Nicolae, Ignacio, et al., 1998). A second study in a similar population (n=34) reported that epoetin significantly decreased the risk of transfusion (Varan, Buyukpamukcu, Kutluk, et al., 1999). The only study with >80 percent of patients previously transfused (n=50) reported that epoetin significantly increased mean Hb levels and significantly reduced the risk of transfusion (Leon, Jimenez, Barona, et al., 1998). Thus, the limited data available suggest that patients may benefit from epoetin treatment whether or not they have a prior history of transfusion.

Table 32. Outcomes for Subpopulations Differing by Prior Transfusion History

Citation | N Enrolled (controls+Epo) | N Evaluable (controls+Epo) | % Response p Value (controls vs. Epo) | Hb Change, g/dL p Value (controls vs. Epo) | %Transfused p Value (controls vs. Epo) | RBC Units per patient p Value (controls vs. Epo)
Prior transfusion dependence <20%
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 34 (17+17) | 34 (17+17) | NR | NR | 0.008 (47.1 vs. 5.9) | NR
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 122 (34+46+42) | 120 (33+45+42) | NR | NR | (39.4 vs. 4.4, 14.3) | (1.2 vs. 0.3, 0.4)
Sweeney, Nicolae, Ignacio, et al., 1998 | 48 (24+24) | 46 (24+22) | (0 vs. 45.5) | 0.0012 (0.29 vs. 1.55) | NR | NR
Prior transfusion dependence >80%
Leon, Jimenez, Barona, et al., 1998 | 50 (25+25) | 50 (25+25) | NR | <0.001 (0.1 vs. 2.6) | <0.001 (96 vs. 16) | <0.001 (3.6 vs. 0.3)

1 "Higher quality" trials in bold font; nonrandomized studies in italics.

#### Predictors of Response

Several studies attempted to define predictors of response to epoetin therapy. We abstracted any information, including text statements without data, statistical testing detail, or stated significance values, that evaluated the ability of any parameter to predict response. Table 33 summarizes the results for any potential predictor reported by two or more studies.

There was a high degree of variability among studies as to which potential predictors were selected for analysis, which outcomes were used as indicators of response, and how the analysis was reported. Several studies did not identify the type of statistical analysis used, several used univariate analyses (e.g., correlation coefficient, chi-square test), and one reported use of multiple linear regression (Case, Bukowski, Carey, et al., 1993).

Overall, no significant predictors of response to epoetin therapy emerged from these various analyses. In particular, neither baseline serum erythropoietin nor the ratio of observed to predicted serum erythropoietin levels predicted response in any analysis.

### Key Question 4 Results and Conclusions

What are the incidence and severity of adverse effects associated with the use of epoetin and how do these compare with the adverse effects of transfusion?

Fifteen of the included studies (n=1,554) reported adverse events for at least the epoetin-treated study arm. The number of patients with specific adverse events potentially related to epoetin treatment was collected for each of these studies. Table 34 lists the specific adverse events recorded and the percentage of patients with each adverse event (out of the total number of patients evaluated). Some studies also (or only) listed a total number of patients in each study arm who experienced any adverse event, listed in Table 34 as "any adverse effect." We used the chi-square test (or Fisher's exact test, when cell number was limiting) to determine if there were significant differences between treatment arms with respect to the frequency of adverse events.

Table 34. Adverse events reported by studies on patients being treated for malignancy

Adverse Event | No. of Studies Reporting | N evaluated (controls+treated) | % Controls with Adverse Effects | % Treated with Adverse Effects | p Value ^1^
Any adverse effect (each patient counted once only) | 10 | 1,155 (473+682) | 45.9 | 56.3 | 0.054
Hypertension (highest freq. if systolic/diastolic separated) | 9 | 722 (285+437) | 2.1 | 4.1 | 0.21
Deep vein thrombosis or thromboembolism | 6 | 580 (238+342) | 2.5 | 4.7 | 0.41
Hemorrhage and/or thrombocytopenia | 2 | 161 (80+81) | 5.0 | 4.9 | 1.0
Skin rash, irritation, and/or pruritus | 6 | 372 (121+251) | 5.0 | 6.8 | 0.68
Seizures | 4 | 408 (200+208) | 2.0 | 2.4 | 1.0
Injection site pain | 3 | 177 (77+100) | 5.2 | 9.0 | 0.54
Fatigue (separate from QoL reporting) | 4 | 699 (264+435) | 18.9 | 11.3 | 0.02
Withdrawals (due to adverse events) | 8 | 846 (387+459) | 12.4 | 17.9 | 0.07
Mortality (from any cause, while on study) | 2 | 338 (137+201) | 11.7 | 7.0 | 0.24

1 Chi-square test.

The frequency of nearly all reported adverse events does not appear to differ markedly between epoetin-treated patients and controls. Fatigue is the only adverse event for which there was a statistically significant difference, with controls reporting fatigue more frequently than those treated with epoetin. This is consistent with more severe anemia throughout the study duration in the control patients.

Note that the "any adverse effect" results are driven by one large unpublished trial (Littlewood, Bajetta, Cella, et al., 1999), in which at least one adverse event was reported for >80 percent of patients in each study arm. The trend favored the control arm but was not quite statistically significant. There was also a nonsignificant trend towards more frequent withdrawals as a result of adverse events among epoetin-treated patients than among controls. No specific adverse events are significantly associated with epoetin treatment in this study.

## General Conclusions

Our conclusions are based on data abstraction and analysis of 22 controlled trials with a total enrollment of 1,927 patients.^7^ All trials compared the outcomes of managing anemia with epoetin treatment or with RBC transfusion alone in patients undergoing therapy for a malignancy. Eighteen trials with a total 1,698 enrolled patients (88 percent) were randomized, and seven randomized trials with a total of 853 patients were placebo controlled and double blind (44 percent). The number of patients reported as evaluable is 1,838, which is 95 percent of all enrolled patients. We classified the 22 trials into three categories defined by the study patients' mean Hb at enrollment: Hb>12 g/dL; Hb >10 but <12 g/dL; and Hb<10 g/dL. No trial directly compared the outcomes of initiating epoetin treatment at different Hb thresholds.

7 Recently, an additional study was published that enrolled 30 patients (Dunphy, Harrison, Dunleavy, et al., 1999). These data, which are summarized in an earlier footnote, do not change any conclusions of this review.

What are the outcomes of managing anemia with epoetin compared with transfusion alone? What are the relative effects of epoetin treatment (with transfusion used as necessary) when different Hb thresholds are used to initiate treatment?

- We found adequate and consistent evidence that epoetin increases Hb levels and percent of patients demonstrating hematologic response when compared with controls managed by transfusion alone. This was true for pediatric patients as well as adults.
- For all randomized studies delivering epoetin subcutaneously, the odds of transfusion for epoetin-treated patients is reduced by a factor of 0.380 compared with the odds for patients supported with transfusion alone. The overall NNT calculated for this group of studies is 4.4 (95 percent CI, 3.6 to 6.1), which suggests four to five patients must be treated to spare one patient from transfusion.
- Sensitivity analysis found a smaller magnitude of risk reduction for higher quality studies, which were double blinded. The odds of transfusion for epoetin-treated patients are reduced by a factor of 0.453 for higher quality studies compared with reduction by a factor of 0.137 for lower quality studies. For higher quality studies, the calculated NNT is 5.2 (95 percent CI, 3.8 to 8.4); and for lower quality studies, the calculated NNT is 2.6 (95 percent CI, 2.1 to 3.8). Thus, the higher quality studies predict one patient would avoid transfusion for every five to six patients treated with epoetin, and the lesser quality studies predict one for every two to three treated. There is evidence that in unblinded studies, physicians may be more aggressive in transfusing patients in the control arm, thus overestimating the observed effect of epoetin.
- The strongest evidence for an effect of epoetin on quality-of-life outcomes is an unpublished randomized double-blinded trial in a patient population with baseline Hb level <10 g/dL, which found significant differences in score changes for three questions that used visual analog scales (n evaluable=335) and for the FACT-An (n evaluable =290) that favored the epoetin-treated arm. As of this writing, no information is available to assess the study protocol for bias resulting from methods used to collect quality-of-life data, the impact of missing quality-of-life data, or the clinical significance of the reported changes in quality-of-life scores. Eight other published studies, which included a total of 516 patients evaluable for quality-of-life outcomes, do not provide consistent evidence that epoetin improves quality-of-life outcomes.
- The most robust evidence that epoetin improves transfusion outcomes for patients undergoing therapy for malignancy compared with transfusion alone comes from trials in patient groups with baseline Hb <10 g/dL.Transfusion outcomes do not appear to be superior in trials where epoetin treatment is initiated in groups of patients who have mean Hb> 10 g/dL compared with outcomes in trials where mean Hb is <10 g/dL. Among trials on adult patients with baseline Hb <10 g/dL, the range of differences between epoetin and control arms for percentage of patients transfused was 9 percent to 45 percent. For baseline Hb >10 but <12 g/dL, the range was 7 percent to 47 percent, and 7 percent to 39 percent for baseline Hb>12 g/dL.
- The available evidence is not adequate to determine whether outcomes of epoetin treatment are superior when treatment is initiated in groups of patients who have mean Hb >10 g/dL, compared with outcomes in groups where mean Hb is <10 g/dL. Randomized controlled trials, double blinded and adequately powered, are needed. Inferences from indirect comparison of the results of the available trials cannot resolve this question.
- While it is possible that adequately powered comparative trials might demonstrate the superiority of epoetin intervention at the higher Hb levels, our examination of this evidence base suggests why that may not prove to be true. First, patients whose entry level Hb is below the mean may account for a substantial proportion of transfusions in epoetin-treated patients in trials where baseline Hb is <10 g/dL. Thus the greatest yield for reducing the number of patients transfused in this population might come from initiating epoetin before the Hb level falls substantially below 10, rather than by initiating epoetin treatment at a level substantially above 10 g/dL. Second, in all trials, patients who are unresponsive to epoetin may account for a substantial proportion of patients transfused. Initiating epoetin treatment at a higher Hb level is not expected to reduce transfusions in this subgroup of patients.

In the studies included in this review, does varying the characteristics of the administration of epoetin affect the outcomes of treatment, particularly correction of anemia? Are the characteristics of epoetin administration likely to confound the interpretation of the evidence on the relative effects of epoetin treatment when different Hb thresholds are used to initiate epoetin treatment?

- The meta-analysis examined whether the characteristics of epoetin administration (dosing regimen, treatment duration, and dose range) have an effect on the estimate of the summary odds ratio for transfusion. Only epoetin dose appeared to have an independent effect on transfusion outcomes, but this was potentially confounded by study quality. However, the results of two randomized controlled trials that directly compared lower and higher doses of epoetin (450 vs. 900 units/kg per week) did not demonstrate that the higher dose was superior.

Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment? Are there laboratory measurements that can either predict or permit early identification of patients whose anemia is likely to respond to epoetin?

- Three small studies demonstrated that epoetin reduces the percentage of pediatric patients requiring transfusion. Although no studies reported outcomes stratified specifically for geriatric patients, adults up to age 90 were included in some trials and no trials noted marked differences in outcomes based on age.
- There is evidence that epoetin produces hematologic responses and probably reduces transfusions in patients with nonmyeloid hematologic malignancies to a similar degree as in patients with tumors of solid organs or tissues. The limited evidence available does not identify any obvious or systematic variation among tumors of different solid organs or tissues with respect to the effects of epoetin on hematologic responses or transfusion use.
- Evidence from a few small trials suggests that epoetin treatment can reduce transfusions even when iron supplementation is not used. However, the limited duration of these studies leaves open the possibility that responses to epoetin may gradually decline when it is used for more extended periods in patients with inadequate iron intake.
- Three studies showed that epoetin increases Hb levels for patients managed with radiotherapy alone. However, mean Hb levels of control patients did not decrease from baseline values over the course of these trials. The radiotherapy regimens utilized apparently did not contribute to or exacerbate preexisting mild anemia.
- The evidence demonstrates benefit from epoetin for patients receiving chemotherapy regimens that include either cisplatin or carboplatin, as well as regimens that do not include either of the platinum drugs.
- No significant predictors of response to epoetin therapy were reported. In particular, neither baseline serum erythropoietin nor the ratio of observed to predicted serum erythropoietin levels predicted response in any analysis.

What are the incidence and severity of adverse effects associated with the use of epoetin and how do these compare with the adverse affects of transfusion?

- Limited evidence on adverse events is available from the studies included in this review, but the frequencies of those reported do not appear to differ markedly between epoetin-treated patients and controls. The only statistically significant difference was a greater frequency of fatigue reported by patients in the control arms. There were more patients reporting at least one adverse event, and more withdrawals because of adverse events, among those treated with epoetin. However, these differences were not statistically significant.