# Introduction

## Scope and Objectives

Erythropoietin is an endogenous hormone, produced primarily in the kidney, which participates in regulating production of red blood cells (erythropoiesis). Two forms of recombinant human erythropoietin, which were given the generic names "epoetin alfa" and "epoetin beta" by the United States Adopted Names Council, were developed in the 1980s as treatments for anemia. The two epoetins replicate the protein sequence and biologic activity of the endogenous hormone and increase the number of red blood cells (RBCs), and thus the blood concentration of hemoglobin (Hb), when given to individuals with functioning erythropoiesis. Indeed, when epoetin is used inappropriately in individuals with normal erythropoiesis (e.g., as a form of "blood doping" by competitive athletes), the red blood cell (RBC) count can rise to a level that is life-threatening (Adamson and Vapnek, 1991; Catlin and Hatton, 1991; Smith and Perry, 1992). The initial clinical use of epoetin was to treat anemia associated with chronic renal failure, especially patients on dialysis (i.e., end-stage renal disease [ESRD]).

Anemia is a deficiency in the concentration of RBCs (also termed "erythrocytes") or Hb that occurs when the equilibrium between red cell loss and production is disturbed. Anemia is relatively common in patients with either hematologic or solid tissue malignancies. It may be caused by effects of treatment, the underlying disease, or both on production of or responses to erythropoietin, or by other mechanisms. Anemia caused by occult bleeding, hemolysis, marrow replacement, or a nutritional deficiency is unlikely to respond to epoetin treatment but may be corrected through the use of other therapies. When cancer treatment or the disease itself decreases production of endogenous erythropoietin, epoetin treatment is likely to correct the resulting anemia. Anemia can also be caused by impaired erythropoietic responses to the endogenous hormone, which may be resolved when the recombinant product is used to augment the patient's baseline erythropoietin concentration.

The severity of anemia can range from mild to life-threatening. The National Cancer Institute (NCI) and Cooperative Oncology Groups use a grading system for anemia. Within normal limits (WNL), (Hb) values are 12.0 to 16.0 g/dL for women and 14.0 to 18.0 g/dL for men. There are four grades of anemia, indicating increasing severity: Grade 1, mild (10.0 to <WNL); Grade 2, moderate (8.0 to 10.0); Grade 3, serious/severe (6.5 to 7.9); Grade 4, life-threatening (<6.5). A recent review by Groopman and Itri (1999) cataloged the incidence of anemia of Grades 1 and 2 and 3 and 4 for various malignancies and treatment regimens and found substantial variation (e.g., from 10 to 80 percent in studies of advanced colorectal, breast, or ovarian cancer).

Data are unavailable to correlate the frequencies for specific symptoms with Hb levels in cancer patients. However, the spectrum of symptoms associated with mild compared with severe anemia has been described. Mild anemia is often asymptomatic or may manifest tachycardia, palpitations, and dyspnea on exertion, and mild fatigue. Severe anemia is characterized by palpitations and dyspnea at rest, severe fatigue, and exercise intolerance; other signs and symptoms include cardiac enlargement and impaired cognition.

Red blood cell transfusion has long been the primary treatment of severe or life-threatening anemia. But transfusion is used cautiously in the treatment of moderate and mild anemia because of the risks associated with exposure to allogeneic blood products and concern to conserve the blood supply. With the availability of epoetin, not only can severe anemia be prevented, but there is also the opportunity to treat or prevent mild anemia. However, epoetin is not useful for the acute treatment of severe or life-threatening anemia because adequate hematologic response does not occur until 4 or more weeks of treatment have elapsed. Nor is epoetin effective for anemias that result from mechanisms other than decreased production or responsiveness to endogenous erythropoietin. Moreover, some individuals in whom other causes of anemia have been ruled out may fail to respond to epoetin.

The biologic effects of erythropoietin on red blood cell production, and the consequences for correction of some anemias by epoetin, are generally well understood. The focus of this systematic review is on the clinical outcomes of using epoetin to prevent or correct mild to moderate anemia related to cancer and its treatment. Outcomes of interest include preventing exposure to allogeneic blood (transfusion), reducing the number of red blood cell units transfused, improving symptoms of anemia (e.g., fatigue, dyspnea, sleeplessness, impaired concentration), reducing hospitalization, improving quality of life (measured by validated instruments), and lessening the incidence of adverse events (e.g., hypertension). This systematic review is limited to controlled trials that compare outcomes of managing anemia with and without the use of epoetin. In these trials, epoetin administration (with transfusion used as necessary) was always compared with transfusion alone. There were no trials that compared epoetin with any other alternative.

In addition, where available, this systematic review sought evidence on the outcomes of epoetin in various patient populations (e.g., pediatric, geriatric), predictors of response to epoetin, and the effect of the characteristics of the epoetin intervention (e.g., dose) on outcome. We also sought to compare the costs of epoetin with those for transfusion alone, but no controlled trials reported such data. As a result, our review of evidence on cost is limited to a discussion of secondary cost analyses summarized in the introductory section of this evidence report.

Four groups of patients with malignancy are included in this systematic review: (1) patients with anemia or at risk of anemia due primarily to cancer therapy; (2) patients with anemia due primarily to their malignant disease and who may also be receiving cancer therapy; and patients who are anemic as a result of bone marrow ablation prior to (3) allogeneic or (4) autologous stem-cell transplantation. This systematic review does not address use of epoetin to reduce the need for transfusion or to facilitate collection of autologous blood in patients undergoing surgery for cancer. Below are the specific objectives and key questions for each of these groups.

### Anemia Primarily Due to Cancer Therapy and Anemia Due to Malignant Disease

The first group of patients are those being treated for malignancy with chemotherapy, radiation, or chemotherapy and radiation. The second group of patients comprises those who would be anemic whether or not they were receiving treatment for their malignancy. All patients in these studies had nonmyeloid hematologic malignancies (multiple myeloma, non-Hodgkin's lymphoma, chronic lymphocytic leukemia) or myelodysplastic syndrome (MDS).

#### Objectives

For the two groups of patients above, this systematic review compares the outcomes of the following alternatives for managing anemia:

1. Initiating epoetin when the level of hemoglobin decreases to a specified threshold:
  - Hb >12 g/dL
  - Hb >10 and <12 g/dL
  - Hb <10 g/dL or requiring blood transfusions.
2. Managing anemia without epoetin, using transfusion (usually initiated when hemoglobin decreases to a threshold between 7 and 9 g/dL).
3. Initiating prophylactic epoetin treatment concurrent with cancer therapy even if hemoglobin levels are above the anemic range. (Note that this alternative is not applicable to patients with anemia resulting primarily from malignancy, who are by definition already anemic and who may not be undergoing cancer therapy.)

#### Key Questions

1. What are the outcomes of managing anemia with epoetin compared with transfusion alone? What are the relative effects of epoetin treatment when different hemoglobin thresholds are used to initiate treatment?
2. In the studies included in this review, does varying the characteristics of the administration of epoetin affect the outcomes of treatment, particularly correction of anemia? The characteristics of epoetin administration are dose, route, regimen type (fixed, increasing, or decreasing dose) and treatment duration. Are the characteristics of epoetin administration likely to confound the interpretation of the evidence on the relative effects of epoetin treatment when different hemoglobin thresholds are used to initiate epoetin treatment?
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment? Are there laboratory measurements that can either predict or permit early identification of patients whose anemia is likely to respond to epoetin?
4. What are the incidence and severity of adverse effects associated with the use of epoetin and how do these compare with the adverse effects of transfusion?

### Anemia Resulting from Bone Marrow Ablation Prior to Stem-Cell Transplantation (Allogeneic or Autologous)

Virtually all patients undergoing stem-cell transplantation require red blood cell transfusion, but epoetin may reduce the duration of anemia or the number of units transfused. Allogeneic and autologous stem-cell transplantation are reviewed separately.

#### Objectives

In patients being treated for a malignancy with bone marrow ablation and stem-cell support, this systematic review compares the outcomes of the following two alternatives for managing anemia:

1. Managing anemia after bone marrow ablation with transfusion initiated at a predefined Hb threshold (usually 7 to 10 g/dL) supplemented with epoetin treatment, beginning at the time of stem-cell infusion and continuing for a period of 4 to 8 weeks.
2. Managing anemia after bone marrow ablation with transfusion initiated at a predefined Hb threshold.

#### Key Questions

1. Does managing anemia after high-dose chemotherapy and stem-cell support using epoetin (with RBC transfusion support initiated at a predefined Hb threshold) improve outcomes compared with managing anemia with RBC transfusion alone?
2. Are any characteristics of epoetin administration associated with superior outcomes? The characteristics of epoetin administration are dose, route, regimen type, and treatment duration?
3. Are there populations or subgroups of patients that are more or less likely to benefit from epoetin treatment?
4. What are the incidence and severity of adverse effects associated with the use of epoetin, and how do these compare with the adverse effects of transfusion alone?

## Prevalence and Severity of Anemia in Cancer Patients^1^ 1 Most citations for well-established points in this background chapter are to relatively recent reviews, rather than to the original publications. Interested readers are referred to the cited reviews to identify the original sources for these observations.

### Disruption of Hematopoiesis in Anemia

Anemia is a deficiency in the concentration of RBCs (also termed "erythrocytes") or Hb that occurs when the equilibrium between red cell loss and production is disturbed. The principal function of erythrocytes is to transport oxygen (bound to Hb) from the lungs, where the oxygen tension is high, to the organs and tissues, where it is low (Bunn, 1994a; Spivak, 1994). Thus, the adequacy of tissue oxygenation depends on sufficiency of the red cell mass. RBCs also transport carbon dioxide from the tissues back to the lungs so that it can be eliminated. When excess blood loss, decreased red cell survival (hemolysis), or decreased red cell production disrupts the normal equilibrium between RBC loss and production, anemia and tissue hypoxia result.

Normal hematopoiesis is regulated by erythropoietin, a glycoprotein hormone produced primarily in the kidney in adults; the other site of production, the liver, is the major production site in the fetus (Faulds and Sorkin, 1989). In a dose-dependent manner, erythropoietin stimulates the proliferation of committed erythroid progenitor cells (burst-forming and colony-forming units-erythroid [BFU-E and CFU-E]), maintains cell viability during erythroid differentiation, and thus participates in regulating development of mature erythrocytes (Bunn, 1994a; Faulds and Sorkin, 1989). The usual baseline concentration of endogenous serum erythropoietin in individuals with a normal hematocrit is approximately 4 to 30 mU/mL, depending on altitude (McEvoy, 1999; Spivak, 1994). Hypoxia, or decreased oxygen tension in the blood, is the stimulus for increased erythropoietin production and release (Bosi, Vannucchi, Grossi, et al., 1991). Most patients who are anemic will demonstrate a surge of erythropoietin production in response to the severity of the anemia (Bosi, Vannucchi, Grossi, et al., 1991). In patients with hypoxia, severe anemia from blood loss, or aplastic anemia, the erythropoietin concentration can increase up to 1,000 times greater than baseline (McEvoy, 1999).

Anemia is a common condition, with an incidence of 1.5 percent in the general population (Denton, Diamond, Matloff, et al., 1994). Some disorders that produce anemia, such as nutritional deficiency states and premenopausal menorrhagia, are uncomplicated and correctable with iron replacement. Other causes of anemia, including renal dysfunction, hyperviscosity, inflammation, sequestration, infection, neoplasia, and chemotherapy for cancer, may be associated with decreased erythropoietin production (Moliterno and Spivak, 1996).

### Anemia in Cancer Patients

The NCI estimates that approximately 8.2 million Americans alive today have a history of cancer (American Cancer Society. 1999). Some of these individuals can be considered cured, whereas others still have evidence of cancer and may be undergoing treatments. About 1,221,800 new cancer cases are expected in the United States in 1999 (Landis, Murray, Bolden, et al., 1999).

The prevalence and severity of anemia in cancer patients depend on the extent of malignant disease and the intensity of the patient's treatment. As summarized in Table 1, the World Health Organization (WHO) and the NCI and its Cooperative Oncology Groups have developed systems for grading the severity of anemia based on hemoglobin values. Within normal limits, Hb values are 12.0 to 16.0 g/dL for women and 14.0 to 18.0 g/dL for men. The NCI grades are: Grade 1, mild (10.0 to <WNL); Grade 2, moderate (8.0 to 10.0); Grade 3, serious/severe (6.5 to 7.9); Grade 4, life-threatening (<6.5). Patients with serious or life-threatening anemia generally require RBC transfusion.

Table 1. Grading systems for anemia

| Toxicity grading system, g/dL hemoglobin
Severity | WHO | NCI and cooperative oncology groups ^1^
Grade 0 (WNL) ^2^ | >11.0 | WNL
Grade 1 (mild) | 9.5-10.9 | 10.0-WNL
Grade 2 (moderate) | 8.0-9.4 | 8.0-10.0
Grade 3 (serious/severe) | 6.5-7.9 | 6.5-7.9
Grade 4 (life-threatening) | <6.5 | <6.5

1 Cooperative oncology groups: Eastern Cooperative Oncology Group; Southwest Oncology Group; Cancer and Leukemia Group B; Gynecologic Oncology Group.

2 WNL hemoglobin values are 12.0-16.0 g/dL for women and 14.0-18.0 for men.

Adapted from Groopman and Itri, 1999.

A recent literature review catalogued the incidence and severity of anemia in patients by type of malignancy, with information on chemotherapy treatments and regimens (Groopman and Itri, 1999). The incidence of Grade 3 or 4 anemia varied considerably. For example, the range was 10 to 80 percent in studies of patients with advanced colorectal, breast, or ovarian cancer. Overall, Grade 1 or 2 anemia was much more common than Grade 3 or 4. Another recent report found that, in ptients with nonmyeloid malignancies receiving cytotoxic chemotherapy, those with lymphomas, lung tumors, and ovarian or genitourinary tumors experienced the highest incidence (50 to 60 percent) of Grade 3 or 4 anemia (Ludwig and Fritz, 1998b). Patients treated with nephrotoxic agents such as cisplatin may be susceptible to anemia as a consequence of reduced endogenous production of erythropoietin (Wood and Hrushesky, 1995).

Anemia, regardless of its underlying cause, reduces the oxygen-carrying capacity of the blood (Armitage, 1998; Koeller, 1998; Lee, 1999a, 1999b; Ludwig and Fritz, 1998a; Moliterno and Spivak, 1996). Physiologic adaptive mechanisms such as changes in heart and respiration rates, cardiac output, venous return, peripheral resistance, and oxygen affinity of hemoglobin in the tissues generally compensate for anemia of milder severity and prevent the development of most symptoms. Whether the onset of anemia is gradual or rapid is likely to affect the ability of these adaptive mechanisms to compensate for the decline in Hb and to prevent development of symptoms.

Table 2 lists symptoms of anemia in cancer patients. However, there are no data to estimate the frequency of these symptoms as a function of Hb level or red cell counts in patients with malignancy. Patients with mild anemia are often asymptomatic. As the severity of anemia and the degree of hypoxia increase, adaptive mechanisms are progressively less able to compensate and signs and symptoms appear more frequently. Patients with Grade 3+ anemia or who are symptomatic are usually treated with RBC transfusions, which prevents or rapidly relieves the symptoms.

Table 2. Signs and symptoms of anemia in cancer patients

Body System | Mild Anemia | Severe Anemia
Cardiovascular | Tachycardia Palpitations on exertion | Tachycardia Palpitations at rest Cardiac enlargement Systolic ejection murmur
Pulmonary | Dyspnea on exertion | Dyspnea at rest
Central nervous system | | Dizziness and vertigo Headaches Irritability Impaired cognition Difficulty sleeping Difficulty concentrating
Gastrointestinal | | Anorexia Nausea Indigestion
Genitourinary | | Menstrual problems Male impotence Loss of libido
Skin | | Pallor Low skin temperature
General | Mild fatigue | Severe fatigue Exercise intolerance

Adapted from Ludwig and Fritz, 1998b; Koeller 1998.

### Differential Diagnosis and Treatment of Anemia in Cancer Patients

Anemia in cancer patients can be caused by the underlying disease, its treatment, or causes unrelated to the malignancy. Treatment of anemia requires a thorough differential diagnosis of the underlying cause or causes (Armitage, 1998). An evaluation may include some or all of the following measurements: Hb and hematocrit levels; RBC indices; reticulocyte counts; iron indices, including serum iron level, total iron-binding capacity (TIBC), percent transferrin saturation (TSAT), and serum ferritin; Coomb's test; vitamin B_12_ and folate concentrations; and a test for occult blood in stool. Blood smears also can reveal characteristic profiles of various anemias associated with malignancy.

### Mechanisms and Classification of Anemia

Different types of anemia exhibit characteristic changes in size and hemoglobin content of erythrocytes (Lee, 1999a). The initial classification into macrocytic, microcytic, and normocytic anemias is based on erythrocyte indices such as mean corpuscular volume (MCV). Additional indices such as mean corpuscular hemoglobin (MCH) and mean corpuscular hemoglobin concentration (MCHC) may be less useful, although readily available with most automated cell counters. Erythropoietic response and reticulocyte count can be useful to indicate whether the underlying disorder affects the bone marrow.

Loss of RBCs by internal hemorrhage often occurs in advanced stages of certain solid tumors (e.g., colorectal carcinoma or other gastrointestinal malignancies; some genitourinary tumors), and if undetected, almost always causes iron deficiency (Armitage, 1998; Bunn, 1994b; Lee, 1999a, 1999b, 1999c). Chronic blood loss is typically accompanied by a decrease in the size of RBCs (microcytic anemia, detectable by decreases in MCV) and in their hemoglobin content (hypochromic anemia, detectable by decreases in MCH). Iron deficiency in cancer patients can be unrelated to malignancy, for example, chronic bleeding resulting from peptic ulcer or menorrhagia or inadequate iron intake.

Two other causes of anemia, acute blood loss and hemolysis, are usually accompanied by an elevated number of reticulocytes (reticulocytosis) and little if any change in the size of RBCs (normocytic anemia). Hemolytic anemia in patients with malignancies may occur by either autoimmune or microangiopathic mechanisms (Armitage, 1998; Beguin, 1996; Frenkel, Bick, and Rutherford, 1996; Moliterno and Spivak, 1996; Rosse and Bunn, 1994). Autoimmune hemolytic anemia is relatively uncommon in cancer patients but occurs most often in those with chronic lymphocytic leukemia (CLL) or lymphoma, possibly as an adverse effect of fludarabine treatment. Microangiopathic hemolytic anemia (also referred to as thrombotic microangiopathy), which involves intravascular hemolysis caused by red cell fragmentation, is rarely caused by malignancy, except occasionally in patients with widely disseminated metastases (Foerster, 1999).

In cancer patients, several conditions can result in a normocytic anemia without reticulocytosis (Armitage, 1998; Beguin, 1996; Moliterno and Spivak, 1996). One example is overgrowth of the marrow with malignant cells; this occurs most often in leukemia, but also is possible in multiple myeloma, lymphoma, and prostate, breast, and small cell lung cancer (Abels, 1992; Frenkel, Bick, and Rutherford, 1996; Rappeport and Bunn, 1994). Myelofibrosis and other nonmalignant processes that replace the normal complement of marrow cells also are possible causes of normocytic anemia without reticulocytosis. Another cause is drug- or radiation-induced aplastic anemia, often associated with alkylating agents. Bone marrow biopsy may be necessary to determine the cause of normocytic anemia without reticulocytosis.

Anemia that results in larger than normal RBCs (macrocytic anemia) can occur as a result of nutritional deficiency or inadequate absorption of vitamin B_12_ and/or folate, after treatment with certain antimetabolites used in cancer (e.g., methotrexate, mercaptopurine, cytosine arabinoside) or viral diseases (e.g., zidovudine), and in patients who drink alcohol (Abels, 1992; Armitage, 1998; Bunn, 1994b; Lee, 1999b; Moliterno and Spivak, 1996). In these instances, the anemia is termed "megaloblastic," is a consequence of impaired DNA synthesis, and results in the presence of cells (megaloblasts) with characteristic alterations of chromatin. Macrocytic anemia also may occur without the appearance of megaloblasts and without impaired DNA synthesis. Examples of such macrocytic anemias include those resulting from myelodysplastic syndromes and some hepatic diseases and in patients who have undergone splenectomy.

### Anemia Due to Chronic Disease

Patients with malignant diseases, as well as those with many infectious and inflammatory diseases and in some instances those with trauma, may have "anemia of chronic disease" (Abels, 1992; Armitage, 1998; Beguin, 1996; Bunn, 1994b; Frenkel, Bick, and Rutherford, 1996; Henry 1996; Koeller, 1998; Means, 1999; Moliterno and Spivak, 1996). Anemia due to chronic disease may occur as either a microcytic or normocytic anemia and may be accompanied by a normal or reduced number of reticulocytes. The serum concentration of iron, total iron binding capacity, and transferrin saturation are generally decreased, whereas serum ferritin and bone marrow iron stores are normal or increased. The RBC life span is shortened. Elevated production of cytokines (possibly including interleukin-1 and interleukin-6 [IL-6], tumor necrosis factor, and interferons beta and gamma) that inhibit erythropoiesis and reduce endogenous production of erythropoietin may play a role in the etiology of anemia of chronic disease. Serum erythropoietin levels are lower than expected for the degree of anemia when compared with those measured in iron-deficient patients with an equivalent severity of anemia (Miller, Jones, Piantadosi, et al., 1990). This observation provides a rationale for use of erythropoietin to treat the anemia of chronic disease.

The myelodysplastic syndromes (MDSs) are clonal disorders of hematopoiesis characterized by cytopenias and dysfunctional blood cells (Lowenthal and Marsden, 1997). MDS may be associated with severe neutropenia, transfusion-dependent anemia, and, less commonly, transformation to acute leukemia (Stein, Abels, and Krantz, 1991). The French, American, British (FAB) classification of myelodysplastic syndromes includes five categories of anemias: refractory anemia (RA), refractory anemia with ringed sideroblasts (RARS), refractory anemia with excess of blasts (RAEB), refractory anemia with excess of blasts in transformation (RAEB-T), and chronic myelomonocytic leukemia (CMML) (Rappeport and Bunn, 1994). MDS patients do not in general have a deficiency of erythropoietin but do have an inappropriately low endogenous erythropoietic response to their anemia, consistent with anemia of chronic disease (Stein, Abels, and Krantz, 1991).

### Anemia Due to Cancer Treatment

Patients with malignant diseases may experience a direct toxic effect of treatment on either the bone marrow stem-cell compartment or on the renal cells that produce erythropoietin (Abels, 1992; Armitage, 1998; Beguin, 1996; Moliterno and Spivak, 1996). In a dose-dependent manner, radiation and many chemotherapeutic agents may reduce the pool of stem cells, induce temporary or permanent damage to their capacity to proliferate and/or differentiate, or both. Although treatment-induced neutropenia and/or thrombocytopenia are more common and usually more severe than anemia, anemia severe enough to warrant transfusion also occurs (Aledort and Mohandas, 1996).

## Differential Diagnosis Determines Treatment

Treatment of anemia in cancer patients is based on the underlying cause of the anemia. Patients with anemia due to acute blood loss are infused with crystalloid solutions if their hypovolemia requires treatment, they have not lost more than 20 percent of blood volume, and the diagnostic workup shows no problems with erythropoiesis (Schroeder, 1999). Anemia caused by a nutritional deficiency (e.g., vitamin B_12_ or folate) is usually easily corrected by supplementation.

Adequate iron stores or adequate iron supplementation is required for effective hematopoiesis; when patients are iron deficient, hemoglobin synthesis, and therefore erythrocyte production, slows (Faulds and Sorkin, 1989; Lee, 1999c). Once patients with iron-deficiency anemia replenish iron stores, either though dietary means (e.g., increased intake of iron-rich foods) or iron supplementation (e.g., oral ferrous sulfate or ferrous gluconate), effective erythropoiesis can resume. Rarely, patients may not tolerate oral iron or there may be inadequate absorption. In these instances, iron-dextran complex may be administered intravenously.

Effective treatment of the malignant disease itself will eventually correct the anemia when it is caused by autoimmune hemolysis (associated with chronic lymphocytic leukemia or lymphoma), microangiopathy from widely disseminated metastases, marrow replacement with malignant cells, a myelodysplastic syndrome, or the anemia of chronic disease. Similarly, toxic effects of chemotherapy and radiation on the bone marrow stem cells usually resolve spontaneously with time. Since cancer therapy often is an extended process, for some patients it may be useful or necessary to utilize supplementary treatments that increase RBC counts more rapidly.

## Red Blood Cell Transfusion and Epoetin in Anemia Treatment

This systematic review compares outcomes of managing mild to moderate anemia with and without the use of epoetin; epoetin (with transfusion used as necessary) is compared with transfusion alone. Red blood cell transfusion has long been the usual treatment of severe or life-threatening anemia. But transfusion is used cautiously in the treatment of moderate and mild anemia because of the risks associated with exposure to allogeneic blood and concern to conserve the blood supply. With the availability of epoetin, not only can severe anemia be prevented, but there is also the opportunity to treat or prevent mild anemia. However, the availability of epoetin cannot completely eliminate the need for RBC transfusion to treat anemia. The time from epoetin administration to hematologic response is too long when anemia is life-threatening or severe; some anemias are unrelated impairment of endogenous erythropoietin production and utilization, and some individuals may fail to respond to epoetin for reasons that are unknown.

This section describes the two interventions that are compared in this evidence report. We also briefly summarize published evidence-based guidelines that address the use of RBC transfusions or epoetin.

### Red Blood Cell Transfusion

Red blood cell transfusion is the usual treatment for patients with anemia accompanied by clinically significant symptoms. It is also the most rapid means of raising the RBC count and is invariably effective in the absence of continued bleeding or ongoing hemolysis. Although the frequencies of adverse effects from RBC transfusions are small, they can be serious or life-threatening (Aledort and Mohandas, 1996; Ludwig and Fritz, 1998a; Schroeder, 1999; Valeri, Crowley, and Loscalzo, 1998;). The risks include hemolytic transfusion reactions, nonhemolytic febrile transfusion reactions, iron overload, hypervolemia, transmission of viral or (less often) bacterial infectious diseases, transfusion-related graft-versus-host disease (GVHD), transfusion-related acute lung injury, and immunosuppression. Recent estimates of the frequency for these and other adverse effects of RBC transfusion range from as much as 0.5 percent to 1 percent for circulatory overload or nonhemolytic febrile transfusion reactions to as little as 1 in 1,000,000 for bacterial contamination or 1 in 450,000 to 660,000 for transmission of HIV-1 (Simon, Alverson, AuBuchon, et al., 1998).

#### Guidelines for RBC Transfusion

Several medical specialty societies and other professional organizations have developed clinical guidelines, standards, or practice parameters regarding transfusion of RBCs and other blood components. Standards developed by the American Association of Blood Banks (AABB) either alone (American Association of Blood Banks. 1999) or in partnership with America's Blood Centers and the American Red Cross (American Association of Blood Banks, America's Blood Centers, American Red Cross, 1998) focus on collection, processing, storage, and release of blood and blood components for use in transfusions. However, they do not address indications for RBC transfusion in patients with either acute or persistent anemia. A guideline by the American Society of Anesthesiologists (American Society of Anesthesiologists Task Force on Blood Component Therapy, 1996) focused solely on the perioperative and peripartum use of blood component therapy, clinical settings that are outside the scope of the present systematic review.

A clinical guideline on elective RBC transfusion by the American College of Physicians (1992) as part of its Clinical Efficacy Assessment Project recommends the following:

- Empiric, automatic transfusion thresholds should be avoided;
- RBCs should be administered on a unit-by-unit basis to relieve specific symptoms with reassessment after each unit is given; and
- RBCs should not be given to patients with persistent anemia (regardless of Hb level) in the absence of one or more of the following symptoms: syncope, dyspnea, tachycardia, angina, postural hypotension, and/or transient ischemic attack.

A more recent practice guideline by the College of American Pathologists (Simon, Alverson, AuBuchon, et al., 1998) makes similar recommendations. This document stresses that nearly all patients require RBC transfusion if the Hb level falls below 6 g/dL and that almost no patient does if the Hb level is above 10 g/dL. When the Hb level is between 6 and 10 g/dL, individual patient factors such as the extent of blood loss, underlying cardiac disease, and overall clinical status should be used to decide if RBC transfusion is needed. In addition, for patients with chronic anemia, RBCs should only be given to treat or minimize symptoms and after pharmacologic agents (e.g., iron, B_12_, folate, or epoetin) that may be indicated by the patient's specific diagnosis have failed to correct the anemia.

### Epoetin

Recombinant human erythropoietin or "epoetin" was developed in the 1980s, after the human gene responsible for its production was cloned and expressed in vitro (Jacobs, Shoemaker, and Rudersdorf, 1985; Lin, Suggs, Lin, et al., 1985). The 165-amino acid mature recombinant protein is identical to the endogenous hormone with respect to its peptide sequence, and it has identical biologic activity (Amgen, Inc., 1999; Faulds and Sorkin, 1989; Ortho Biotech, Inc., 1999).

The recombinant epoetin has been produced in two forms: alfa and beta (Halstenson, Macres, Katz, et al., 1991). Each differs from the other and from the endogenous form principally in the nature and composition of the carbohydrate chains attached to the peptide (McEvoy, 1999). The two recombinant forms may differ in their pharmacokinetic properties (Halstenson, Macres, Katz, et al., 1991). However, only the alfa form has been approved for marketing in the United States by the U.S. Food and Drug Administration (FDA) (McEvoy, 1999).

Epoetin cannot be administered orally; it is administered either by subcutaneous (sc) or intravenous (iv) injection (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). In most studies on patients with malignancies, the drug has been administered as an iv bolus three times weekly. The drug also has been administered parenterally via other routes convenient to the clinical situation (e.g., via central lines used for infusion of chemotherapy). Also, the drug may be self-administered by the patient (Amgen, Inc., 1999; Ortho-Biotech, Inc., 1999).

Trials in patients with end-stage renal disease provide evidence that the drug is cleared more rapidly after intravenous than after subcutaneous administration (Albitar, Meulders, Hammoud, et al., 1995; Besarab, Flaherty, Erslev, et al., 1992; Canaud, Bennhold, Delons, et al., 1995; Kaufmann and Reda, 1996; Paganini, Eschbach, Lazarus, et al., 1995; Virot, Janin, Guillaumie, et al., 1996). Slower clearance suggests a longer duration of exposure to biologically effective concentrations at a given dose when the drug is administered subcutaneously rather than intravenously.

For cancer patients undergoing chemotherapy, the FDA-approved labeling states that the recommended starting dose is 150 U/kg sc three times weekly (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). If the hematocrit exceeds 40 percent (Hb >13.4 g/dL), the drug should be withheld until the hematocrit falls to 36 percent (Hb <13); the drug dose should be decreased by 25 percent when therapy is resumed (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). If the initial drug dose induces a very rapid response (e.g., an increase of four or more points in any 2-week period), the dose should be reduced. If hematocrit response is not satisfactory after 8 weeks, the dose can be increased up to 300 U/kg three times weekly (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). If patients fail to respond to 300 U/kg three times weekly, it is unlikely that they will respond to higher doses (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999).

Epoetin alfa is FDA-approved in the United States and marketed under the trade names Epogen^®^ (Amgen, Inc., Thousand Oaks, CA) and Procrit^®^ (Ortho Biotech, Inc., Raritan, NJ). Both trade products are derived from the same source and are identical in composition (McEvoy, 1999).

Epoetin alfa has been FDA-approved for four uses (Table 3):

- The treatment of anemia associated with chronic renal failure (including patients on dialysis [end-stage renal disease] and patients not on dialysis).
- The treatment of anemia related to therapy with zidovudine in HIV-infected patients.
- The treatment of anemia in patients with nonmyeloid malignancies where anemia is a result of the effect of concomitantly administered chemotherapy.
- The treatment of anemic patients (Hb >10 to <13 g/dL) scheduled to undergo elective, noncardiac, nonvascular surgery to reduce the need for allogeneic blood transfusions and of patients at high risk for perioperative transfusions with significant, anticipated blood loss (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999).

Table 3. FDA-approved uses of epoetin alfa and dosing recommendations^1^

FDA-Approved Labeling | Starting Dose | Adjustment ^2^ | Comment
"Indicated in the treatment of anemia associated with chronic renal failure, including patients on dialysis (end-stage renal disease) and patients not on dialysis" | 50-100 U/kg 3 times weekly (iv or sc) | Reduce dose if: Hct approaches 36% or Hct increases >4 points in any 2-week period. Increase dose if: Hct does not increase by 5-6 points after 8 weeks of therapy and Hct is below the suggested range. | - Predialysis patients with symptomatic anemia considered for therapy should have a hematocrit less than 30%.; - Transferrin saturation should be at least 20% and ferritin should be at least 100 ng/mL.; - Hct should be monitored twice weekly until it has stabilized in the target range and the maintenance dose has been established.; - Suggested target hematocrit range: 30-36%; however, the labeling states that "at the physician's discretion, the suggested target hematocrit range may be expanded to achieve maximal patient benefit."
"Indicated for the treatment of anemia related to therapy with zidovudine in HIV-infected patients" | 100 U/kg 3 times weekly (iv or sc) for 8 weeks | After attainment of the desired response (i.e., reduced transfusion requirements or increased Hct), the dose should be titrated to maintain the response based on factors such as the change in zidovudine dosage, and the presence of intercurrent infections or inflammatory episodes. If the Hct exceeds 40%, the dose should be discontinued until the Hct drops to 36%. The dose should be reduced by 25% when the treatment is resumed and then titrated to maintain the desired Hct. | - Endogenous serum erythropoietin concentration should be <500 mU/mL.; - Weekly total zidovudine dose should be <4.2 g; - Hct should be monitored once weekly until it has stabilized in the target range and then measured periodically thereafter.
"Indicated in the treatment of anemia in patients with non-myeloid malignancies where anemia is due to the effect of concomitantly administered chemotherapy. | 150 U/kg sc 3 times weekly | If Hct exceeds 40%, the drug should be withheld until the Hct falls to 36%; the drug dose should be decreased by 25% when therapy is resumed. If the initial drug dose induces a very rapid response (e.g., an increase of 4 or more points in any 2-week period), the dose should be reduced. If Hct response is not satisfactory after 8 weeks, the dose can be increased up to 300 U/kg 3 times weekly. | - Patients must be receiving the concomitant chemotherapy for a minimum of 2 months.; - Therapy not indicated for the treatment of anemia in cancer patients due to other factors such as iron or folate deficiencies, hemolysis, or GI bleeding; these should be managed appropriately.; - Although no specific serum erythropoietin concentration can be stipulated above which patients would be unlikely to respond, treatment of patients with "grossly elevated" serum concentrations (e.g., >200 mU/mL) is not recommended.; - If patients fail to respond to 300 U/kg 3 times weekly, it is unlikely that they will respond to higher doses.; - Hct should be monitored once weekly until it has stabilized in the target range and then measured periodically thereafter.
"Indicated in the treatment of anemic patients(hemoglobin >10 to <13 g/dL) scheduled to undergo elective, noncardiac, nonvascular surgery to reduce the need for allogeneic blood transfusions… indicated for patients at high risk for perioperative transfusions with significant, anticipated blood loss." | 300 U/kg daily sc for 10 days prior to surgery, the day of surgery, and 4 days after surgery. Also, the drug may be given at a dosage of 600 U/kg sc once weekly at 21, 14, and 7 days before surgery, plus a fourth dose the day of surgery. | N/A | - Not indicated for anemic patients who are willing to donate autologous blood.; - The safety of the perioperative use of the drug has been studied only in patients who are receiving anticoagulant prophylaxis.; - All patients should receive adequate iron supplementation; iron therapy should be initiated no later than the beginning of epoetin treatment and should continue throughout the therapy course.

1 All information from Ortho Biotech and Amgen FDA-approved labeling.

2 Maintenance doses should be titrated to response in all cases.

Amgen, Inc. is licensed to market Epogen® for the treatment of dialysis patients with anemia of ESRD; Ortho Biotech, Inc. is licensed to market Procrit® for the treatment of all other FDA-approved uses, including the treatment of anemia in predialysis patients.

The drug has been used off-label for a variety of other uses, including anemia of prematurity (Faulds and Sorkin, 1989), anemia of chronic disease (e.g., rheumatoid arthritis) (Faulds and Sorkin, 1989; Pincus, Olsen, Russell, et al., 1990; Salvarani, Lasagni, Casali, et al., 1991; Vreugdenhil and Swaak, 1990;), anemia of myelodysplastic syndromes (Adamson, Schuster, Allen, et al., 1992; Ludwig, Fritz, Leitgeib, et al., 1993; Stein, Abels, and Krantz, 1991;), sickle-cell anemia (Faulds and Sorkin, 1989), anemia of multiple myeloma (Ludwig, Fritz, Leitgeib, et al., 1993); and anemia following high-dose chemotherapy with stem-cell support (Henry, 1998).

In patients with chronic renal failure receiving epoetin therapy, the most common adverse effect of the drug is hypertension, occurring in approximately 24 percent of such patients (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). In other patient populations, hypertension occurs rarely (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). Other more serious adverse effects of the drug include hypertensive encephalopathy, seizures, and thrombotic/vascular events (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999); however, these more serious events also appear to occur most often in patients being treated with epoetin for anemia resulting from renal failure (Amgen, Inc., 1999; Markham and Bryson, 1995; Ortho Biotech, Inc., 1999).

Patients receiving epoetin for anemia related to conditions other than chronic renal failure (e.g., zidovudine treatment or other chemotherapy) demonstrate no serious adverse effects directly attributable to drug therapy (Amgen, Inc., 1999; Markham and Bryson, 1995; Ortho Biotech, Inc., 1999). Differences in the severity of adverse effects in different patient populations, or even within populations, may be attributable to differences in the underlying disease states and/or comorbidities, such as the presence of hypertension or cardiac disease (Beguin, 1998b; de Andrade, Frei, and Guilfoyle, 1999). Several large (i.e., study populations of over 2,000 patients), community-based, single-arm studies of epoetin in anemic cancer patients have described no unexpected adverse effects in this population (Demetri, Kris, Wade, et al., 1998; Glaspy, Bukowski, Steinberg, et al., 1997). The most common adverse events noted were fever, decreased white cell count, nausea, vomiting, and asthenia, all occurring in fewer than 10 percent of patients (Demetri, Kris, Wade, et al., 1998; Glaspy, Bukowski, Steinberg, et al., 1997). One study reported disease progression occurring in 23 percent of patients; however, this was not directly attributable to epoetin treatment (Glaspy, Bukowski, Steinberg, et al., 1997). According to one set of investigators, "The incidence and type of adverse events experienced by the patients in this trial do not appear to differ from patients with cancer, appear to be consistent with the underlying disease state and the chemotherapeutic regimens, and are consistent with those observed in the double-blind, placebo-controlled trials" (Demetri, Kris, Wade, et al., 1998).

The FDA-approved product information for epoetin alfa states that the safety and efficacy of the drug have not been established in patients with a known history of a seizure disorder or underlying hematologic condition (e.g., sickle cell anemia, myelodysplastic syndromes, hypercoagulable disorders) (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). Use of epoetin alfa is contraindicated in patients with (1) uncontrolled hypertension, (2) known sensitivity to mammalian cell-derived products, or (3) known hypersensitivity to human albumin (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999).

If patients fail to respond or to maintain a response to epoetin therapy in the recommended dosing range, the following possible causes of delayed or diminished response should be considered: iron deficiency, underlying infectious inflammatory or malignant process, occult blood loss, underlying hematologic diseases, folic acid or vitamin B_12_ deficiency, hemolysis, aluminum intoxication, or osteitis fibrosa cystica (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). Although no specific serum erythropoietin concentration can be stipulated above which patients would be unlikely to respond, treatment of patients with "grossly elevated" serum concentrations (e.g., >200 mU/mL) is not recommended.

During therapy with epoetin alfa, iron stores are quickly mobilized and utilized as erythrocytes are produced. Absolute or functional iron deficiency may develop (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). Functional iron deficiency is defined as insufficient iron to support erythropoiesis despite normal iron stores and is generally characterized by normal or elevated ferritin levels in the presence of low transferrin saturation (serum iron concentration divided by the iron-binding capacity). Functional iron deficiency is presumably caused by the inability of the body to mobilize iron stores rapidly enough to support increased erythropoiesis (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). In patients receiving epoetin therapy, transferrin saturation should be at least 20 percent and ferritin levels should be at least 100 ng/mL (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). Transferrin saturation and ferritin concentrations should be determined prior to and also during therapy (Amgen, Inc., 1999; Ortho Biotech, Inc., 1999). However, both serum ferritin and transferrin saturation have limitations as diagnostic tests for functional iron deficiency, and other tests are being investigated (Glaspy and Cavill, 1999).

Supplemental iron is recommended to achieve and maintain target hematocrit levels in patients with chronic renal failure, and intravenous administration may be necessary (National Kidney Foundation. 1997). Uniform recommendations regarding iron supplementation for cancer patients with anemia do not exist. Not all trials of epoetin therapy in cancer patients have supplemented patients with iron, and those that have generally administered iron orally. Controlled trials are currently underway to evaluate the effect of iv iron on the response of cancer patients to epoetin therapy (Glaspy and Cavill, 1999).

#### Optimizing Therapeutic Efficiency

To maximize the benefit of epoetin while minimizing cost, it will be necessary to determine the relative efficiency of various doses, dosing regimens, and durations of treatment with respect to the total amount of drug consumed to achieve and maintain the Hb target.

Patients may differ in their responsiveness to epoetin and thus in the dose needed to achieve a given increase in or target Hb level. One variable-dose regimen initiates therapy with a minimally effective dose for a specified duration and then increases the dose selectively for patients who have not responded. An alternative initiates therapy with a higher dose that yields hematologic responses in a larger percentage of patients. Either the dose is reduced for those patients who respond, or the drug is discontinued once patients reach a specified Hb level and reinstituted when Hb falls below a specified level.

One set of issues to resolve by means of empirical evidence from clinical trials concerns the relative merits of these different dosing regimens. Is it better to start with a low dose and increase for the nonresponders or to start with a high dose and decrease (or intermittently discontinue treatment) for those who do respond? There is evidence that initial exposure to erythropoietin triggers dormant (G_o_) erythroid progenitor cells into the active portion of the cell cycle (G_1_) and stimulates their proliferation, whereas continued exposure promotes survival and differentiation of the progeny cells (Koury and Bondurant, 1990; Spivak, Pham, and Isaacs, 1991). On the other hand, significant overshoot of the target Hb level may occur because of the length of time required for maturation of end-stage RBCs.

With regard to frequency, recent evidence from a large community-based single-arm study (Gabrilove, Einhorn, Livingston, et al., 1999) suggests that administration of 40,000 units once weekly achieves equivalent changes in Hb levels and hematologic responses as the dose used in two earlier community-based studies, 10,000 units three times weekly (Demetri, Kris, Wade, et al., 1998; Glaspy, Bukowski, Steinberg, et al., 1997). Although the once-weekly regimen is undoubtedly more convenient, it uses 33 percent more drug per patient. Another issue is the role of iron supplementation in maintaining responsiveness to epoetin. Finally, the relationship between the duration of treatment for malignancy, or the natural history of the specific malignant disease, and the duration of the need to manage anemia is not well understood.

#### Predicting Response to Epoetin

The ability to predict which patients will respond to epoetin would help to optimize its use. Predictors of response of interest include both baseline parameters to select patients for epoetin therapy and early indicators of response to determine whether to continue epoetin therapy (for reviews, see Adamson and Ludwig, 1999; Beguin, 1998a; Ludwig and Fritz, 1998a and 1998b;). Phase I and II trials show no correlation with epoetin response for the following factors: age, sex, baseline Hb concentration, white blood cell counts, platelet counts, folate or serum ferritin concentration (Adamson and Ludwig, 1999).

The baseline concentration of endogenous erythropoietin may be a useful predictor of response, particularly when compared with the degree of anemia (for review, see Adamson and Ludwig, 1999; Beguin, 1998a; Ludwig and Fritz, 1998a and 1998b). Some investigators calculate a ratio between the observed and expected concentrations of erythropoietin to predict responses to epoetin. The expected value is derived by comparison with measurements of serum erythropoietin concentrations in iron-deficient patients with an equivalent severity of anemia. This approach is based on the observation that serum erythropoietin levels in cancer patients often are lower than expected for the degree of anemia (Miller, Jones, Piantadosi, et al., 1990). However, both the absolute value and the observed to expected ratio for serum erythropoietin have failed to correlate with responses to epoetin in some studies (for review, see Adamson and Ludwig, 1999; Beguin, 1998a; Ludwig and Fritz, 1998a and 1998b).

Response to epoetin may vary with the type of malignancy. Ludwig and Fritz (1998a and 1998b) reported that the percentage of patients responding was highest for patients with head and neck cancer or myeloma and lowest for those with MDSs or Hodgkin's disease. Others argue that the type or extent of malignancy is important only when extensive marrow involvement limits hematopoiesis or when the malignancy is associated with specific mechanisms of anemia (e.g., hemolysis) that are unlikely to respond to epoetin (Adamson and Ludwig, 1999; Beguin, 1998a).

Laboratory measurements in the first 2 to 4 weeks of therapy may be useful in deciding whether to continue, discontinue, or alter the dose of epoetin treatment. Some guidelines that may be useful as early predictors of response include increases in the concentration of soluble transferrin receptors, Hb, or ferritin and in the number of circulating reticulocytes (for review, see Adamson and Ludwig, 1999; Beguin, 1998a; Ludwig and Fritz, 1998a and 1998b). Several algorithms have been proposed that combine factors to improve the predictive value. Some use a baseline measure such as the serum erythropoietin concentration or its observed to expected ratio, plus an early predictor such as the 2 to 4 week increment in reticulocyte count or transferrin receptor concentration. Other algorithms combine two early predictors. To date, however, adequate data are not available to determine the best approach for predicting responses to epoetin.

#### Guidelines for Epoetin Use

The Systemic Treatment Program Committee of the Ontario Cancer Treatment Practice Guidelines Initiative conducted a systematic review to assess the effectiveness of epoetin therapy for reducing RBC transfusions and for improving quality of life (Quirt, Micucci, Moran, et al., 1997). The analysis selected all randomized controlled trials published between 1985 and 1995 that enrolled patients receiving chemotherapy for nonhematologic cancers. Results from eight trials (n=813) that reported the proportion of patients transfused during followup (with varied study duration) were combined in a pooled analysis using a random effects model. Although data were abstracted on other outcomes, including mean number of RBC units transfused per patient, mean Hb and hematocrit levels at various times after epoetin treatment was initiated, quality of life, and adverse events, the paucity of results reported for these parameters precluded any pooled analyses.

The meta-analysis found that epoetin therapy reduces the proportion of patients transfused, with a risk ratio (RR) of 0.64 (95 percent CI, 0.53 to 0.78; p<0.00001). The benefit was maintained whether all or only placebo-controlled trials (RR, 0.66) were selected. In trials that did not give placebo to control patients, physicians ordering transfusions were not blinded to the patients' treatment. Epoetin administration improved hematocrit and hemoglobin level and reduced transfusion requirements whether administered before (RR, 0.56) or after (RR, 0.66) chemotherapy-induced anemia was diagnosed. The evidence for a benefit from use of epoetin was stronger in platinum-based chemotherapy patients (RR, 0.56; 95 percent CI, 0.42 to 0.75) than in nonplatinum-based chemotherapy patients (RR, 0.73; 95 percent CI, 0.56 to 0.96).

The Systemic Treatment Program Committee of the Ontario Cancer Treatment Practice Guidelines Initiative developed practice guidelines based on the meta-analysis results (Quirt, Micucci, Moran, et al., 1997). Their recommendations are as follows: "For patients receiving chemotherapy for nonhematologic cancer in whom symptoms of anemia are expected and in whom transfusion of RBCs is not considered an acceptable treatment option, epoetin can be recommended as a safe, effective treatment alternative. The evidence in support of using epoetin is stronger for patients receiving platinum-based chemotherapy regimens than for those receiving non-platinum-based regimens." The guidelines addressed neither patients with hematologic cancers nor those on radiation therapy-based protocols.

The guidelines noted the absence of information on quality of life or cost benefit. In addition, the evidence was judged insufficient to determine the optimal timing for beginning epoetin therapy or the baseline patient factors or treatment regimens that might predict response. The Provincial Systemic Treatment Disease Site Group noted their plans to issue updated guidelines based on periodic reviews of new evidence. However, the recommendations of the current guideline remain in effect until a revision is published. Updates will be posted at http://hiru.mcmaster.ca/ccopgi/guidelines/sys/cpg12_1.html.

Koeller (1998) published guidelines for the treatment of cancer-related anemia. However, the published clinical recommendations were not based on a formal systematic review of evidence from all reported clinical trials. The publication that reported this guideline did not describe a process for review of the guideline's recommendations either by a medical specialty society or other expert panel(s).

## Anemia and Quality of Life in Cancer Patients

The availability of epoetin to treat cancer-related anemia has stimulated efforts to describe and measure the impact of anemia on quality of life. Fatigue is a common symptom of cancer and cancer treatment, and anemia is one of various contributors to fatigue in cancer patients. Disease-specific instruments are being developed to measure the effects of fatigue and anemia on quality of life. Instruments that attempt to measure the effects of fatigue and anemia on quality of life were used in two large community-based studies of patients receiving epoetin while undergoing cancer treatment. The results of these uncontrolled studies show an association between increasing Hb levels and increasing quality-of-life scores (Demetri, Kris, Wade, et al., 1998; Glaspy, Bukowski, Steinberg, et al., 1997). However, only controlled trials can support causal inferences about the effects of epoetin treatment on quality of life (Leidy, Revicki, and Geneste, 1999). Other factors (e.g., changes in disease status) may affect both Hb levels and quality of life. In addition, the community studies are subject to limitations resulting from substantial amounts of missing data.

This section reviews recent literature on fatigue and anemia in cancer patients, describes the instruments used to measure quality of life in studies of epoetin, identifies methodologic issues relevant to the assessment of quality of life in cancer clinical trials, and summarizes the results and the limitations of the community-based studies of epoetin treatment.

### Cancer-Related Fatigue

Fatigue is the most frequently reported symptom of cancer and cancer treatment in patient surveys (Portenoy, Thaler, Kornblith, et al., 1994; Vogelzang, Breitbart, Cella, et al., 1997) and is often more distressing to patients than is pain (Nail and Winningham, 1995; Vogelzang, Breitbart, Cella, et al., 1997). Although there is no universally accepted definition, fatigue has been described as "diminished energy, or an increased need to rest that is disproportionate to any recent change in activity" that results in a "sustained deterioration in the usual ability to perform either physical or intellectual activities" (Miaskowski and Portenoy, 1998). Cancer-related fatigue was recently accepted as a diagnosis in the International Classification of Diseases, 10^th^ Revision, Clinical Modification (Portenoy and Itri, 1999).

A recent population-based survey reports that cancer-related fatigue is common and also suggests that oncologists underestimate its impact on patients (Vogelzang, Breitbart, Cella, et al., 1997). Of 419 patients who had undergone either chemotherapy (35 percent), radiotherapy (39 percent), or both (24 percent), 78 percent reported experiencing fatigue during the course of their disease and treatment; and 71 percent reported that fatigue somewhat or significantly (32 percent) had an impact on their daily routine. Although 61 percent of patients reported that their daily lives were more adversely affected by fatigue than by cancer-related pain, only 37 percent of oncologists held this view. Another study (Irvine, Vincent, Graydon, et al., 1994), which compared 101 cancer patients with 53 healthy individuals, reported that the proportion of cancer patients experiencing fatigue increased significantly from 39 percent at baseline to 61 percent with treatment. A recent study comparing cancer inpatients undergoing palliative care with age and sex-matched volunteers reported that 75 percent of the cancer patients experienced fatigue of greater intensity than that experienced by 95 percent of the controls (Stone, Hardy, Broadley, et al., 1999).

In cancer patients, the etiology of fatigue is multifactorial and has both physiologic and psychosocial dimensions (Winningham, Nail, Burke, et al., 1994). Causes include anemia, metabolic disturbances, disease progression, and adverse treatment-related effects. Disease stage and status (remission versus stable versus progressive; localized versus metastatic), type (hematologic versus solid tumor), and particular symptoms can be linked not only to anemia, but also to pain, loss of muscle function, loss of appetite, and fatigue (Langer, 1997; Winningham, Nail, Burke, et al., 1994). In a study of correlates of fatigue in cancer patients receiving chemotherapy or radiotherapy, changes in weight and white blood cell count were significantly correlated with fatigue whereas changes in hematocrit and Hb were not (Irvine, Vincent, Graydon, et al., 1994).

Anemia results in a reduction in the oxygen-carrying capacity of blood. Reduced delivery of oxygen to muscle tissue reduces work capacity and exercise tolerance and may result in perceived weakness. Brain function may also be affected, with possible changes in mood and perception. Activities may be curtailed because of lack of physical and mental energy.

Reduced availability of substrate for energy metabolism, or accumulation of abnormal substances that impair intermediary metabolism, could affect normal physiologic and/or cognitive function, resulting in symptoms of fatigue (Miaskowski and Portenoy, 1998). For example, a hypermetabolic state that can accompany tumor growth may result in increased substrate need for energy metabolism. Nausea and decreased appetite frequently accompany cancer therapy. Inadequate nutrition, as well as poor nutritional uptake, may lead to decreased substrate availability. Cancer cachexia, thought to be related to a change in energy transformation processes, results in weight loss and fatigue.

Abnormally increased production of the cytokine IL-6 has been associated with neoplasms and with tissue injury produced by radiation therapy (Miaskowski and Portenoy, 1998). In clinical trials, exogenous IL-6 has been associated with fatigue (Gordon, Nemunaitis, Hoffman, et al., 1995; Sosman, Aronson, Sznol, et al., 1997; Weber, Yang, Topalian, et al., 1993). Endogenous production of IL-6 can be stimulated by interferon alfa immunotherapy, which is also associated with fatigue (Jones, Wadler, and Hupart, 1998). Evidence suggests that both IL-6 and interferon alpha can affect the function of thyroid cells; thus, endocrine disease may explain some aspects of fatigue experienced by cancer patients (Jones, Wadler, and Hupart, 1998).

Cancer patients undergoing radiation therapy appear to experience a transient decline in neuromuscular efficiency that is unrelated to cardiovascular or psychologic status (Monga, Jaweed, Kerrigan, et al., 1997). Neurologic diseases, such as the peripheral neuropathy that can accompany some cancer chemotherapy (e.g., with vinca alkaloids) and that is sometimes seen in multiple myeloma patients, may also result in decreases in the efficiency of neuromuscular functioning.

Metabolic disturbances and centrally acting drugs may also cause sleep or arousal disorders, which could contribute to fatigue. Affective disorders such as depression can also be associated with difficulty sleeping and with fatigue (Miaskowski and Portenoy, 1998).

Because the etiology of cancer-related fatigue is multifactorial, there are a variety of avenues that may be useful in its management. Correction of anemia, either by RBC transfusion or after stimulation of RBC production, can relieve the portion of a patient's fatigue that is caused by anemia but does not address other causes of fatigue. This suggests that multimodality approaches should be explored and evaluated for effectiveness.

Pharmacologic approaches may be used to alleviate fatigue. First, elimination of nonessential centrally acting drugs, dose reductions, or alteration of dosing regimens may be beneficial. Antidepressants are indicated when there is a clear diagnosis of depression; patients treated successfully for major depression often report reduction in fatigue (Miaskowski and Portenoy, 1998).

Behavioral modifications may improve symptoms of fatigue. Educating patients regarding potential methods of reducing fatigue may relieve anxiety and provide reassurance and an element of control. Exercise has been postulated to reduce fatigue. Studies of exercise interventions during or after chemotherapy programs suggest that aerobic exercise reduces fatigue in study populations compared with that in control populations (Dimeo, Stieglitz, Novelli-Fischer, et al., 1999; Dimeo, Tilmann, Bertz, et al., 1997). Efforts to maintain nutritional status may avoid or alleviate metabolic dysfunction and prevent some cancer-associated fatigue (Kalman and Villani, 1997). Maintenance of regular sleep patterns and reduced activity schedules may also have a positive impact.

### Instruments Used to Measure the Effects of Anemia Treatment on Quality of Life

Quality-of-life instruments may be global or disease specific. Global instruments are intended for use across various chronic disease populations and permit comparison of quality-of-life outcomes among interventions and diseases. Today, the Short Form 36-item Health Survey (SF-36) is the most commonly used global measure of health status. But global instruments may fail to address issues that are important to patients and relevant to treatment of specific diseases. In oncology trials, there has been an attempt to balance the tradeoffs between global and disease specific measures by combining a cancer core instrument with a module specific to a particular malignancy or treatment (Beitz, Gnecco, and Justice, 1996). The primary cancer core instruments for use in clinical trials are the European Organization for Research and Treatment of Cancer (EORTC) core Quality of Life Questionnaire (QLQ-C30) and the general fanctional assessment of cancer therapy scale. Each of these core instruments can be supplemented with more specific modules, for example the EORTC QLQ-LC13 for lung cancer or the FACT-Ovarian.

Clinical trials of epoetin initially used unidimensional linear analog self-assessment scales (LASA) to measure changes in the quality of life related to anemia. Several studies of epoetin have used a three-item LASA in which patients rate their perceived energy level, ability to perform activities of daily living, and overall quality of life on a 100 mm-ruled line representing a continuum from lowest to highest possible assessment for each item (Abels, 1993; Demetri, Kris, Wade, et al., 1998; Glaspy, Bukowski, Steinberg, et al., 1997; Littlewood, Bajetta, Cella, et al., 1999). The reference cited by these investigators for the 3-item LASA is an earlier study of a 21-item LASA (Gough, Furnival, Schilder, et al., 1983) that was compared with other methods of quality-of-life assessment in patients with advanced cancer, but was not formally validated for reliability and validity. Nor is it clear that the wording for the three-item LASA was identical to that of items in the earlier study. An unvalidated 10-item LASA that addresses physical, functional, emotional, and social domains has also been used (Kurz, Marth, Windbichler, et al., 1997; Leitgeb, Pecherstorfer, Fritz, et al., 1994; Ludwig, Sundal, Pecherstorfer, et al., 1995). Limitations of these unidimensional instruments are the lack of validation and the inability to assess the relationship between multiple dimensions of quality of life or to directly compare scales using different questions.

More recent trials of epoetin use a multidimensional instrument, the Functional Assessment of Cancer Therapy-Anemia (FACT-An) (Cella, 1997). The core of the FACT-An is the Functional Assessment of Cancer Therapy-General (FACT-G), which contains 29 questions that can be used to generate subscale scores regarding physical, functional, emotional, and social well-being, as well as satisfaction with the patient-physician relationship (Cella, Tulsky, Gray, et al., 1993). Data from 1,172 cancer patients who answered the FACT-G questionnaire indicated that fatigue was the symptom most often reported (73 percent). As a result, two additional subscales were produced to assess fatigue and anemia in cancer patients. The FACT-Fatigue (FACT-F) consists of a fatigue-specific subscale of 13 items that was added to the FACT-G. The FACT-An was produced by adding to the FACT-F seven nonfatigue items relevant to anemia in cancer patients. Because of their recent development, experience with FACT-F and FACT-An is more limited than experience with the EORTC QLQ-30 or FACT-G.

The EORTC QLQ-C30 was developed for use in international clinical trials (Aaronson, Ahmedzai, Bergman, et al., 1993). This questionnaire incorporates five functional scales (physical, daily activity, cognitive, emotional, and social), three symptom scales (fatigue, pain, and nausea and vomiting), and a global health and quality-of-life scale. The EORTC QLQ-C30 has been shown to correlate well with items that examine similar dimensions in the SF-36 (Apolone, Filiberti, Cifani, et al., 1998; Chie, Huang, Chen, et al., 1999).

The FACT-G was validated in a population of 854 cancer patients (Cella, Tulsky, Gray, et al., 1993). FACT-G scores correlated well with other similar measures completed at the same time (e.g., r=0.79 for the Functional Living Index-Cancer; r=−0.52 for the Eastern Cooperative Oncology Group [ECOG] performance score). Test-retest correlation coefficients were all above 0.80. FACT-G physical, functional, and total scores differentiated patients by cancer stage (p<0.01). The FACT-G has been compared with the EORTC QLQ-C30 (Kemmler, Holzner, Kapp, et al., 1999). Correlations between corresponding subscales were best for the physical, functional, and emotional subscales (r=0.48 to 0.66) but lower for the social subscales (r=0.14). Correlations between the FACT-F and FACT-An and more widely used quality-of-life assessment instruments such as the SF-36 have not yet been reported.

The FACT-An and FACT-F questionnaires were validated on a sample of 50 patients with a variety of solid and hematologic malignancies, who had Hb levels ranging from 7 to 15.9 g/dL and were rated at different performance levels (Cella, 1997; Yellen, Cella, Webster, et al., 1997). Test-retest reliability was 0.87 for both, and internal consistency was high for the Fatigue subscale (alpha range, 0.93 to 0.95) but lower for the nonfatigue FACT-An subscale (0.59 to 0.70). All FACT scales were significantly related with other known measures of fatigue: the Profile of Mood States (POMS) Vigor and Fatigue subscales and the Piper Fatigue Scale. The FACT-An has been translated into other languages, and studies are underway to validate the instrument in larger populations and evaluate the effect of interventions to reverse fatigue caused by anemia.

### Reporting the Results of Quality-of-Life Assessments

The results of quality-of-life studies should be translated into clinically meaningful terms; that is, what is the smallest change in a quality-of-life score that patients perceive as beneficial?^2^ Statistical significance (p value) of the difference between treatment and control groups with respect to the magnitude of change in raw scores on quality-of-life instruments indicates only the likelihood of the results occurring by chance in the study population. It is more difficult to interpret the clinical significance of the results. Calculation of an effect size expresses quality-of-life change in the context of the variation within the population, and there are conventions for defining an effect size as small, moderate, or large. A clearer picture emerges when the magnitude of quality-of-life changes can be interpreted in comparison to the magnitude of more familiar clinical changes or results.

2 The authors thank Diane L. Fairclough Dr.PH. (AMC Cancer Research Center, CO) for generously sharing her expertise, which was of great help in preparing this discussion.

Effect size, calculated as the mean change divided by the standard deviation of the baseline scores, indicates what proportion of the background variation the change represents. Effect sizes of 0.2 to about 0.5 are considered to be small, 0.5 to 0.8 to be moderate, and greater than 0.8 to be large (Cohen, 1977; Kazis, Anderson, and Meenan, 1989). For example, in a validation study for the FACT-An scale, the authors observed a mean difference of 17.4 points between individuals with Hb levels of 11 to 12.99 g/dL and > 13 g/dL and a mean difference of 8.6 points between individuals with levels <11 g/dL and 11 to 12.99 g/dL (Yellen, Cella, Webster, et al., 1997). These represent moderate (0.75) and small (0.32) effect sizes, respectively. In a controlled intervention study, the effect size in the treatment group can be compared with the effect size in the control group, or the effect size can be calculated from the difference in the mean change scores between the two study arms.

One approach to interpreting the clinical significance of the magnitude of effect is to "anchor" quality-of-life score changes to other clinical changes or results for which the clinical significance of the magnitude of change has been established. For example, one could relate quality-of-life score changes to the differences observed between patients with ECOG performance scores that differ by one unit. Mean FACT-An total and subscale scores were significantly different for patients with an ECOG performance scale rating of 0 versus patients with a performance scale rating of 2 or 3 (combined) and were significantly different for patients with a performance scale rating of 1 versus 2 or 3. This suggests that the FACT-An can differentiate between these performance score categories. In addition, FACT-G (only) was able to differentiate between patients with performance scores of 0 versus 1 (Yellen, Cella, Webster, et al., 1997). The most commonly reported anchoring method involves relating changes in disease-specific quality-of-life scores to the change in a patient-reported global quality-of-life score that is relevant to the study (Lydick and Epstein, 1993). In this way, the more informative properties of the multidimensional quality-of-life instrument are linked to a more interpretable single-item question. Determining the clinical significance of the magnitude of quality-of-life score changes obtained from a recently developed disease-specific instrument such as the FACT-An may benefit from being anchored to a more familiar global measurement.

It is possible that the clinical significance of a given magnitude of change depends on the baseline value. For example, a small change could be more clinically significant for a patient with a low baseline quality-of-life score than for a patient with a high baseline. Additionally, changes in one direction could have more clinical significance than changes of equal magnitude in the opposite direction. However, this type of information is not currently available and may depend upon the quality-of-life scale.

## Community-Based Trials of Epoetin Therapy

### Assessment of Quality of Life in Clinical Trials

Several uncontrolled clinical studies of epoetin in cancer patients report statistically significant and favorable changes in measures of quality of life after epoetin treatment compared with baseline. However, factors other than epoetin intervention may affect outcomes; for example, tumor stage and progression, effects of cancer therapy, and changes in cancer therapy regimen. Comparison with historical or prospective but nonrandomized control groups may suffer from selection bias. Randomized controlled trials of adequate power are necessary to determine the true effects of an intervention on quality of life (Leidy, Revicki, and Geneste, 1999). In randomized trials, other factors that can affect cancer patients' quality of life are randomly and evenly distributed among treatment arms.

Quality-of-life results can also be affected by numerous details of the administration of the quality-of-life instrument and by the interaction between the physician and patient. Therefore, trials that assess quality-of-life endpoints should also incorporate specific design features related to the administration of quality-of-life instruments and the analysis and interpretation of results. The FDA recently outlined key features that should be addressed in designing and executing randomized controlled trials to assess quality-of-life endpoints for oncology drugs (Beitz, 1999; Beitz, Gnecco, and Justice, 1996); as summarized below:

- Rigorously validated instruments that permit cross-study comparisons should be used.
- Double-blinding is preferred; if it is not feasible, study personnel involved in the quality-of-life assessment should be blinded to the patients' treatment assignments and responses to treatment.
- The protocol should prospectively identify the quality-of-life outcomes to be measured as evidence of effectiveness, the critical points in time for measurement, and the minimum differences in quality-of-life scores to be considered clinically significant.
- The logistics of questionnaire administration should be handled to minimize the impact on the integrity of the quality-of-life assessment. Feedback from the investigator, treating physician, or staff that affects the patients' sense of well-being is a major source of bias in open-label trials and should be avoided. Ideally, the instrument should be administered prior to discussions with the physician (or other health care provider) as to treatment response, adverse events, or other matters that could affect patients' responses to the quality-of-life questionnaire.
- The study protocol should include a detailed schema and rationale for the time intervals at which the instrument will be administered. The training for staff administering the instrument should be described, with similar information if the instrument is self-administered by the patient.
- There should be a detailed plan for preventing missing data, investigating the pattern of missing data, and addressing missing data in the analysis. If data are missing nonrandomly, serious bias can result. For example, patients with missing questionnaires are frequently the sickest patients or those least responsive to therapy. But failure to respond to specific items in a questionnaire also raises concerns.

The largest published trials of epoetin therapy in oncology patients are two uncontrolled community studies (CSs) of patients undergoing chemotherapy reported by Glaspy, Bukowski, Steinberg, et al. (1997) and Demetri, Kris, Wade, et al., (1998), referred to here as CS-1 and CS-2, respectively.^3^ Because of their size (over 2,000 patients enrolled in each trial), community-based setting, and measurement of quality-of-life outcomes, the results from these single-arm trials are widely cited. To date, the community studies are the largest source of evidence on quality-of-life outcomes. Cleeland, Demetri, Glaspy, et al. (1999) conducted a multivariate regression analysis of the CS-1 and CS-2 data to determine, for each study, the association between change in Hb level (baseline to final value at study end or last monthly measurement before patient withdrawal) and change in quality-of-life (baseline to final value at study end or patient withdrawal) while adjusting for factors other than epoetin that might affect changes in both Hb levels and quality-of-life scores. Additional data imputation models were developed in an effort to adjust for missing quality-of-life data. This study was supported by Ortho Biotech, and the company supplied additional detail for evaluation (Finkelstein, Berndt, and Crimieux, unpublished manuscript, 1998).

3 Recently, a third large single-arm community-based study of a similar oncology population (CS-3) investigated the use of a once-weekly dosing regimen for epoetin (Gabrilove, Einhorn, Livingston, et al., 1999) for nearly 3,000 patients treated with epoetin. This study has only been reported as a meeting abstract thus far, but found increased Hb levels, reductions in transfusion, and improvements in patient reported-quality-of-life measures related to increased Hb levels.

We will summarize the results of the community studies and the finding of the multivariate analysis by Cleeland, Demetri, Glaspy, et al. (1999). Overall, these reports showed an association between increases in Hb and increases in quality-of-life scores. An equally important finding was that tumor response also had an independent effect on changes in quality-of-life scores. Given the biologic mechanisms of anemia in cancer, tumor response would be expected to have an independent effect on Hb, resulting from both the underlying disease and related changes in treatment. These reports, however, did not establish a causal relationship between epoetin treatment and improvement in quality of life. Moreover, a substantial amount of data on tumor response and quality of life are missing in the community studies. In the analysis, the values for missing tumor response data were assumed rather than omit substantial numbers of patients, and imputation methods were applied to the missing quality-of-life data. However, there is potential for significant bias in the results of the analysis. Finally, data collected in uncontrolled community studies is subject to bias resulting from inadequate control over the circumstances under which the quality-of-life assessment instrument is administered. Without controls, the influence of the expectations of physicians and patients may overestimate the magnitude of effect reported.

### Summary of Community Studies

Table 4 summarizes and compares important features of CS-1 (Glaspy, Bukowski, Steinberg, et al., 1997) and CS-2 (Demetri, Kris, Wade, et al., 1998). Both studies enrolled patients with nonmyeloid malignancies who were receiving chemotherapy and treated them with approximately 150 U/kg of epoetin three times weekly. Enrollment in CS-2 was restricted to patients with Hb lower than 11; CS-1 set no Hb cutoff for enrollment, but only 8.2 percent of patients had initial Hb greater than 11. CS-1 and CS-2 enrolled 2,342 and 2,370 patients, respectively. In both trials, 42 percent of patients withdrew before completing the full treatment cycle.

Table 4. Comparison of two single-arm trials of epoetin and quality of life

Authors/Year | CS-1 ^1^ | CS-2 ^2^
Number of patients enrolled | 2,342 | 2,370
Study period | 4 months | 2-4 months
Study definition of anemia | None; (8.2% of patients had initial Hb >11) | Hb <11; eligibility restricted to anemic patients
Study definition of response | None | >2 g/dL increase in Hb or Hb >12 or both
Diseases included | Stem-cell therapy and transplant patients not excluded | Stem-cell therapy and transplant patients excluded
Prior radiation treatment | No information | Nearly 90% of patients received no prior radiation
Number of patients who left the trial prior to completing the protocol (percent of enrolled) | 983 (42.0%) | 1,003 (42.3%)
Number of patients evaluable for hematologic outcomes (percent of enrolled) | 2,019 (86.2%) | 2,237 (94.4%)
Number of patients evaluable for quality-of-life outcomes (percent of enrolled) | 1,498 (64.0%; LASA) | 1,761 (74.3%; LASA) 1,579 (66.6%; FACT-An)
Number of patients with pretreatment tumor status data (percent of enrolled) | None | 1,368 (57.5%) ^3^
Number of patients with post-treatment tumor status data (percent of enrolled) | 759 (32.4%) collected retrospectively ^3^ | 2,117 (89.3%) collected prospectively ^3^

1 Glaspy, Bukowski, Steinberg, et al., 1997.

2 Demetri, Kris, Wade, et al., 1998.

3 Tumor status/response classified into categories of complete response, partial response, stable disease, progressive disease

More than 2,000 patients were evaluable for hematologic and transfusion outcomes in each trial, 86 percent of enrolled patients in CS-1 and 94 percent in CS-2. When baseline Hb levels were compared with end of study results in CS-1, there was a 1.8 g/dL average increase (p<0.001), and 53 percent of patients achieved an Hb increase of 2.0 g/dL or better. In CS-2, the average increase was 2.0 g/dL (p<0.001), and 61 percent of patients met the study criteria for response. In CS-1, epoetin therapy was associated with an approximately 50 percent decrease both in the proportion of patients who required transfusion and in the number of units of RBCs transfused per patient. In CS-2, the percentage of patients who required transfusion decreased from 29 percent at baseline to 5 percent at month 4, and the mean number of units transfused per patient decreased from 1 to 0.2.

Much smaller percentages of enrolled patients were evaluable for quality-of-life outcomes than for hematologic outcomes. The LASA scales for energy, daily activity, and overall well-being were used in both trials; data were available for analysis for 1,498 (64 percent) patients in CS-1 and 1,761 (74 percent) patients in CS-2. The Functional Assessment of Cancer Therapy-Anemia was used only in CS-2; data on 1,579 (67 percent) of patients were available for analysis. Neither report described protocols to control for systematic bias arising from the timing, circumstances, interactions, or expectations related to the administration of the quality-of-life instruments. Univariate analysis in both trials showed significant, positive associations between increases in Hb levels and increases in all quality-of-life scores. Stratification by end-of-study tumor response status in CS-2 indicated that the association between increases in Hb levels and improvement in quality-of-life scores disappeared when the tumor progressed. LASA scores significantly improved over baseline; analysis of available data found a 30 to 50 percent change in each quality-of-life measure, with a greater than 4 g/dL increase in Hb. By FACT-An, responders to epoetin had a significant improvement in quality-of-life scores; the improvement was much less for nonresponders.

Data on posttreatment tumor response were collected prospectively only in CS-2 and were available for 89 percent of enrolled patients. In CS-1, posttreatment tumor response data were collected retrospectively, but were obtained for only 32 percent of enrolled patients. No pre-treatment tumor status data was collected in CS-1; in CS-2, baseline data were available only for 1,368 (58 percent) of enrolled patients. The missing CS-2 baseline data severely limit the assessment of the effects of change in Hb on changes in quality-of-life scores independent of the effects of baseline tumor status or change in tumor status during treatment.

### Multivariate Regression Analysis and Imputation for Missing Data

Cleeland, Demetri, Glaspy, et al. (1999) conducted a multivariate regression analysis of the CS-1 and CS-2 data to determine, for each study, the association between change in Hb level (baseline to final value at study end or last monthly measurement before patient withdrawal) and change in quality-of-life (baseline to final value at study end or patient withdrawal), while attempting to control for factors other than epoetin that might affect both Hb levels and quality-of-life scores. The analysis also attempted to determine the Hb level at which the greatest improvement in quality of life, if any, is achieved. The analysis focused on the relationship between Hb change and change in quality of life score but did not attempt to relate causes of Hb change (i.e., epoetin, transfusion, chemotherapy, or disease) to changes in quality of life.

Variables selected for the analysis included baseline tumor status and change in tumor response, data collected prospectively only in CS-2. The analysis identified change in tumor status to progressive disease and progressive disease at baseline as confounders of the association between change in Hb level and change in quality of life. This is not surprising, since disease status and/or disease treatment are related to Hb level and can independently affect quality of life. In a study of high-dose versus low-dose epoetin treatment of patients with advanced gastrointestinal cancer, Glimelius, Linne, Hoffman, et al. (1998) found that tumor response was as important for improvements in EORTC QLQ-C30 scores as an increase in Hb. Findings reported in the unpublished manuscript by Finkelstein, Berndt, and Crimieux (1998) illustrated a similar effect observed in CS-2. Change in tumor status from stable or in remission at baseline to progressive was associated with a decrease in the LASA overall quality-of-life score of 12 units; for the FACT-An, the corresponding decrease was 15 units. In comparison, an increase in Hb from lower than 7.5 g/dL to 14 g/dL was associated with a 21-unit increase in the LASA score. Interestingly, the authors did not explore the potential effect of a change in tumor status from progressive to stable/remission, which could reasonably be expected to be associated with Hb change and to have a positive, independent effect on quality of life. Moreover, because 47 percent of patients in CS-2 did not report baseline data on tumor status, the authors assumed nonprogressive disease at baseline for the patients with missing data. The analysis reported a significant, independent association between the change in Hb and the change in quality-of-life scores, suggesting that effectors of Hb change might also effect changes in quality of life. The analysis also suggested that the greatest increase in quality of life was associated with an increase in Hb to the range of 11to 13 g/dL. However, modeling the association between change in Hb and change in quality of life in CS-2 is problematic not only because of the difficulty in adequately accounting for all confounders of the association, but also because of two types of missing data.

First, nearly one-half of patients are missing data on baseline tumor status. The rationale for the assumption of nonprogressive disease for all patients with missing data is not clearly explained. Moreover, no sensitivity analyses were presented to show the effects of this assumption on the results reported. It cannot be determined whether this assumption was conservative or might overestimate the relationship between increases in Hb and change in quality-of-life scores. A second problem is that final LASA scores were missing from 25 percent of patients and final FACT-An scores were missing from 33 percent of patients. Missing quality-of-life data are unlikely to be missing at random from the entire population enrolled. In fact, patients who lacked a complete set of data were more likely to be nonresponders to epoetin (Ortho Biotech, Inc., personal communication between Jerome Seidenfeld, Ph.D. and Margaret Piper, Ph.D., M.P.H., 1999).

In an attempt to adjust for nonrandomly missing quality-of-life data, the missing data were imputed based on several known characteristics of the patients with complete data, using the econometric Heckman approach. A sensitivity analysis in which the missing final quality-of-life data were all assumed to show no improvement was performed and reported to confirm the results of the analysis using imputed final quality-of-life data.

In summary, a multiple regression analysis was performed on data from two large uncontrolled community studies of epoetin therapy in cancer patients. This analysis showed an association between increases in Hb and increases in quality-of-life scores. The analysis attempted to control for the independent effects of progressive disease on quality-of-life changes, but did not address the potential effects of change in tumor status from progressive to stable/remission. Systematically missing data on baseline tumor status and final quality-of-life scores prevented drawing clear conclusions regarding the significance and magnitude of the association. The data were derived from uncontrolled studies that did not report rigorous protocols for the conduct of quality-of-life assessment, which could contribute to overestimation of the effects of increased Hb on quality-of-life changes. Finally, this approach can establish an association between change in Hb levels and changes in quality of life, but cannot demonstrate a causal relationship. Nor does this model demonstrate a causal relationship between epoetin treatment and improvement in quality of life in cancer patients undergoing chemotherapy.

## Analyses Comparing Costs of Epoetin to Costs of Transfusion

No trials included in this systematic review reported data to compare the costs of epoetin and transfusion. As a result, our review of evidence on cost is limited to a discussion of secondary cost analyses summarized here. Published studies include cost comparisons based on a decision model, a cost-benefit analysis based on willingness to pay, and cost-effectiveness studies. Most cost analyses to date have used randomized controlled trial data reported by Abel (1993) or the community study by Glaspy, Bukowski, Steinberg, et al. (1997) as the basis for developing assumptions about epoetin dosage, hematologic response rates, transfusion rates, and changes in quality of life associated with treatment. Overall, cost comparison analyses are in agreement that epoetin costs are much greater than those of transfusion alone and that broad sensitivity analyses do not change this conclusion under existing conditions and reasonable assumptions.

A cost comparison study by Sheffield, Sullivan, Saltiel, et al. (1997) analyzed the costs for treatment based on a decision model constructed for both treatment pathways, epoetin with transfusion support or transfusion alone. This model assumed six chemotherapy cycles, one every 4 weeks, with epoetin administration beginning at Hb <11 g/dL. Cost was calculated based on an initial dose of 450 U/kg per week; nonresponders then received 900 U/kg per week; all patients were assumed to receive iron supplementation. A successful response to epoetin was defined as an Hb increase of >2 g/dL; based on published randomized clinical trial data (Abels, 1993), 64 percent of patients were assumed to respond. The average cost per patient was $12,971 per patient for epoetin and $4,481 per patient for transfusion alone, with a cost difference of $8,490 in favor of transfusion alone. Costs converged only if the epoetin dose was lowered and more transfusions were used.

Meadowcroft, Gilbert, Maravich-May, et al. (1998) also reported a cost comparison study. This study assumed an epoetin regimen of 450 U/kg per week for a 3-week chemotherapy cycle and a response rate of 58 percent based on the published literature. The cost of having fatigue was assumed to be $175, which was noted to be a conservative estimate. In this study, the cost difference was $6,314, favoring transfusion alone, over four chemotherapy cycles.

Ortega, Dranitsaris, and Puodziunas (1998) reported a cost-benefit analysis of epoetin using a "willingness to pay" assessment of value. Epoetin dose was assumed to be 450 U/kg per week for 12 weeks; risk reduction was estimated from a randomized clinical trial (Abels, 1993). The resulting cost difference was approximately $3,600 in favor of transfusion. A sample of patients receiving chemotherapy for malignancy was given relevant information regarding the clinical aspects of epoetin and transfusion therapy; then each was asked to rate the importance of the epoetin benefit and to decide the maximum they would pay to receive epoetin therapy. Patients were only willing to pay approximately $600, suggesting that their aversion to transfusion therapy was not sufficient to warrant paying the actual incremental epoetin cost of $3,600. The authors stated that the majority of cancer patients and respondents interviewed in this Canadian study were younger than age 65 and not eligible for provincial drug benefits and that their payment options are similar to those of U.S. patients, e.g., private health insurance, personal funds, etc. Thus, they suggested that the study results are likely to be generalizable to the U.S. population. Results of this study were reported in U.S. dollars.

A cost-effectiveness analysis by Barosi, Marchetti, and Liberato (1998) assumed a 4-month course of epoetin at a dose of 450 U/kg per week. Response rates were derived from a large, single-arm trial (Glaspy, Bukowski, Steinberg, et al., 1997) and compared with those of randomized controlled trials. Quality-of-life adjustment for epoetin was based on visual analog scale results from single-arm (Glaspy, Bukowski, Steinberg, et al., 1997) and randomized controlled trials (Abels, 1993); the same improvement was also used for patients heavily transfused to reach the same Hb level. The incremental cost of epoetin per quality adjusted life year (QALY) was estimated at $189,652. The authors compared this with a cost of $20,000 per QALY for epoetin use in ESRD (Nicholls, 1992). In sensitivity analyses, the incremental cost dropped below $100,000 only if the direct cost of epoetin was 50 percent lower or if epoetin was only used on patients who were heavily transfused during chemotherapy and the need for transfusions was thereby abolished. Results of this Italian study were reported in U.S. dollars.

Using similar assumptions based on a randomized, controlled trial (Abels, 1993), similar base transfusion cost estimates, and higher epoetin cost estimates, Cremieux, Finkelstein, Berndt, et al., (1999) estimated a cost difference of $6,135 in favor of transfusion and a range of cost per QALY of $34,377 to $214,391, depending on the value attached to the change in quality of life. The authors attribute the variability in the estimate to a nonlinear relationship between change in physical function and the patient's value for that change on a linear scale, arguing that a given change in quality of life estimates across health states has different meaning for patients at different states or levels of physical function.

Calculating cost effectiveness using QALYs is recommended as the standard method for comparison of health care interventions (Gold, Siegel, Russell, et al., 1996). But in the above study, Cremieux, Finkelstein, Berndt, et al. (1999) argue against the use of QALYs when the gain is short-term change in quality of life, such as is achieved by supportive or palliative care. Instead, the authors defined effectiveness as either the cumulative gain in Hb level or the raw unit change in quality of life on a linear scale. By taking the ratio of the cost of transfusion alone to the cumulative gain in Hb (or the unit change in quality of life) for the epoetin-treated arm and dividing this by a similar ratio for the control arm, the authors reported "cost-effectiveness" results in favor of epoetin treatment. However, this analysis does not permit comparison of cost effectiveness of health care interventions for various conditions, which is the objective of using QALYs as a standard measure of effectiveness. The findings were limited to outcomes related to anemia; and there was no illustration of how to apply the method to cost-effectiveness analysis of other supportive or palliative interventions.

## Background on Key Clinical Issues for Each Population Addressed in this Systematic Review

### Issues Specific to Anemia Primarily Due to Cancer Therapy

The population of greatest interest for this systematic review is patients who are beginning chemotherapy (and/or radiotherapy) and who have mild anemia (Grade 1: Hb 10g/dL to < WNL) or who are at risk of anemia. Four alternatives can be envisioned to manage these patients. The most aggressive option is to treat all patients with epoetin with the intent of achieving or maintaining Hb levels within the normal range. An intermediate approach is to initiate epoetin only for patients in the lower portion of the range for mild anemia (i.e., Hb >10 and <12 g/dL) to prevent the development of moderate (Grade 2: Hb 8 to 10 g/dL) anemia. The third option would delay epoetin treatment until Hb falls to <10 g/dL and patients develop moderate anemia. The fourth alternative would be to manage anemia without epoetin. Patients would receive RBC transfusions when symptomatic or when serious/severe anemia (Grade 3: Hb 6.5 to 7.9 g/dL) developed. Each of these four alternatives could be implemented by setting a specific Hb level at which treatment would be initiated, for example, epoetin treatment at Hb <11 g/dL or transfusion at Hb <8 g/dL.

In the trials included in this systematic review, the percent of patients receiving RBC transfusion was always lower in the epoetin arm than in the control arm. However, transfusion was nonetheless relatively common in patients treated with epoetin. One explanation is that the Hb level for initiating epoetin was too low. But other explanatory factors should also be considered. First, each trial had some proportion of patients who did not demonstrate a hematologic response to epoetin, and therefore epoetin could not protect these patients from transfusion. Second, in trials in which mean baseline was <10 g/dL, a substantial proportion of patients might enter with Hb level far enough below the mean that they were already near the Hb transfusion trigger for the study. This would not occur in a clinical setting in which Hb was monitored on an ongoing basis, with epoetin treatment initiated at a predefined threshold. Third, some cancer treatment regimens might cause an accelerated decline in Hb level relative to other treatment regimens, so that rate of decline as well as absolute Hb threshold may be relevant.

The specific chemotherapy regimen and previous treatment history may influence not only the likelihood and severity of anemia but also its course. The likelihood of symptomatic anemia varies with the specific drug or drug combination given, the dose and dose intensity for each drug, and the number of treatment cycles or the duration of the treatment regimen. For patients given less intense or short-duration regimens and without extensive prior treatment, Hb levels may decline briefly with each chemotherapy cycle and then spontaneously return to normal levels. Such patients are low risk for developing chronic symptomatic anemia or requiring RBC transfusion. In contrast, spontaneous correction of anemia is likely to be substantially delayed in those given more myelotoxic chemotherapy for longer times or in those treated for a second or greater relapse with a history of multiple previous therapies. Several drugs (e.g., cisplatin) have direct toxic effects on the kidney that can reduce endogenous production of erythropoietin (Armitage 1998; Beguin 1996; Moliterno and Spivak, 1996; Wood and Hrushesky 1995).

Radiation therapy can be toxic to bone marrow stem cells. However, the degree to which radiation therapy impairs hematopoiesis depends on the dose and extent of radiation. Total body irradiation has the greatest chance of causing anemia. In contrast, conformal radiation targeted to an internal organ distant from any of the larger marrow-containing bones is unlikely to reduce Hb levels. The role of oxygen in the cytocidal effects of radiation therapy for cancer (Hellman, 1997) raises an additional issue. Investigators have hypothesized that correcting anemia might improve the effectiveness of radiation therapy by increasing tissue oxygenation (e.g., Bush 1986; Dische 1991; Fein, Lee, Hanlon, et al., 1995; Poskitt 1987).

Disease characteristics may also influence the likelihood and severity of anemia. Such characteristics include the tissue or organ site of the tumor, its specific histologic type, the burden of malignant cells present, and the site(s) of their dissemination. Some malignancies also are more likely than others to cause the anemia of chronic disease, possibly because of differences in the production of cytokines that reduce expression of endogenous erythropoetin. Tumor burden may influence the dose, intensity, and duration of anemia-causing therapy as well as the level of cytokine production.

Finally, patients are less likely to have clinical responses to epoetin when malignant cells have replaced a large percentage of the normal bone marrow cells. This can occur in patients with some hematologic malignancies as well as in those with tumors of solid organs or tissues with a propensity to metastasize to the bone marrow (e.g., prostate, breast, or small cell lung cancer). Transfusion may be the only option to manage anemia in such patients. For this reason, patients with extensive malignant involvement of the bone marrow were excluded from many clinical trials of epoetin.

### Issues Specific to Anemia Primarily Due to Malignant Disease

Patients with anemia that is primarily due to malignant disease are those who would be anemic whether or not they were receiving concurrent treatment for their malignancy. In principle, it would be useful to know if anemic patients who are not being treated for their malignancy differ from those who are being treated with respect to potential benefits from use of epoetin to manage anemia. However, it is difficult in practice to separate studies on disease-related anemia from studies on treatment-related anemia, since presently in the United States, most patients with a malignancy are treated. Furthermore, those who are not being treated (e.g., those in an apparent complete remission who may have subclinical residual disease) are unlikely to have anemia unless their malignancy is a clonal bone marrow disorder.

For this systematic review, clinical trials of epoetin in which all enrolled patients received concurrent therapy for malignancy are included in the review of evidence for treatment-related anemia (Chapter 3). Trials of epoetin that enrolled some patients not treated for malignancy during the study are included in the review of evidence for disease-related anemia (Chapter 4). To be included among the trials on disease-related anemia, studies also must have restricted enrollment to patients with diseases known to have a high occurrence of the anemia of malignancy. However, results from trials with a preponderance of patients receiving chemotherapy or radiation may not apply to populations with anemia and a malignancy that is not being treated.

Anemias resulting from malignancy are heterogenous. For example, anemia resulting from inhibitory cytokines and/or other humoral factors whose production may be increased in patients with certain malignancies may respond differently to epoetin therapy than does anemia due to defects in the stem-cell population or due to inadequate production of endogenous erythropoietin (Moliterno and Spivak, 1996). Consequently, results from studies on patients with anemia primarily due to hematologic malignancies probably do not speak to the potential benefits of using epoetin in patients with anemia primarily caused by tumors of solid tissues or organs. Furthermore, it is likely that hematologic malignancies with different etiologies of anemia also may differ with respect to hematologic responses to and clinical benefits from epoetin.

Some hematologic malignancies (e.g., MDSs, multiple myeloma) may arise from genetic changes to the bone marrow stem-cell population that may reduce their ability to proliferate and/or differentiate into mature RBCs in response to erythropoietin. Note also that malignant myeloid cells may express receptors for erythropoietin; some have speculated that such cells might proliferate more rapidly after epoetin is administered. Patients with myeloid malignancies (i.e., acute and chronic myeloid leukemias) have been excluded from most (if not all) clinical trials of epoetin because of this possibility.

The MDSs are distinctive among the hematologic malignancies that cause disease-related anemia and that have been treated with epoetin. MDS patients usually are not deficient in endogenous erythropoietin (Stein, Abels, and Krantz, 1991). However, the clonal defect in the hematopoietic stem-cell population may render them resistant to the differentiative and maturational effects of erythropoietin. The hypothesis that pharmacologic concentrations of epoetin might overcome these defects led to a series of single-arm trials.

Hellstrom-Lindberg (1995) conducted a meta-analysis of the single-arm studies of epoetin therapy in patients with MDS. The analysis included 17 single-arm studies with a combined total of 205 patients. Response was defined as an increase in Hb of >1.5 g/dL without transfusion support; the overall response rate was 16 percent. Fewer patients with MDS of FAB class RARS responded than did patients with all other FAB classes (7.5 percent versus 21.1 percent, p=0.015), although the study included few patients with RAEB-t or CMML. Patients who were transfusion independent at study entry were more likely to respond than those who were transfusion dependent (44 percent versus 10 percent, p=0.0001). Although the serum concentration of erythropoietin at study entry was lower among responding patients than among nonresponders, this determination did not appear to be an independent predictor of the likelihood of response. For example, the highest response rates were reported for patients in FAB classes RA or RAEB and without previous transfusion history, regardless of baseline serum erythropoietin.

Since all trials included in the meta-analysis by Helmstrom-Lindberg (1995) lacked control groups managed without epoetin, the results are difficult to interpret. They do provide a solid rationale for conducting randomized comparative trials. However, the unique biologic features of MDS make it unlikely that results from controlled trials on patients with this disease are applicable to patients with other malignancies.

### Issues Specific to Anemia Resulting from Bone Marrow Ablation Prior to Stem-Cell Transplantation

Patients with malignancies who undergo myeloablative therapy followed by infusion of hematopoietic stem cells invariably go through a period of severely impaired or completely absent erythropoiesis. Neither can they produce new platelets or white blood cells until engraftment of the reinfused stem cells is complete. As a consequence, virtually all transplanted patients require some transfusions with RBCs and platelets. Thus, it is unlikely that epoetin might reduce the percentage of transplant patients who are transfused, although it might reduce the time to RBC engraftment and the number of RBC units transfused per patient.

Early in the investigation of epoetin for patients undergoing stem-cell transplants, there was concern that epoetin might divert too much of the stem-cell pool into the erythroid differentiation pathway. It was hypothesized that if this happened, recovery of neutrophil and/or platelet counts might be delayed. Consequently, the effects of epoetin on neutrophil engraftment and on platelet counts were outcomes of interest in these trials.

For transplants in the inpatient setting, there was interest in whether epoetin treatment might reduce the length of hospitalization by reducing the time to erythroid engraftment. However, recovery of neutrophil and platelet counts also is necessary before hospitalized transplant patients can be discharged. Thus, some studies have investigated the use of epoetin in combination with myeloid growth factors such as filgrastim or sargramostim.

The source of stem cells may also play a role in the need for or response to epoetin. Allogeneic transplants may be from a related or unrelated donor who may be matched or partially mismatched at the six human leukocyte antigen (HLA) loci. With autologous transplants, the patient's own stem cells are reinfused. The potential for epoetin to accelerate engraftment, reduce transfusion use, or improve other outcomes may differ for allogeneic and autologous transplants and may also depend on the degree of HLA mismatch. In addition, stem cells may be obtained from bone marrow or from peripheral blood, which may differ in either the need for or the response to epoetin.

Peripheral blood stem cells (PBSCs) are usually harvested after mobilization with myeloid growth factors. The infusate includes progenitor cells that are farther along the differentiation and maturation pathway towards end-stage RBCs than are present in bone marrow-derived stem cells. Myeloid engraftment is known to be faster with PBSC than with marrow-derived stem cells. Consequently, epoetin treatment after the stem cells are infused may be unable to further accelerate erythroid engraftment in this setting.

Stem-cell transplant patients experience a high incidence of serious and life-threatening adverse effects of treatment that are unrelated to anemia and its management. Few, if any, studies in the transplant setting administer epoetin for more than 2 months or monitor outcomes for more than 3 months. By that time, engraftment of all three lineages is usually complete in most patients. Allogeneic transplants carry a high risk for GVHD, which may cause serious morbidity or mortality. All transplant patients are at risk for serious, life-threatening infections or bleeding episodes until engraftment has occurred. Adverse outcomes due to these complications may overwhelm any potential benefit from managing anemia with epoetin. In addition, patients who die early from transplant-related complications are lost to follow-up for evaluation of erythroid engraftment.