# Appendix D. Acronyms

AABB: American Association of Blood Banks

AHRQ: Agency for Healthcare Research and Quality

ASCO: American Society of Clinical Oncology

ASH: American Society of Hematology

AuSCS: autologous stem-cell support

BFU-E: burst-forming units-erythroid

CFU-E: colony-forming units-erythroid

CI: confidence interval

CLL: chronic lymphocytic leukemia

CMML: chronic myelomonocytic leukemia

CONSORT: Consolidated Standards of Reporting Trials

CS: community study

ECOG: Eastern Cooperative Oncology Group

EORTC: European Organization for Research and Treatment of Cancer

EPO (Epo): epoetin

ESRD: end-stage renal disease

FAB: French, American, British

FACT-An: Functional Assessment of Cancer Therapy-Anemia

FACT-F: Functional Assessment of Cancer Therapy-Fatigue

FACT-G: Functional Assessment of Cancer Therapy-General

FDA: Federal Drug Administration

Fe: iron

GI: gastrointestinal

G-CSF: granulocyte colony-stimulating factor (filgrastim)

GM-CSF: granulocyte/macrophage colony-stimulating factor (sargramostim)

Hb: hemoglobin

Hct: hematocrit

HDC: high-dose chemotherapy

HLA: human leukocyte antigen

IL-6: interleukin-6

iv: intravenous

LASA: linear analog self-assessment

MCH: mean corpuscular hemoglobin

MCHC: mean corpuscular hemoglobin concentration

MCV: mean corpuscular volume

MDS: myelodysplastic syndrome

MeSH: Medical Subject Heading

MM: multiple myeloma

mn: mean

MTX: methotrexate

N: number of patients

N/A (NA): not applicable

NCI: National Cancer Institute

NHL: non-Hodgkin's lymphoma

NNT: number needed to treat

NR: not reported

NS: no significant difference

O/E: ratio of observed to expected

O/P ratio: ratio of observed to predicted

PBSC: peripheral blood stem cell

PDI: Psychological Distress Inventory

PLT: platelet

POMS: Profile of Mood States

PS: performance score

pt: patient

QALY: quality-adjusted life year

QLQ: Quality-of-Life Questionnaire

QoL: quality of life

R/O: ruled out

RA: refractory anemia

RAEB: refractory anemia with excess of blasts

RAEB-T: refractory anemia with excess of blasts in transformation

RARS: refractory anemia with ringed sideroblasts

RBC: red blood cell

retic: reticulocyte

RR: risk ratio

sc: subcutaneous

SCS: stem-cell support

SD: standard deviation

serum Epo: serum concentration of endogenous erythropoietin

SF-36: Short Form 36-Item Health Survey

TBI: total body irradiation

TIBC: total iron-binding capacity

transf: transfusion

TSAT: percent transferrin saturation

Tx: treatment

WHO: World Health Organization

WNL: within normal limits