# Appendix C. Data Abstraction Form

Appendix C. Data Abstraction Form

Field Name | Type | Description
Table: Included Studies (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Citation | Txt | AHCPR style for citation in text
Abstract_only? | Y/N | Is this study reported in Abstract form only?
Others? | Y/N | Are there other Procite records that report data from this study?
No_others | # | How many other Procite records report data from this study?
Key_Q1 | Y/N | Are data reported that address Key Question 1 (anemia of chemotherapy)?
Key_Q2 | Y/N | Are data reported that address Key Question 2 (anemia of disease)?
Key_Q3 | Y/N | Are data reported that address Key Question 3 (anemia after stem cell transplant)?
Funding | Lookup | What was the source of funding for this study? (academic grant, industry and academic grant, Ortho, Chugai-Upjohn, other industry, other, not specified)
Table: Study Design Characteristics (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Random | Y/N | Did study randomize patients to EPO/no EPO?
allocation | Y/N | Did the study indicate concealment of allocation (e.g. central randomization, opaque envelopes)?
Blinding | Lookup | Was study blinded (single, double, or non-blinded)?
Placebo? | Y/N | Did the study use a placebo for the control group?
Control_type | Lookup | Did study use historical controls? (Concurrent if no)
Multi-ctr | Lookup | Was study a multi-center trial? (Single center if no)
Disease(s) | Lookup | Disease(s) included in eligibility for study (select from lookup list)
tumor type | Txt | Enter solid tumor type(s) if study was limited to patients with a single or a few types
stratified? | Y/N | If patients had multiple malignancy types, were outcomes stratified by at least one type?
Qol data? | Y/N | Did the study collect quality of life (QoL) data?
QoL_name | Txt | Did the study report intermediate time point QoL results in addition to beginning and end?
mult_outcomes | Y/N | Did the study report intermediate time point results for QoL, hematologic, or transfusion data?
Table: Study Definitions (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
CR_Definition | Txt | Define complete response to EPO ('None' if not defined for Q1, Q2; blank for Q3 studies)
PR_Definition | Txt | Define partial response to EPO ('None' if not defined for Q1, Q2; blank for Q3 studies)
trig_specif? | Y/N | Did the study protocol specify a RBC transfusion trigger?
transf_trig | # | What value of Hb was used as the transfusion trigger (convert from Hct if necessary)?
RBC_engraft | # | For Q3 (transplant) studies only, what Hb value defined RBC engraftment (0=no def.)?
Retic_engraft | Text | Define reticulocte measurement used in patient outcome
Table: Study Eligibility Criteria (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
Hb_cutoff | # | Upper limit of Hb level for study enrollment (<; e.g. enter 12.1 if study reports </=12)
lowerlimit? | Y/N | Is Hb cutoff value entered a lower limit rather than an upper limit?
Calc? | Y/N | Was hemoglobin cutoff level calculated from hematocrit? (Hb level reported if No)
PS_cutoff? | Y/N | Was patient eligiblity limited based on performance score?
PS_scale | Lookup | Which scale was used to report performance status?
PS_limit | # | Enter the poorest performance score accepted for patient inclusion.
LE_cutoff? | Y/N | Was patient eligibility limited to a minimum life expectancy?
min_LE | # | Enter the minimum # months of life expectancy for inclusion on study.
Table: Study Eligibility, Other Causes of Anemia (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
R/O_other | Y/N | Were other causes of anemia ruled out in enrolled patients?
Fe_def | Lookup | Was iron deficiency ruled out as the cause of anemia?
B12_def | Lookup | Was vitamin B12 ruled out as the cause of anemia?
folate_def | Lookup | Was folate ruled out as the cause of anemia?
bleeding | Lookup | Was internal bleeding ruled out as the cause of anemia?
hemolyt_anem | Lookup | Was hemolytic anemia ruled out as the cause of anemia?
others_NOS | Lookup | Were other causes of anemia ruled out without specifying specific causes?
Table: Study Epo Treatment Regimen (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
regimen_type | Lookup | Describe general regimen type
EPO_dose | # | Initial dose of EPO per day
EPO_units | Lookup | Enter type of EPO dose units reported
EPO_target | # | Enter the target Hb value after which EPO was discontinued, as applicable.
EPO_final | # | Enter the final Hb value if regimen calls for increasing or decreasing EPO dose
EPO_route | Lookup | Route of EPO administration
EPO_freq | # | Initial frequency of EPO administration, per week
EPO_duration | # | Maximum duration of EPO administration, in weeks
Fe_suppl | Lookup | Were patients given iron supplementation (oral or IV)?
CSF_use | Y/N | Did patients also receive G-CSF or GM-CSF?
Table: Study Cancer Treatment (Q1)
Rec# | # | Procite Record Number, primary study citation
Regimen | Lookup | Were there single or multiple chemotherapy regimens administered?
Reg_desc | Text | Describe the chemotherapy regimen(s).
Plat? | Lookup | Were all, some, or none of patients administered a platinum agent?
No_cycles | # | Mean or median # chemotherapy cycles during study
Mn/Md_C | Lookup | Was # chemotherapy cycles reported as a mean value or a median?
RadioTx? | Lookup | Did patients receive radiotherapy while on study?
TBI? | Lookup | Was TBI included in radiotherapy regimen?
radioTx_cycles | # | Mean or median # of radiotherapy cycles
Mn/Md_R | Lookup | Was # radiotherapy cycles reported as a mean value or a median?
Table: Stem Cell Transplant Description (Q3)
Rec# | # | Procite Record Number, primary study citation
type | Lookup | Which type of transplant was studied (autologous or allogeneic)?
BM/PB | Lookup | Which source of stem cells was used in the study?
TBI? | Lookup | Was TBI used as part of the preparative regimen?
MTX? | Lookup | Was methotrexate used as part of the prophylactic regimen to prevent GVHD?
Table: Study Population I (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
BM_Mets | Lookup | Does study include patients with bone marrow metastases of non-hematologic tumors?
Prev_chemoTx | Lookup | Does study include patients previously treated with chemotherapy?
No_cycles | # | Mean or median number of previous cycles
No_regimens | # | Mean or median number of previous chemotherapy regimens
prev_Plat | Lookup | Did any patients have previous exposure to platinum drugs?
Prev_radio | Lookup | Does study include patients previously treated with radiotherapy?
TBI | Lookup | Was patient previously exposed to TBI? (No if only targeted to involved field)
Table: Study Arms Balanced (Q1, Q2, Q3)
rec# | # | Procite Record Number, primary study citation
balanced? | Lookup | Were the study arms well balanced (overall evaluation based on available data)?
how_tested | Lookup | Was balance determined by quantitative (statistical) or qualitative methods (eyeball)?
tumor_type | Lookup | For tumor types in mixed studies, which arm is favored?
age | Lookup | For patient age, which arm is favored?
bone_mets | Lookup | For % of patients with bone metastases, which arm is favored?
No_prev_cycles | Lookup | For mean/median # of previous chemotherapy cycles, which arm is favored?
No_regimens | Lookup | For the # of previous chemotherapy regimens, which arm is favored?
Prev_Plat/non-Plat | Lookup | For the # or % of patients previously treated with platinum agents, which arm is favored?
No_study_cycles | Lookup | For mean/median # chemoTx cycles during study, which arm is favored?
No_study_regimens | Lookup | For # different chemoTx regimens used during study, which arm is favored?
Study_Plat/non-Plat | Lookup | For the # or % of patients treated with platinum during the study, which arm is favored?
dose_intensity | Lookup | For dose intensity of delivered chemoTx (by platelet or ANC counts), which arm is favored?
prev_radioTx | Lookup | For mean/median # of previous radioTx cycles, which arm is favored?
prev_TBI | Lookup | For # or % of patients previously given TBI, which arm is favored?
radioTx_cycles | Lookup | For mean/median # of radioTx cycles on study, which arm is favored?
study_TBI | Lookup | For mean/median # of patients given TBI on study, which arm is favored?
Transf_Dep | Lookup | For # or % of patients transfusion dependent at study entry, which arm is favored?
Hb_entry | Lookup | For mean/median Hb levels at study entry, which arm is favored?
Hb_transf | Lookup | For mean/median Hb levels at transfusion (if trigger not specified), which arm is favored?
PS | Lookup | For mean/median performance scores at study entry, which arm is favored?
Table: Study Population II (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
Tx | Lookup | treatment (Order: Control arm, treatment arm, stratum1 control, stratum 1 treatment, etc.)
Stratum? | Y/N | Enter 'yes' if this record represents data from a subgroup (stratum) of the study
Stratum_desc | Txt | Describe stratum type
percent_trans_dep | # | Percentage of patients who were transfusion dependent at study entry (100% for Q3)
percent_plat | Text | Percentage of patients who were transfusion dependent at study entry (100% for Q3)
Mn/Md | Lookup | Is age of group reported as a mean or median value?
Age | # | Mean or median age for each arm
LL | # | lower limit, age range of each arm
UL | # | upper limit, age range of each arm
SD | # | standard deviation, age range of each arm
No_enrolled | # | number of patients enrolled in each arm
No_evaluable | # | number of patients evaluated in each arm
Exclusions | Y/N | Were all excluded patients accounted for in this study arm?
bsln_Hb | # | baseline value for Hb level of each study arm
SD_bsln_Hb | # | SD of baseline value for Hb level of each study arm
Range_bsln_Hb | Text | Range of baseline Hb value; ENTER ONLY IF NO SD; format: x.x-y.y
Table: Outcomes: Hematologic Parameters (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
PR# | # | Number of patients in each arm who achieved a partial response to EPO
CR# | # | Number of patients in each arm who achieved a complete response to EPO
Overall_resp | # | Overall response rate, calculated as (PR+CR)/N evaluable
p_Overall_resp | p (txt) | p value for the comparison of overall EPO and control arm response rates
Hb_final | # | Final Hb level (in g/dL) of each study arm, if specified
Hb_calc? | Y/N | Were Hb levels calculated from Hct?
Mn/Md? | Lookup | Were Hb levels reported as a mean value or a median?
SD_Hb | # | Enter the standard deviation for final Hb level of each arm
Hb_change | # | Change in Hb level (in g/dL) for each arm over duration of study
SD_Hb_change | # | Enter the standard deviation for the change in Hb level from baseline for each arm
change_calc | Y/N | Was change in Hb level calculated from baseline and final values?
graph? | Y/N | Did study report include a graph of Hb or Hct over time?
p_value | p (txt) | p value for comparison between EPO and control arms for change in Hb levels
Table: Outcomes: Transfusion Use (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
RBC_transf_data? | Y/N | Did study report data on use of RBC transfusions?
N_transf | # | Number of patients in each arm who received RBC transfusion at any time
p_transf | p (txt) | p value for comparison of EPO and control arms for % patients transfused with RBC
dur_RBC_pts | # | Duration in weeks over which #patients transfused was measured
RBC_units | # | Mean or median #RBC units (1unit PRBC=325ml) transfused/pt. over study duration, by study arm
Mn/Md_RBC | Lookup | Was the # RBC units transfused per patient reported as a mean or a median value?
SD_RBC | # | Standard deviation for the # RBC units transfused per patient, by study arm
dur_RBC | # | Duration in weeks over which RBC transfusion use was measured
graph_RBC? | Y/N | Did the study report include a graph of RBC units transfused per patient over time?
mult_times_RBC | Y/N | Did the study report data on RBC units transfused/pt at more than a single time point?
p_RBC | p (txt) | p value for comparison of EPO and control arms for # RBC units transfused
Plt_transf_data? | Y/N | Did study report data on platelet transfusions?
plt_units | # | Mean or median # platelet units transfused per patient over study duration, by study arm
Mn/Md_plt | Lookup | Was the # platelet units transfused per patient reported as a mean or a median value?
SD_plt | # | Standard deviation for the # platelet units transfused per patient, by study arm
dur_plt | # | Duration in weeks over which platelet transfusion use was measured
graph_plt? | Y/N | Did the study report include a graph of platelet units transfused per patient over time?
mult_times_plt | Y/N | Did the study report data on platelet units transfused/pt at more than a single time point?
p_plt | p (txt) | p value for comparison of EPO and control arms for # platelet units transfused
Table: Outcomes: Red Cell/Erythrocyte Engraftment (Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
percent_engraft | # | Percentage of patients who achieved RBC/erythrocyte engraftment, by arm
p_engraft | p (txt) | p value for comparison of EPO and control arms for %patients achieving engraftment
time_engraft | # | Mean or median time (in days) to RBC/erythrocyte engraftment, by arm
Mn/Md? | Y/N | Is the time to engraftment a mean or median value?
sd_time_engraft | # | SD for mean time to RBC/erythrocyte engraftment, by arm
p_time_engraft | p (txt) | p value for comparison of EPO and control arms in the median time to engraftment, by arm
retic_result | Text | Enter retic result by study arm, as defined in Study Definitions
p_retic | Text | p value for comparison of retic results; enter only for EPO-treated study arm
Table: Serum Fe Parameters (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
Fe_protocol? | Y/N | Was iron status monitoring specified in the protocol?
Fe_verified | Y/N | If no iron supplementation, was adequacy of iron stores evaluated by one or more lab tests?
serum_Fe | Lookup | Were serum iron levels used to verify adequacy of iron stores to support hematopoiesis?
ferritin | Lookup | Were serum ferritin level used to verify adequacy of iron stores to support hematopoiesis?
trf_sat | Lookup | Was % transferrin saturation used to verify adequacy of iron stores to support hematopoiesis?
TIBC | Lookup | Was total iron binding capacity used to verify adequacy of iron stores to support hematopoiesis?
Table: Multiple Times (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
Result_desc | Lookup | Select description of result reported
Time1 | # | Enter first intermediate time point
Result1 | # | Enter first intermediate result
Time2 | # | Enter second intermediate time point
Result2 | # | Enter second intermediate result
Time3 | # | Enter third intermediate time point
Result3 | # | Enter third intermediate result
Time4 | # | Enter fourth intermediate time point
Result4 | # | Enter fourth intermediate result
Time5 | # | Enter fifth intermediate time point
Result5 | # | Enter fifth intermediate result
Table: Outcomes: Adverse Events (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
Data? | Y/N | Did study report adverse events data?
No_patients | # | Enter number of patients in the study arm for whom adverse events were reported
hypertension | # | #patients with hypertension, by arm (0 if none, blank if not reported)
rash/irrit/prur | # | #patients with skin rash, irritation, and/or pruritus, by arm (0 if none, blank if not reported)
mortality | # | #patients who died on study, by arm (0 if none, blank if not reported)
DVT/TE | # | #patients with deep-vein thrombosis and/or other thromboembolism, by arm (0 if none, blank if not reported)
hemor/tmbcytpn | # | # patients with hemorrhage and/or thrombocytopenia, by arm (0 if none, blank if not reported)
seizures | # | #patients with seizures, by arm (0 if none, blank if not reported)
other_CV | # | #patients with cardiovascular adverse events other than hypertension, by arm (0 if none, blank if not reported)
inj_site_pain | # | #patients with pain at the injection site, byarm (0 if none, blank if not reported)
fatigue | # | #patients with fatigue, by arm (0 if none, blank if not reported)
withdrawals | # | #patients who withdrew from study due to adverse events, by arm (0 if none, blank if not reported)
any_AE | # | #patients with any adverse event, by arm (0 if none, blank if not reported)
other_rptd? | Y/N | Were other adverse events reported?
other_AE | Txt | For each arm, enter list of other adverse events mentioned in study report
Table: Outcomes: QoL (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
HbBlinding | Y/N | Were patients blinded as to their Hb level prior to QoL assessment?
Max_overall_QoL | # | Enter the maximum possible overall QoL score
Overall_QoL_baseline | # | Enter overall QoL baseline score for the study arm
Overall_QoL_change | # | Enter overall QoL score change during the study for the study arm
p_Overall | p (txt) | Enter p-value for overall QoL change comparing Tx to Ctl arm (Enter only for Tx arm)
Score1_name | Txt | Name the first specific QoL score reported.
Max_score1 | # | Enter the maximum possible score for this QoL measure
Score_baseline | # | Enter baseline score1 for the study arm
Score1_change | # | Enter Score1 change during the study for the study arm
p_Score1 | p (txt) | Enter p-value for Score1 QoL change comparing Tx to Ctl arm (Enter only for Tx arm)
Score2_name | Txt | Name the second specific QoL score reported.
Max_score2 | # | Enter the maximum possible score for this QoL measure
Score2_baseline | # | Enter baseline score2 for the study arm
Score2_change | # | Enter Score2 change during the study for the study arm
p_Score2 | p (txt) | Enter p-value for Score2 QoL change comparing Tx to Ctl arm (Enter only for Tx arm)
Score3_name | Txt | Name the third specific QoL score reported
Max_score3 | # | Enter the maximum possible score for this QoL measure
Score3_baseline | # | Enter baseline score3 for the study arm
Score3_change | # | Enter Score3 change duringf the study for the study arm
p_Score3 | p (txt) | Enter p-value for Score2 QoL change comparing Tx to Ctl arm (Enter only for Tx arm)
Score4_name | Txt | Name the fourth specific QoL score reported
Max_score4 | # | Enter the maximum possible score for this QoL measure
Score4_baseline | # | Enter baseline score4 for the study arm
Score4_change | # | Enter Score4 change over the course of the study for the study arm
p_Score4 | p (txt) | Enter p-value for Score4 QoL change comparing Tx to Ctl arm (Enter only for Tx arm)
tumor_resp | Txt | Was tumor response an independent predictor for change in QoL?
Table: Predictive Factors (Q1, Q2)
Rec# | # | Procite Record Number, primary study citation
Data? | Y/N | Did study report data on predictive factors?
analysis_method | Lookup | How did the study test for significance of factors that predict responses to EPO?
baseline_EPO | # | Significance value for baseline serum EPO level as a predictor of response to EPO treatment
EPO_type | Lookup | Value type used to test for significance of baseline EPO as predictor of response
EPO_change | # | Significance value for change in serum EPO level as response predictor to EPO treatment
EPO_change_type | Lookup | Value type used to test for significance of change in serum EPO levels as response predictor
O/P | # | Significance value for ratio of observed to predicted serum EPO level as response predictor
O/P_type | Lookup | Value type used to test for significance of O/P ratio as response predictor
malig | # | Significance value for tissue or organ site of malignancy as response predictor
malig_type | Lookup | Value type used to test for significance of malignancy site as response predictor
mets | # | Significance value for presence/absence of metastases as response predictor
mets_type | Lookup | Value type used to test for significance of presence/absence of mets as response predictor
severity | # | Significance value for severity of anemia as response predictor
severity_type | Lookup | Value type used to test for significance of severity of anemia as response predictor
name_other | Txt | Name of other response predictor not specified above
other_predict | # | Significance value for ";other predictor" as response predictor
other_predict_type | Lookup | Value type used to test for significance of "other predictor" as response predictor
Table: Outcomes: Miscellaneous (Q1, Q2, Q3)
Rec# | # | Procite Record Number, primary study citation
Rx_group | # | Treatment group; control = 1, treatment arm 1 = 2, etc.
Data? | Y/N | Are data reported for performance status, hospital days, SOB, dyspnea, or angina?
PS_entry | # | For each arm, enter mean score for performance status at study entry
PS_final | # | For each arm, enter mean score for performance status at end of study
p_PS | p (txt) | Enter p value for the comparison between EPO and control arms for PS
hosp_days | # | For each arm, enter mean # days in hospital
SD_hosp_days | # | For each arm, enter standard deviation for # days in hospital
p_hosp_days | p (txt) | Enter p value for the comparison between EPO and control arms for #hospital days
breath | Lookup | For each arm, did shortness of breath improved over study duration?
dyspnea | Lookup | For each arm, did dyspnea on exertion improved over study duration?
angina | Lookup | For each arm, did angina improved over study duration?

3 KEY QUESTION FORMS AND ORDER OF DATA ENTRY

FORM 1: Key Question 1

Included Studies Study Design Characteristics Study Eligibility Criteria Study Eligibility, Other Causes of Anemia Study Definitions Study Epo Treatment Regimen Study Cancer Treatment Regimen Study Population I Study Population II Study Arms Balanced Outcomes: Hematologic Parameters Outcomes: Transfusion Use Serum Fe Parameters Multiple Times Outcomes: Adverse Events Outcomes: QoL Predictive Factors Outcomes: Miscellaneous

FORM 2: Key Question 2

Included Studies Study Design Characteristics Study Eligibility Criteria Study Eligibility, Other Causes of Anemia Study Definitions Study Epo Treatment Regimen Study Population I Study Population II Study Arms Balanced Outcomes: Hematologic Parameters Outcomes: Transfusion Use Serum Fe Parameters Multiple Times Outcomes: Adverse Events Outcomes: QoL Predictive Factors Outcomes: Miscellaneous

FORM 2: Key Question 3

Included Studies Study Design Characteristics Study Definitions Study Epo Treatment Regimen Stem Cell Transplant Description Study Population II Study Arms Balanced Outcomes: Transfusion Use Outcomes: Red Cell/Erythrocyte Engraftment Multiple Times Outcomes: Adverse Events Outcomes: Miscellaneous