# Appendix B. Study Sponsorship

The trials included in this systematic review were classified within each major subject area by source of research support. Using the acknowledgments of support in published papers from each study and/or institutional affiliation of authors, we categorized the trials as having been funded by one of the following:

- Research grants from government or other nonprofit agencies only;
- Pharmaceutical manufacturers only;
- Pharmaceutical manufacturers and nonprofit agency research grants; or
- No sponsorship reported.

Tables B-1 to B-4 summarize sources of sponsorship for included studies of epoetin treatment for anemia in patients with malignancies. Studies identified as "higher quality" trials are indicated in bold font; nonrandomized studies are indicated in italics. To compare significant outcomes for studies with different sources of support, the tables also provide information on the results reported. For each of the most frequently reported outcomes, the tables list p values for studies that found a significant difference in favor of the epoetin-treated arm(s). Blank spaces indicate trials that reported the outcome but either did not conduct or did not report a test for significant differences between study arms.

## Anemia Due To Cancer Therapy

Only 2 of 22 trials (n=113 evaluable patients) reported research grant support solely from government or other nonprofit agencies (Table B-1). Seventeen trials (n=1,139) received either the study drug or research support from a pharmaceutical manufacturer or included an employee of a pharmaceutical manufacturer among the authors. One of these 17 (Markman, Reichman, Hakes, et al., 1993) was supported by research grants from both nonprofit agencies and a drug company. The source of research funding was indeterminate for three trials (n=496 evaluable).

Of the "higher quality" trials, six were sponsored only by pharmaceutical manufacturers and two (one unpublished) were classified as no sponsorship reported.

The evidence does not suggest that the source of research support had a substantial impact on the outcomes reported from these studies. However, the very small number of studies without support from pharmaceutical manufacturers limits the ability to detect a relationship between source of funding and outcomes.

## Anemia Due To Disease

No trials of epoetin for anemia due to malignancy were supported either wholly or in part by research grants from government or other nonprofit agencies (Table B-2). Three trials (n=391 enrolled) received either the study drug or research support from a pharmaceutical manufacturer or included an employee of a pharmaceutical manufacturer among the authors. The other three trials (n=302) did not specify a source of research support.

The evidence does not suggest that the source of research support had a substantial impact on the outcomes reported from these studies. The only trial to report a significant effect of epoetin use on the percentage of patients transfused did not acknowledge support from a manufacturer (Osterborg, Boogaerts, Cimino, et al., 1996). Furthermore, all three of the trials that did not acknowledge manufacturers' support reported significant effects on hematologic responses. However, the very small number of studies limits the ability to detect a relationship between source of funding and outcomes.

## Anemia Following High-Dose Chemotherapy and Stem-Cell Transplantation

### Allogeneic Transplantation

Table B-3 summarizes sources of sponsorship for studies included in this review that address anemia following high-dose chemotherapy and allogeneic stem cell support. Two studies received funding solely from nonprofit agencies (n=45 evaluable patients). Three studies, all higher quality trials, received support from pharmaceutical manufacturers in the absence of any other reported support (n=343). Two studies did not report any source of funding (n=86). Trials supported by pharmaceutical manufacturers did not tend to report results in favor of epoetin compared with results of trials funded by other sources or trials for which funding was not identified. The evidence does not suggest that the source of research support had a substantial impact on the outcomes reported from these studies.

### Autologous Transplantation

Table B-4 summarizes sources of sponsorship for studies included in this review that address anemia following high-dose chemotherapy and autologous stem-cell support. Three studies received funding solely from nonprofit agencies (n=87 evaluable patients). Three studies, including the higher quality trial, received support from a pharmaceutical manufacturer in the absence of any other reported support (n=232). In general, trials supported by pharmaceutical manufacturers did not tend to report results in favor of epoetin where trials funded by other sources or trials for which funding was not identified did not. The evidence does not suggest that the source of research support had a substantial impact on the outcomes reported from these studies.

Table B-1. Sources of research support and statistically significant differences in outcomes: Anemia due to cancer therapy1

Table B-1. Sources of research support and statistically significant differences in outcomes: Anemia due to cancer therapy^1^

Citation | N Enrolled (control+treated) | N Evaluable (control+treated) | Significant Effect on % Responses? | Significant Effect on Hb Change? | Significant Effect on % Transfused? | Significant Effect on RBC U/Patient? | Significant Effect on QoL?
Nonprofit agency research grants only
Silvestris, Romito, Fanelli, et al., 1995 | 54 (24+30) | 51 (22+27) | | NR | NR | NR | NR
Del Mastro, Venturini, Lionetto, et al., 1997 | 62 (31+31) | 62 (31+31) | NR | <0.005 | NS ^2^ | NR | NS
Pharmaceutical manufacturers only
Oberhoff, Neri, Amadori, et al. 1998 | 227 (110+117) | 189 (88+101) | 0.0001 | NR | ^3^ | 0.044 | NR
Sweeney, Nicolae, Ignacio, et al., 1998 | 48 (24+24) | 48 (24+24) | | 0.0012 | NR | NR | NS
Dusenbery, McGuire, Holt, et al., 1994 | 76 (61+15) | 76 (61+15) | NR | 0.001 | | NR | NR
Lavey and Dempsey, 1993 | 40 (20+20) | 40 (20+20) | <0.001 | <0.001 | NR | NR | NR
Porter, Leahey, Polise, et al., 1996 | 24 (12+12) | 20 (10+10) | NR | NR | NS | 0.01 | NR
Quirt, Couture, Pichette, et al., 1996 | 56 (28+28) | 54 (27+27) | NR | | NS ^2^ | | NR
Wurnig, Windhager, Schwameis, et al., 1996 | 30 (14+16) | 29 (14+15) | NR | NS | NS | <0.01 | NR
Leon, Jimenez, Barona, et al., 1998 | 50 (25+25) | 50 (25+25) | NR | <0.001 | <0.001 | <0.001 | <0.05
Henke, Guttenberger, Barke, et al., 1999 | 44 (11+33) | 44 (11+33) | NR | <0.0001 | NR | NR | NR
Varan, Buyukpamukcu, Kutluk, et al., 1999 | 34 (17+17) | 34 (17+17) | NR | | 0.008 | NR | NR
Welch, James, Wilkinson, et al., 1995 | 30 (15+15) | 30 (15+15) | NR | | NS | NS | NS
Kurz, Marth, Windbichler, et al., 1997 | 35 (12+23) | 35 (12+23) | 0.001 | | 0.009 | | NS
Thatcher, De Campos, Bell, et al., 1999 | 130 (44+86) | 130 (44+86) | <0.05 | | <0.05 | <0.01
Case, Bukowski, Carey, et al., 1993 | 157 (76+81) | 153 (74+79) | | 0.0001 | NS^2^ | NS
Henry, Brooks, Case, et al., 1995 | 132 (65+67) | 125 (61+64) | <0.0001 | <0.0001 | NS | NS | 0.013
ten Bokkel Huinink, de Swart, van Toorn, et al., 1998 | 122 (34+88) | 120 (33+87) | NR | NR | ^3^ | | NR
Pharmaceutical manufacturers and non-profit agency grants
Markman, Reichman, Hakes, et al., 1993 | 63 (46+17) | 56 (40+16) | <0.005 | NR | NS | NR | NR
No sponsorship reported
Gamucci, Thorel, Frasca, et al., 1993 | 38 (17+21) | 38 (17+21) | NR | <0.005 | NR | NR | NR
Littlewood, Bajetta, Cella, et al., 1999 | 375 (124+251) | 359 (115+244) | 0.001 | | 0.0168 | NR | <0.01
Cascinu, Fedeli, Del Ferro, et al., 1994 | 100 (50+50) | 99 (49+50) | | | 0.01 | 0.01 | NR

1 Bold print indicates higher quality studies; italics indicate nonrandomized studies.

2 Calculated odds ratio for transfusion suggests no significant difference, as upper limit of 95% confidence interval is >1.0 (see Meta-Analysis).

3 Calculated odds ratio for transfusion suggests a significant difference, as upper limit of 95% confidence interval is <1.0 (see Meta-Analysis).

Table B-2. Research support sources and statistically significant differences in outcomes: Anemia due to malignant disease

Table B-2. Research support sources and statistically significant differences in outcomes: Anemia due to malignant disease

Citation | N Enrolled (control+treated) | N Evaluable (control+treated) | Significant Effect on % Responses? | Significant Effect on Hb Change? | Significant Effect on % Transfused? | Significant Effect on RBC U/Patient? | Significant Effect on QoL?
Pharmaceutical manufacturers only
Cazzola, Messinger, Battistel, et al., 1995 | 146 (29+117) | 146 (29+117) | | | | | NR
Garton, Gertz, Witzig, et al., 1995 | 24 (13+11) | 20 (10+10) | | 0.02 | NR | NR | NR
Rose, Rai, Revicki, et al., 1994 | 221 (80+141) | 221 (80+141) | <0.0001 | <0.0001 | NR | NR | <0.05
No sponsorship reported
Osterborg, Boogaerts, Cimino, et al., 1996 | 144 (49+95) | 121 (39+82) | 0.01 | NS | <0.05 | NS | NR
Dammacco, Silvestris, Castoldi, et al., 1998 | 71 (31+40) | 65 (29+36) | <0.001 | NR | NR | NR | NR
Ital. Coop. Study Group for rHuEpo in MDS, 1998 | 87 (43+44) | 75 (37+38) | 0.007 | NR | NR | NR | NR

Table B-3. Sources of research support and statistically significant differences in outcomes: Anemia following allogeneic HDC/SCS1

Table B-3. Sources of research support and statistically significant differences in outcomes: Anemia following allogeneic HDC/SCS1

Citation | N Enrolled (control+treated) | N Evaluable (control+treated) | Significant Effect, Time to RBC Engraftment? | Significant Effect, Time to Reticulocyte Engraftment? | Significant Effect on RBC Units/Patient?
Allogeneic transplantation
Nonprofit agency research grants only
Vannucchi, Bosi, Linari, et al., 1997 | 20 (10+10) | 20 (10+10) | NS | p<0.01 | p<0.05
Locatelli, Zecca, Pedrazzoli, et al., 1994 | 31 (17+14) | 25 (15+10) | NR | p<0.05 | p<0.001
Pharmaceutical manufacturers only
Klaesson, Ringden, Ljungman, et al., 1994 | 50 (25+25) | 45 (23+22) | p=0.030 | NS | p=0.04
Biggs, Atkinson, Booker, et al., 1995 | 91 (43+48) | 83 (39+44) | p=0.002 | p<0.0005 | NS
Link, Boogaerts, Fauser, et al., 1994 | 215 (109+106) | 215 (109+106) | p=0.003 | p<0.05 | NS
No sponsorship reported
Steegmann, Lopez, Otero, et al., 1992 | 24 (11+13) | 24 (11+13) | NR | p<0.05 | p<0.05
Link, Brune, Hubner, et al., 1993 | 62 (43+19) | 62 (43+19) | p=0.0015 | p=0.0065 | p=0.010

1 Bold print indicates higher quality studies; italics indicate nonrandomized studies.

Table B-4. Sources of research support and statistically significant differences in outcomes: Anemia following autologous HDC/SCS1

Table B-4. Sources of research support and statistically significant differences in outcomes: Anemia following autologous HDC/SCS1

Citation | N Enrolled (control+treated) | N Evaluable (control+treated) | Significant Effect, Time to RBC Engraftment? | Significant Effect, Time to Reticulocyte Engraftment? | Significant Effect on RBC Units/Patient?
Autologous transplantation
Nonprofit agency research grants only
Vannucchi, Bosi, Ieri, et al., 1996 | 20 (10+10) | 20 (10+10) | NS | p<0.05 | NS
Ayash, Elias, Hunt, et al., 1994 | 48 (37+11) | 47 (37+10) | p=0.001 | NR | NS
Locatelli, Zecca, Pedrazzoli, et al., 1994 | 21 (11+10) | 20 (10+10) | NR | NS | NS
Pharmaceutical manufacturers only
Pene, Appelbaum, Fisher, et al., 1993 | 83 (65+18) | 83 (65+18) | NR | NR | NS
Chao, Schriber, Long, et al., 1994 | 35 (17+18) | 35 (17+18) | NR | p=0.48 | p=0.22
Link, Boogaerts, Fauser, et al., 1994 | 114 (57+57) | 114 (57+57) | p=0.77 | NS | NS

^1^Bold print indicates higher quality studies