# Appendix A. Technical Advisory Group External Reviewers Medical Advisory Panel

## Technical Advisory Group

- James O. Armitage, M.D.
- University of Nebraska Medical Center
- Internal Medicine

- Charles Bennett, M.D., Ph.D.
- VA Chicago Health Care Systems
- Member, ASH/ASCO Expert Panel on the Use of Erythropoietin

- Michael S. Gordon, M.D.
- Director, Clinical Hematology and Cytokine Program
- Indiana Cancer Pavilion
- Co-Chair, ASH/ASCO Expert Panel on the Use of Erythropoietin

- Alan E. Lichtin, M.D.
- Hematology/Oncology
- Cleveland Clinic Foundation
- Co-Chair, ASH/ASCO Expert Panel on the Use of Erythropoietin

- James L. Wade, III, M.D.
- Director, Medical Oncology
- Cancer Care Specialists

- Steven Woolf, M.D., M.P.H.
- Associate Clinical Professor
- Fairfax Family Practice
- Member, ASH/ASCO Expert Panel on the Use of Erythropoietin

## Task Order Officer

- Martin Erlichman, M.S.
- Center for Health Care Technology
- AHRQ

## External Expert Reviewers

- John W. Adamson, M.D.
- Blood Research Institute

- Barbara Alving, M.D.
- Director, Division of Blood Diseases and Resources
- National Heart, Lung, and Blood Institute

- Tom Anderson, M.D.
- Division of Hematology/Oncology
- Medical College of Wisconsin
- American Cancer Society

- Joseph H. Antin, M.D.
- Dana-Farber Cancer Institute

- George Browman, M.D., M.Sc.
- Hamilton Regional Cancer Centre
- McMaster University EPC

- Hanan S. Bell, Ph.D.
- Independent Consultant; formerly Clinical Policies Analyst/Co-Director
- American Academy of Family Physicians

- Bruce Camitta, M.D.
- Midwest Children's Medical Center
- The Coalition of National Cancer Cooperative Groups, Inc.

- David Cella, Ph.D.
- Director and Research Professor
- Institute for Health Services Research and Policy Studies
- Northwestern University.
- Member, ASH/ASCO Expert Panel on the Use of Erythropoietin

- Benjamin Djulbegovic, M.D., Ph.D.
- Division of Bone Marrow Transplant
- H. Lee Moffitt Cancer Center
- University of South Florida
- Member, ASH/ASCO Expert Panel on the Use of Erythropoietin

- Diane L. Fairclough, Dr.PH
- Center for Research Methodology & Biometry
- AMC Cancer Research Center

- Suzanne Fleischman, Ph.D.
- Member, ASH/ASCO Expert Panel on the Use of Erythropoietin

- Lawrence Goodnough, M.D.
- Division of Laboratory Medicine
- Washington University Medical Center

- David H. Henry, M.D.
- Pennsylvania Oncology Hematology Associates

- Barbara LeStage, M.H.P
- American Cancer Society

- Mary Pat Lynch, C.R.N.P., M.S.N., A.O.C.N
- Oncology Nursing Society

- Margaret M. McCarthy
- Executive Director
- Alliance for Lung Cancer Advocacy, Support, and Education

- Judy Perotti
- Director, Patient Services
- Y-Me National Breast Cancer Organization (Y-Me)

- Mitchell Slavin, Pharm.D.
- Ortho Biotech, Inc.

- Jerry L. Spivak, M.D.
- Division of Hematology
- The Johns Hopkins University

- Paul J. Wallace, M.D.
- Kaiser Permanente Northwest

## Blue Cross and Blue Shield Association Medical Advisory Panel

- Peter C. Albertsen, M.D.
- University of Connecticut Health Center
- Division of Urology

- James O. Armitage, M.D.
- Internal Medicine
- University of Nebraska Medical Center

- Wade Aubry, M.D. (Chair)
- Blue Cross and Blue Shield Association
- National Medical Consultant

- J. Lawrence Colley, M.D.
- Corporate Medical Director
- Trigon BlueCross BlueShield

- Helen Darling, M.A.
- Practice Leader, Group Benefits & Health Care
- Watson Wyatt & Company

- David M. Eddy, M.D., Ph.D.
- Kaiser Permanente
- Southern California Region
- Scientific Advisor for Health Policy and Management

- Alan M. Garber, M.D., Ph.D.
- Director, PCOR and CHP
- Stanford University

- Michael A. Hattwick, M.D.
- Woodburn Internal Medicine Associates, Ltd.

- I. Craig Henderson, M.D.
- University of California, San Francisco
- Professor of Medicine, Chief of Oncology

- Albert R. Jonsen, Ph.D.
- University of Washington
- Department of Medical History and Ethics

- Peter A. Margolis, M.D., Ph.D.
- Assistant Professor, Department of Pediatrics
- Clinical Assistant Professor, Department of Epidemiology
- Children's Primary Care Research Group

- Barbara J. McNeil, M.D., Ph.D.
- Harvard Medical School
- Department of Health Care Policy

- Richard G. Roberts, M.D., J.D.
- Department of Family Medicine
- University of Wisconsin School of Medicine

- Earl P. Steinberg, M.D., M.P.P.
- Covance Health Economics and Outcomes Services, Inc.

- Clifford Waldman, M.D.
- Medical Director
- Anthem BlueCross & BlueShield

- Paul J. Wallace, M.D.
- Kaiser Permanente Northwest

- Les Zendle, M.D.
- Associate Medical Director
- Kaiser Permanente Southern California