# Appendixes

Appendix A. Technical Advisory Group External Reviewers Medical Advisory Panel

Appendix B. Study Sponsorship

Appendix C. Data Abstraction Form

Appendix D. Acronyms