# Evidence Tables

Evidence Tables

Key to abbreviations used in the evidence tables
AA | Alcoholics Anonymous
ADS | Alcohol Dependence Scale Score
ASI | Addiction Severity Index
B | black
BAC | blood alcohol content
C | content reviewer score
CAH | ca-acetyl-homotaurinate
CDIS | Computerized Diagnostic Interview Schedule
CDT | carbohydrate-deficient transferrin
chg | change
cm | centimeter
CT | controlled trial
CT-R-DB | randomized controlled double blind trial
CT-N-NA | randomized controlled trial-blinding unknown
CX-R-DB | randomized crossover double blind trial
DAC | daily alcohol consumption
detox | detoxification
DER | disulfiram ethanol reaction
DIS | Diagnostic Interview Schedule
dkg | drinking
DSM | Diagnostic and Statistical Manual of Mental Disorders
dx | diagnosis
EOT | end of treatment
excl | excluded
f/l | frequency per liter
g | gram
GGT | gamma-glutamyltransferase
grp | group
H | Hispanic
hx | history
Int | intervention
ITT | intent to treat
IU/l | international unit per liter
M | methodology reviewer score
MAST | Michigan Alcohol Screening Test
MCV | mean corpuscular volume
mEq/l | milliequivalent per liter
mg | milligrams
mm | millimeter
mo(s) | month(s)
NA | not available
NS | not significant
O | other
occ | occasion
OS | ordinal scale
pts | patients
quex | questionnaire
RC | retrospective cohort
RCT | randomized controlled trial
SA | substance abuse
SADQ | Severity of Alcohol Dependence Questionnaire
SD | standard deviation
SE | standard error
SES | socioeconomic status
SQ | subcutaneous
TLFB | Time-Line Follow Back
tx | treatment
VA | Veterans Administration
VAS | visual analog scale
vs. | versus
W | white
w/ | with
WHO | World Health Organization
wks | weeks

Evidence Table 1: Disulfiram study designs[Evidence Tables]

Author, year | Study design and blinding | Alcohol dependence diagnosis and diagnostic instrument | Severity assessment | Detoxified | Abstinence period | Drug intervention | Co-intervention | Length of active trt | Initial/end study population (n) | Percent males initially | Mean age (SD) initially | Race | Co-morbidity | Other SA | Compliance measures | Outcome measures | Relapse definition | Craving measure
Whyte CR, O'Brien PM (1974) | CT-N-NA | Alcoholics | NA | Yes | 6 wks | No drug Int grp 1: Disulfiram: 1000 mg implant | Group and individual therapy during detox only | NA | No drug: 23/NA Int grp 1: 22/NA | Placebo: 100 % Int grp 1: 100 % | Placebo: 45.4 Int grp 1: 40.6 | NA | None | NA | Implant | - unspecified self-report - GGT | NA | NA
Wilson A, Davidson WJ, White J (1976) | CT-R-DB | Alcoholics | NA | NA | NA | Placebo: Saline implant Int grp 1: Disulfiram: 800 mg/implant | NA | NA | Placebo: 10/NA Int grp 1: 10/NA | NA | NA | NA | NA | NA | Implant | - unspecified self-report | NA | NA
Wilson A, Davidson WJ, Blanchard R, et al. (1978) | CT-R-DB | Alcoholics | NA | Yes | NA | Placebo: Saline implant Int grp 1: Disulfiram: 800 mg/implant | NA | 104 wks | Placebo: 10/10 Int grp 1: 10/9 | 80 % | 34.2 (5.3) | NA | NA | NA | Implant for active and placebo | - unspecified self-report | NA | NA
Wilson A, Davidson WJ, Blanchard R, et al. (1980) | CT-R-DB w/2 additional non-randomized, non-blind control grps | Alcoholics | NA | NA | NA | No operation Int grp 1: No medication, participated as if received an implant Int grp 2: Saline implant Int grp 3: Disulfiram: 800 mg/implant | None | 48 wks | No operation 10/10 Int grp 1: 10/10 Int grp 2: 40/29 Int grp 3: 40/29 | 89 % | 36.1 (4.9) | NA | NA | NA | Implant | - unspecified self-report | NA | NA
Fuller RK, Roth HP (1979) Fuller R, Roth H, Long S (1983) | CT-R-DB | Requested alcoholism treatment;> 1 of 6 alcohol-related illnesses | NA | NA | NA | Placebo comparable to int grps Int grp 1: Disulfiram: 1 mg/day Int grp 2: Disulfiram: 500 mg/day for 1 wk then 250 mg/day for remainder of study | Individual counseling encouraged | 52 wks | Placebo: 42/NA Int grp 1: 43/NA Int grp 2: 43/NA | 100 % | 42.6 (8.5) | 61 % (B) | NA | NA | Urine marker in all groups requiring >15 positive tests | - clinical interview - liver function tests - blood alcohol - proxy | NA | NA
Schuckit MA (1985) | CT-N-NA | DSM-III by structured interview with individual and proxy | DAC | NA | NA | No drug Int grp 1: Disulfiram, dose NA | None | 52 wks | No drug: 176/176 Int grp 1: 172/172 | 100 % | Placebo: 47.3 (10.9) Int grp 1: 45.3 (11.5) | NA | None | Yes | NA | - structured interview with individual - structured interview with proxy | NA | NA
Fuller RK, Branchey L, Brightwell DR, et al. (1986) | CT-R Patients knew whether they received disulfiram or not, but did not know dose | Alc dependence dx inst: National Council on Alcoholism | Days drinking in previous month | Yes | <30 days | No drug Int grp 1: 1 mg disulfiram Int grp 2: 250 mg disulfiram | AA; group and individual counseling encouraged | 52 wks | No drug: 199/NA Int grp 1: 204/NA Int grp 2: 202/NA 577 completed the trial | 100 % | No drug: 42.3 (10.3) Int grp 1: 41.5 (10.0) Int grp 2: 41.3 (10.5) | No drug: 56 % (W) 38 % (B) 6 % (O) Int grp 1: 53 % (W) 38 % (B) 9 % (O) Int grp 2: 53 % (W) 37 % (B) 10 % (O) | NA | NA | - riboflavin marker with compliance requiring >15 positive urines - diethylamine in int grp 2 | NA | NA | NA
Johnsen J, Stowell A, Bache-Wiig JE, et al. (1987) | CT-R-DB | Alcoholic by clinical interview | MAST | NA | NA | Placebo comparable to int grps Int grp 1: Disulfiram: 1000 mg | None | 20 wks | Placebo: 11/11 Int grp 1: 10/10 | NA | Placebo: 36.8 (10.0) Int grp 1: 42.8 (14.2) | NA | None | NA | Implant | - unspecified self-report - breath alcohol test - GGT | NA | NA
Johnsen J, Morland J (1991) | CT-R-DB | DSM-III Instrument NA | MAST and SADQ | NA | NA | Placebo implant comparable to int grps Int grp 1: Disulfiram: 1000 mg implant | NA | 40 wks | Placebo: 36/30 Int grp 1: 40/33 | NA | Placebo: 42.7 Int grp 1: 41.7 | NA | None | NA | Implant | - unspecified self-report - GGT | NA | NA
Chick J, Gough K, Falkowski W, et al. (1992) | CT-R-DB Study assessor remained blinded, patient unblinded | NA | SADQ | NA | NA | Placebo (100 mg vit. C) comparable to int grps Int grp 1: Disulfiram: 200 mg/day | AA; group, individual, and family counseling encouraged | 24 wks | Placebo: 62/33 Int grp 1: 64/36 | 84 % | 43 | NA | None | No | - self-report and proxy - administered under supervision | - unspecified self-report - SADQ - weekly diary - GGT - MCV | NA | NA
Bischof T, Bucher J, Battig B, et al. (1995) | RC | Alcoholics | NA | Yes | 7 days | Control: No drug Int grp 1: 1200 mg/day during last 3 days of detox only | 40 % of control and int grp 1 given counseling, with 71 % of counseled patients followed by an alcohol social worker and 29 % by primary care physician | NA | Entire pop: 67/58 Placebo: NA/12 Int grp 1: NA/46 | 64 % | 40 (NA) | NA | NA | NA | NA | - social worker/ physician completed quex collecting psychosocial assessment, duration of abstinence, and disulfiram use | NA | NA

Evidence Table 2: Disulfiram study outcomes[Evidence Tables]

Author, year | Standard drinks | Drinking/nondrinking Days | Episodes of heavy drinking | Patients who resumed drinking | Time to first drink | Craving | Relapse over course of treatment | GGT/MCV/CDT | Compliance with treatment | Conclusions | Subgroup and followup analyses | Limitations | Quality score
| Disulfiram
| Yes | No
Whyte CR, O'Brien PM (1974) | NA | NA | NA | NA | Placebo: 1.9 mos Int grp 1: 5.4 mos p<.001 | NA | NA | NA | NA | Based on only one outcome, int showed efficacy over placebo | NA | - not a randomized trial - alcohol consumption unverified | C=29 M=39
Wilson A, Davidson WJ, White J (1976) | NA | NA | NA | Placebo: 60 % Int grp 1: 50 % p=NA | Placebo: 81 days Int grp 1: 109 days p=NA | NA | NA | NA | NA | Int did not show efficacy over placebo | Analysis based on longest interval of abstinence. Both sham and disulfiram show reduction in this measure (no p-values given) but analysis of covariance showed no difference between sham and disulfiram group. | - alcohol dependence criteria not specified - no patient description - no significance testing - no clear statement of treatment | C=33 M=19
Wilson A, Davidson WJ, Blanchard R, et al. (1978) | NA | NA | NA | NA | NA | NA | NA | NA | NA | Int did not show efficacy over placebo (7 patients w/implant experienced DER) | NA | - small sample - sample consisted of 17 Skid Row persons and 3 from higher SES - statistical tests given with no outcome data provided | C=27 M=25
Wilson A, Davidson WJ, Blanchard R, et al. (1980) | NA | Nondrinking days: No operation controls: 24 Pseudo controls: 31 Placebo implant: 307 Disulfiram implant: 361 p<.05 for Disulfiram vs. placebo | NA | No operation controls: 100 % Pseudo controls: 100 % Placebo implant: 69 % Disulfiram implant: 58.6 % p=NA | NA | NA | NA | NA | NA | Disulfiram implant showed efficacy over placebo implant | NA | - appears to be pharmacological effect but unable to detect circulating disulfiram in the blood - alcohol consumption unverified - sample heavily weighted to Skid Row | C=56 M=25
Fuller RK, Roth HP (1979) Fuller R, Roth H, Long S (1983) | NA | Median percent drinking days during the year: Placebo: 37 % Int grp 1: 32 % Int grp 2: 31 % p=NS | NA | Placebo: 88 % at 12 mos Int grp 1: 75 % at 12 mos Int grp 2: 79 % at 12 mos p=NS | NA | NA | NA | NA | Placebo: 50 % by urine marker Int grp 1: 67 % by urine marker Int grp 2: 57 % by urine marker | Int did not show efficacy over placebo | Additional analyses showed that those who abstained were more compliant with treatment than those who were nonabstainers. p<.02 | - alcohol consumption unverified - sample is poorly described - dropout rate unclear | C=77 M=46
Schuckit MA (1985) | Placebo: Start: 15.3 per drinking day (SD: 8.89) End: 15.6 per drinking day (SD: 12.21) Int grp 1: Start: 14.7 per drinking day (SD: 9.4) End: 13.6 per drinking day (SD: 9.46) p=NS | Drinking days per month: Placebo: Start: 24.3 (SD: 8.7) End: 17.6 (SD: 11.4) Int grp 1: Start: 23.3 (SD: 9.0) End: 19.1 (SD: 11.3) p=NS | NA | NA | NA | NA | NA | NA | NA | Int did not show efficacy over placebo | NA | - not a randomized trial | C=86 M=51
Fuller RK, Branchey L, Brightwell DR, et al. (1986) | NA | Drinking days: No drug: 86.5 (SD: 13.6) Int grp 1: 75.4 (SD: 11.9) Int grp 2: 49.0 (SD: 8.4) Int grp 2 vs. pooled no-drug and int grp 1: p=.05 | NA | No drug: 83.9 Int grp 1: 77.5 Int grp 2: 81.2 p=NS | No drug: 40.7 days (SD: 6.2) Int grp 1: 65.0 days (SD: 36.2) Int grp 2: 54.2 days (SD: 7.5) p=NS | NA | NA | NA | No drug: 18 % Int grp 1: 17 % Int grp 2: 23 % | Disulfiram was not effective in aiding patients to remain completely abstinent or delaying time to first drink: - there was a significant reduction in total drinking days | NA | - compliance with therapy was low in all treatment groups | C=89 M=86
Johnsen J, Stowell A, Bache-Wiig JE, et al. (1987) | Placebo: Start: 186.5 grams/day (SD: 91.3) End: 119.9 grams/day (47.7) Int grp 1: Start: 208.8 grams/day (SD: 150.9) End: 146.3 grams/day (SD: 84.1) p=NS | Moderate drinking weeks per year: Placebo: Start: 24.3 (SD: 19.6) End: 8.5 (SD: 4.2) Int grp 1: Start: 22.5 (SD: 17.2) End: 4.0 (SD: 4.9) p=NS | Placebo: Start: 18.9 (SD: 15.0) End: 4.7 (SD: 4.2) Int grp 1: Start: 20.3 (SD: 15.9) End: 7.0 (SD: 4.8) p=NS | NA | Placebo: 37.4 days (SD: 38.7) Int grp 1: 49.9 days (SD: 36.8) p=NS | NA | NA | GGT Placebo: Start: 54.3 (SD: 55.5) End: 45.6 (SD: 54.8) Int grp 1: Start: 81.2 (59.9) End: 68.8 (39.8) p=NS | NA | Int did not show efficacy over placebo: - implant does not have any pharmacological effect | NA | - small sample size - large individual differences - poor description of sample and co-intervention - placebo and int grp differed at baseline for GGT | C=64 M=56
Johnsen J, Morland J (1991) | Placebo: Start: 89.9 grams/day End: 32.8 grams/day Int grp 1: Start: 63.6 grams/day End: 31.7 grams/day p=NS | Nondrinking weeks: Placebo: 29.7 Int grp 1: 25.6 p=NA | Placebo: 3.5 hard drinking wks Int grp 1: 3.5 hard drinking wks p=NA | Placebo: End: 80 % Int grp 1: 81.8 % p=NA | Placebo: 149 days Int grp 1: 148 days p=NA | NA | NA | MCV (f1) Placebo: Start: 92 (86-102) End: 93 (85-109) Int grp 1: Start: 94 (84-103) End: 92 (85-112) p=NS GGT (mean) Placebo: Start: 81 (13-728) End: 58 (8-339) Int grp 1: Start: 63 (9-876) End: 43 (7-210) p<.02 | NA | Int did not show efficacy over placebo: - both groups improved from baseline | NA | - population consisted of those who wanted an implant | C=75 M=66
Chick J, Gough K, Falkowski W, et al. (1992) | Placebo: Start: 190 units/wk (SD: 153) Chg: -97 (SD: 148) Int grp 1: Start: 207 units/wk (SD: 137) Chg: -165 (SD: 173) p=.05 | Nondrinking days: Placebo: Start: 77 (SD: 53) Chg: 54 (SD: 79) Int grp 1: Start: 58 (SD: 59) Chg: 98 (SD: 68) p=.004 | NA | NA | NA | NA | NA | MCV Placebo: Start: 97.8 (SD: 5.8) Chg: -2.6 (4.5) Int grp 1: Start: 96.6 (SD: 5.8) Chg: -3.0 (5.1) p=NS GGT Placebo: Start: 51 (SD: 72) Chg: +13 (SD: 83) Int grp 1: Start: 49 (SD: 63) Chg: -21 (65) p=.02 | NA | Int showed efficacy over placebo: - fewer units per wk - more nondrinking days - improved GGT | NA | - high dropout rate - blind broken for patients after randomization | C=68 M=76

Evidence Table 3(a): Disulfiram study side effects[Evidence Tables]

Side effects ^*^ | Sample size (total) | Active (%) | Placebo (%) | Statistical significance | Method of assessment ^**^ | Author and date
Gastrointestinal
Nausea | 119 | 3.3 | 3.4 | NA | 6 | Chick J, Gough K, Falkowski W, et al. (1992)
Nausea | 30 | -23 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Stomach ache | 158 | 31.0 | 21.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Constipation | 158 | 18 | 15 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Constipation | 30 | -7 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Diarrhea | 158 | 11.0 | 9.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Diarrhea | 30 | -23 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Heartburn | 158 | 20.0 | 19.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Heartburn | 30 | -8 ^**^ | -12 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Musculoskeletal
- Stiffness of neck | 158 | 28.0 | 15.0 | p=.003 | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Muscular pain | 158 | 28.0 | 37.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Muscular pain | 30 | -16 ^**^ | -18 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Central nervous system/psychiatric
Drowsiness | 30 | +12 ^**^ | -6 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Drowsiness | 605 | 8.0 | 2.0 | p=.03 | 5 | Fuller RK, Branchey L, Brightwell DR, et al. (1986) / Branchey L, Davis W, Lee KK, et al. (1987)
Sleep disturbance | 158 | 34.0 | 33.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Headache | 30 | -30 ^**^ | +6.0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Headache | 119 | 18.3 | 8.4 | NA | 6 | Chick J, Gough K, Falkowski W, et al. (1992)
Headache | 158 | 46.0 | 29.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Dizziness | 158 | 29.0 | 29.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Light-headedness | 30 | -7 ^**^ | -8 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Heavy-headedness | 30 | +8 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Loss of interest | 30 | 0 ^**^ | -12 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Psychiatric complications | 605 | 2.5 | 1.5 | NS | 5 | Fuller RK, Branchey L, Brightwell DR, et al. (1986) / Branchey L, Davis W, Lee KK, et al. (1987)
Depression | 119 | 6.7 | 8.4 | NA | 6 | Chick J, Gough K, Falkowski W, et al. (1992)
Poor memory | 158 | 48.0 | 39.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Poor memory | 30 | 0 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Trouble thinking | 30 | 0 ^**^ | +6 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Cardiovascular
Palpitations | 158 | 24. 0 | 19.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Dermatologic
Rash | 119 | 6.7 | NA | NA | 6 | Chick J, Gough K, Falkowski W, et al. (1992)
Rash | 30 | 0 ^**^ | +6 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Itching | 158 | 46.0 | 53.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Spots | 158 | 33.0 | 33.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
Genitourinary
- Sexual dysfunction | 158 | 14.0 | 28.0 | p=.037 | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Decreased sexual desire | 30 | +8 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Increased urination | 30 | 0 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Respiratory
- Shortness of breath | 158 | 27.0 | 24.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Shortness of breath | 30 | +7 ^**^ | 0 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Miscellaneous
- Appetite loss | 30 | +31 ^**^ | -12 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Fatigue | 119 | 20.0 | 10.2 | NA | 6 | Chick J, Gough K, Falkowski W, et al. (1992)
Fatigue | 158 | 52.0 | 67.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Taste disturbance | 158 | 24.0 | 17.0 | p=.09 | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Taste disturbance | 30 | -23 ^**^ | -6 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
Tremors | 35 | 3.5 | 5.6 | NA | 1 | Ling W, Weiss DG, Charuvastra VC, et al. (1983)
- Runny nose | 158 | 24.0 | 28.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Hardness of hearing | 158 | 24.0 | 19.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Sight disorders | 158 | 27.0 | 19.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Sight disorders | 30 | -15 ^**^ | -6 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Sore eyes | 30 | -23 ^**^ | -12 ^**^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Buzzing in ears | 158 | 14.0 | 13.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Dry mouth | 158 | 22.0 | 23.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Bad breath | 158 | 23.0 | 17.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Bad breath | 30 | -15 ^**^ | -12 ^***^ | NA | 2,4 | Snyder S, Keeler M (1981)
- Other touch disorders | 158 | 11.0 | 13.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Watering eyes | 158 | 17 | 19 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)
- Body odor | 158 | 18.0 | 13.0 | NS | 1 | Christensen JK, Ronsted P, Vaag UH (1984)

* Side effect categories are not mutually exclusive, since some patients may have experienced more than one side effect.

** Method of assessment:

1 Interviewer-administered side-effect checklist.
2 Self-administered side-effect checklist.
3 Open-ended question asked at each visit.
4 Investigator observed at each visit.
5 Spontaneous reporting by patient.
6 Not specified.

*** Treatment emergent side effect; change compared to baseline.

NA = not available. NS = not significant.

Evidence Table 3(b): Disulfuram study withdrawals[Evidence Tables]

Author and date | Sample size (total) | Reason for withdrawal | Active (%) | Placebo (%)
Withdrawals due to side effects ^*^
Chick J, Gough K, Falkowski W, et al. (1992) | 126 | Dizziness and nausea Possible neuropathy Skin rash | 3.1 1.6 3.1 | 0.0 0.0 0.0

* Withdrawals due to side effects are not always mutually exclusive categories, since some patients may experience more than one side effect.

Evidence Table 4: Opiate antagonists (naltrexone and nalmefene) study designs[Evidence Tables]

Author, year | Study design and blinding | Alcohol dependence diagnosis and diagnostic instrument | Severity assessment | Detoxified | Abstinence period | Drug intervention | Co-intervention | Length of active trt | Initial/end study population (n) | Percent males initially | Mean age (SD) initially | Race | Co-morbidity | Other SA | Compliance measures | Outcome measures | Relapse definition | Craving measure
O'Malley SS, Jaffe AJ, Chang G, et al. (1992) O'Malley SS, Jaffe AJ, Chang G, et al. (1996) O'Malley SS, Jaffe AJ, Rode S, et al. (1996) | CT-R-DB | DSM-III-R by structured interview with individual | ASI | NA | 7-30 days | Placebo comparable to int grps Int grp 1: Naltrexone: 50 mg/day | Individual counseling: Coping (C) Supportive (S) | 12 wks | Placebo (C): 25/15 Placebo (S): 27/16 Int grp 1 (C): 29/19 Int grp 1 (S): 23/18 | 74 % | 40.5 (9.7) | 93 % (W) | None | No | Urine marker for all grps | - unspecified self-report - TLFB - proxy | >5 drinks/occ for men >4 drinks/occ for women | 20 pt VAS
Volpicelli JR, Alterman AI, Hayashida M, et al. (1992) Volpicelli JR, Watson NT, King AC, et al. (1995) O'Brien CP, Volpicelli LA, Volpicelli JR (1996) Volpicelli JR, Clay KL, Watson NT, et al. (1995) | CT-R-DB | DSM-III-R by clinical interview | MAST and 5 DSM criteria | Yes | < 21 days | Placebo comparable to int grps Int grp 1: Naltrexone: 50 mg/day | Group and individual counseling | 12 wks | Placebo: 35/20 Int grp 1: 35/24 | 100% | Placebo: 43.3 (9.0) Int grp 1: 43.5 (9.3) | Placebo: 17 % (W) 83 % (B) Int grp 1: 24 % (W) 74 % (B) 2 % (H) | None | No | NA | - structured interview with individual - breath alcohol test - GGT | >5 drinks/occ >5 days/wk Breath alcohol content | 10 pt VAS
Mason BJ, Ritvo EC, Morgan RO, et al. (1994) | CT-R-DB | DSM-III-R by DIS and ADS | ADS | NA | NA | Placebo comparable to int grps Int grp I: Nalmefene: 10 mg/day Int grp 2: Nalmefene 40 mg/day | AA encouraged | 12 wks | Placebo: 7/2 Int grp 1: 7/3 Int grp 2: 7/3 | 74 % | 42.0 (9.4) | 91 % (W) 9 % (H) | None | No | Pill count >75 % for 2 consecutive visits for all grps | - TLFB - drinking diary - breath alcohol test | >5 drinks/day >5 days/wk | 10 pt VAS
Volpicelli JR, Rhines KC, Rhines JS, et al. (1997) | CT-R-DB | DSM-III-R by clinical interview | NA | Yes | <21 days | Placebo comparable to int grps Int grp 1: Naltrexone: 50 mg/day | Individual counseling | 12 wks | Placebo: 49/36 Int grp 1: 48/35 | Placebo: 82 % Int grp 1: 74 % | Placebo: 37.9 (8.5) Int grp 1: 39.0 (9.0) | Placebo: 40 % (W) 2 % (B) 58 % (O) Int grp 1: 35 % (W) 6 % (B) 59 % (O) | None | No | Pill count and self-report for all grps | - structured interview with individual - breath alcohol test - GGT | 5 drinks/occ Breath alcohol content | 10 pt VAS

Evidence Table 5: Opiate antagonists (naltrexone and nalmefene) study outcomes[Evidence Tables]

Author, year | Standard drinks | Drinking/nondrinking days | Episodes of heavy drinking | Patients who resumed drinking | Time to first drink | Craving | Relapse over course of treatment | GGT/MCV/CDT | Compliance with treatment | Conclusions | Subgroup and followup analyses | Limitations | Quality score
O'Malley SS, Jaffe AJ, Chang G, et al. (1992) O'Malley SS, Jaffe AJ, Chang G, et al. (1996) O'Malley SS, Jaffe AJ, Rode S, et al. (1996) | Drinks per drinking day: Placebo (C): 7.1 (SD: 1.0) Placebo (S): 6.5 (SD: 1.0) Int grp (C): 3.7 (SD: 1.2) Int grp (S): 6.4 (SD: 1.5) p=NS p<.05, medication by therapy condition for completers only | Percent drinking days: Placebo (C): End: 10.4 % (SD: 1.9) Placebo (S): End: 9.4 % (SD: 1.8) Int grp (C): End: 4.2 % (SD: 1.9) Int grp (S): End: 4.3 % (SD: 2.3) p<.01 | NA | Placebo (C): 79 % Placebo (S): 81 % Int grp (C): 72 % Int grp (S): 39 % p=.01 | NA | Craving in the past wk: Placebo (C): 5.3 (SD: .8) Placebo (S): 4.7 (SD: .8) Int grp (C): 3.1 (SD: .8) Int grp (S): 4.4 (SD: .9) p=NS p<.01, medication by therapy condition for completers only | Int grp (C) vs. Placebo (C): RR=.36 Int grp (S) vs. Placebo (S): RR=.28 Both Int grp (C) and Int grp (S) had a rate of relapsing that was 1/3 that of Placebo (C) Placebo (S) vs. Placebo (C): RR=.87 The rate of relapsing was about equal in both placebo groups p=.007 | NA | Placebo: 78 % by urine marker Naltrexone: 92 % by urine marker p<.05 | Efficacy partially dependent on psychotherapy Naltrexone groups had fewer episodes of heavy drinking than the placebo groups: - reduced relapse rates - fewer drinking days - evidence of enhanced abstinence as a function of psychosocial therapy - less craving after drinking | Six-month followup analysis: Patients who reported heavy drinking (>5 for men, >4 for women): Placebo (C): 80 % Placebo (S): 75 % Int grp (C): 43 % Int grp (S): 68 % p<.05 Patients who resumed drinking: Placebo (C): 95 % Placebo (S): 75 % Int grp (C): 76 % Int grp (S): 79 % p=NS Subgroup analysis of the 43 who lapsed: Craving Placebo (co-interventions combined): Before lapse: 11.7 (SD: 4.3) During lapse: 10.5 (SD: 4.1) After lapse: 5.0 (SD: 4.3) Naltrexone (co-interventions combined): Before lapse: 7.1 (SD: 4.6) During lapse: 7.3 (SD: 3.9) After lapse: 2.7 (SD: 4.2) p<.01 Drank until met relapse criterion Placebo: 81 % Naltrexone: 50 % p<.05 | - small sample size | C=91 M=85
Volpicelli JR, Alterman AI, Hayashida M, et al. (1992) Volpicelli JR, Watson NT, King AC, et al. (1995) O'Brien CP, Volpicelli LA, Volpicelli JR (1996) Volpicelli JR, Clay KL, Watson NT, et al. (1995) | NA | Drinking days/wk: Placebo: Start: .06 (SD: .13) End: .57 Int grp 1: Naltrexone: Start: .02 (SD: .07) End: .11 p<.03 | NA | Placebo: 57 % Int grp 1: Naltrexone: 46 % p=NS | NA | Placebo: Start: 3.08 (SD: 2.69) End: 3.42 Int grp 1: Naltrexone: Start: 2.54 (SD: 2.06) End: 1.41 p<.01 | Placebo: 54 % Int grp 1: Naltrexone: 23 % p<.01 | GGT: Placebo: Start: 180.1 (SD: 243.8) End: 127.3 (SD:221.7) Int grp 1: Start: 139.9 (SD: 266.5) End: 51.4 (SD: 36.6) p=NS | NA | Int showed efficacy over placebo: - less drinking days per wk - lower craving - less relapse | Second analysis with 29 addit'l subjects showed: - compliant subjects had improved outcome regardless of treatment. But positive naltrexone effect only noted in compliant subjects. - naltrexone did not affect number who sampled alcohol but did reduce the number who went on to excessive drinking. Of the 36 who relapsed, 29 provided information about first lapse: Reported less alcohol high: Placebo: 12 % Int grp 1: 58 % p=.006 Drank until met relapse criterion: Placebo: 65 % Int grp 1: 17 % p<.05 | - alcohol consumption unverified - small sample size - high dropout rate - difference between groups at baseline drinking days - compliance not measured | C=98 M=82
Mason BJ, Ritvo EC, Morgan RO, et al. (1994) | Drinks/drinking day: Placebo: Start: 3.2 (SD: 2.1) End: 3.0 (SD: 2.3) Int grp 1: Nalmefene 10 mg: Start: 6.6 (SD: 2.9) End: 4.7 (SD: 2.5) Int grp 2: Nalmefene 40 mg: Start: 5.1 (SD: 4.2) End: 3.4 (SD: 3.4) p=NS | Nondrinking days/wk: Placebo: Start: 3.5 (SD: 2.8) End: 4 (SD: 2.9) Int grp 1: Nalmefene 10 mg: Start: 1.8 End: 2.4 (SD: 2.1) Int grp 2: Nalmefene 40 mg: Start: 3.1 (SD: 2.6) End: 4.7 (SD: 2.2) p=NS | NA | NA | NA | Placebo: Start: .2 (SD: .4) End: 0 (SD: .1) Int grp 1: Nalmefene 10 mg: Start: 1.7 (SD: 2.3) End: .2 (SD: .7) Int grp 2: Nalmefene 40 mg: Start: .8 (SD: 1.0) End: .3 (SD: .8) p=NS | Placebo: 67 % Int grp 1: Nalmefene 10 mg: 100 % Int grp 2: Nalmefene 40 mg: 29 % p<.05 | | Placebo: 100 % by pill count Int grp 1: Nalmefene 10 mg: 100 % by pill count Int grp 2: Nalmefene 40 mg: 100 % by pill count p=NA | Int grp 2 showed efficacy over placebo: - less relapse over course of treatment | | - very small sample size - no structured psychosocial therapy - high dropout rate | C=68 M=68
Volpicelli JR, Rhines KC, Rhines JS, et al. (1997) | NA | Drinking days: Placebo: End: 10.76 % (SD: 2.32) Int grp 1: Naltrexone: End: 6.2 % (SD: 1.59) p=NS | NA | Placebo: End: 65.3 % Int grp 1: Naltrexone: End: 56.3 % p=NS | NA | Placebo: End: 3.14 (SD .39) Int grp 1: Naltrexone: End: 2.79 (SD: .34) p=NS | Placebo: 53.1 % Int grp 1: Naltrexone: 35.4 % p=NS | GGT: Placebo: Start: 78.6 (SD: 97.7) End: 66.2 (SD: 15.0) Naltrexone: Start: 66.4 (SD: 69.0) End: 45.1 (SD: 7.4) p=.03 | Placebo: 47 % Int grp 1: Naltrexone: 58 % p=NA | Efficacy dependent on compliance (see subgroup analysis) | Subgroup analysis: - for medication-compliant patients there was significantly less relapse: Placebo: 52.2 Int grp 1: 14.3 p=.002 - % days drinking Placebo: 11.0 Int grp 1: 2.83 p=.01 - treatment completers had significantly less relapse: Placebo: 53 % Int grp 1: 26 % p=.02 - treatment completers had a lower % of drinking days: Placebo: 12.66 (SD: 2.99) Int grp 1: 5.40 (SD: 1.78) p=.02 | - high dropout rate - alcohol consumption unverified | C=97 M=92

Evidence Table 6(a): Opiate antagonists study side effects[Evidence Tables]

Side effects ^*^ | Sample size (total) | Active (%) | Placebo (%) | Statistical significance | Method of assessment ^**^ | Author and date
Naltrexone
Gastrointestinal
Nausea | 36 | 18.8 | 15.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
Nausea | 99 | 13.0 | 4.4 | NS | 1 | Volpicelli JR, Clay KL, Watson NT, et al. (1995)
Nausea | 97 | 32.7 | 13.7 | p<.05 | 1 | O'Malley SS, Jaffe AJ, Chang G, et al. (1992)
Nausea | 738 | 9.8 | 0.0 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Vomiting | 36 | 6.3 | 0.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
Vomiting | 99 | 0.0 | 2.2 | NS | 1 | Volpicelli JR, Clay KL, Watson NT, et al. (1995)
Vomiting | 738 | 2.6 | 0.0 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Musculoskeletal
Joint pain | 36 | 31.0 | 20.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
Joint pain | 70 | 2.9 | NA | NA | 3 | Volpicelli JR, Alterman AI, Hayashida M, et al. (1992)
Central nervous system/psychiatric
- Anxiety or nervousness | 36 | 31.0 | 30.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
- Anxiety or nervousness | 99 | 16.7 | 17.8 | NS | 1 | Volpicelli JR, Clay KL, Watson NT, et al. (1995)
- Anxiety or nervousness | 738 | 3.8 | 0.0 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Dizziness | 97 | 34.7 | 15.7 | p<.05 | 1 | O'Malley SS, Jaffe AJ, Chang G, et al. (1992)
Dizziness | 738 | 4.4 | 0.4 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Headaches | 36 | 25.0 | 25.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
Headaches | 99 | 20.4 | 11.1 | NS | 1 | Volpicelli JR, Clay KL, Watson NT, et al. (1995)
Headaches | 738 | 6.6 | 1.7 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Sleep disturbance | 36 | 44.0 | 35.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
Sleep disturbance | 738 | 3.0 | 0.0 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Genitourinary
Increased sexual desire | 99 | 14.8 | 15.6 | NS | 1 | Volpicelli JR, Clay KL, Watson NT, et al. (1995)
Increased sexual desire | 97 | 35.0 | 18.0 | p=.06 | 1 | Volpicelli JR, Rhines KC, Rhines JS, et al. (1997)
Miscellaneous
Fatigue | 36 | 31.0 | 25.0 | p >.05 | 2 | Oslin D, Liberto JG, O'Brien J, et al. (1997)
Fatigue | 738 | 3.6 | 0.4 | NA | 4,5 | Croop RS, Faulkner EB, Labriola DF (1997)
Weight loss | 97 | 24.5 | 7.8 | p<.05 | 1 | O'Malley SS, Jaffe AJ, Chang G, et al. (1992)
Nalmefene
Gastrointestinal
Nausea | 21 | 28.6 | NA | NA | 6 | Mason BJ, Ritvo EC, Morgan RO, et al. (1994)
Central nervous system/psychiatric
Sleep disturbance | 21 | 35.7 | NA | NA | 6 | Mason BJ, Ritvo EC, Morgan RO, et al. (1994)
Headaches | 21 | 42.9 | NA | NA | 6 | Mason BJ, Ritvo EC, Morgan RO, et al. (1994)
Dermatologic
Rash | 21 | 7.1 | NA | NA | 6 | Mason BJ, Ritvo EC, Morgan RO, et al. (1994)

* Side effect categories are not mutually exclusive, since some patients may have experienced more than one side effect.

** Method of assessment:

1 Interviewer-administered side-effect checklist.
2 Self-administered side-effect checklist.
3 Open-ended question asked at each visit.
4 Investigator observed at each visit.
5 Spontaneous reporting by patient.
6 Not specified.

NA = not available. NS = not significant.

Evidence Table 6(b): Opiate antagonists study withdrawals [Evidence Tables]

Author and date | Sample size (total) | Reason for withdrawal | Active (%) | Placebo (%)
Withdrawals due to side effects ^*^
Naltrexone
O'Malley SS, Jaffe AJ, Chang G, et al. (1992) | 104 | Nausea and dizziness Headache | 9.6 0.0 | 0.0 1.9
Volpicelli JR, Alterman AI, Hayashida M, et al. (1992) | 70 | Nausea | 5.7 | 0.0
Volpicelli JR, Rhines KC, Rhines JS, et al. (1997) | 71 | Side effect (Total) Nausea | 5.7 5.7 | 2.8 0.0
Oslin D, Liberto JG, O'Brien J, et al. (1997) | 72 | Side effect (NOS) | 0.0 | 2.8
Croop RS, Faulkner EB, Labriola DF (1997) | 738 | Side effect (Total) Anxiety/nervousness Depression Nausea Headache Dizziness Fatigue Abnormal liver tests Syncope Vomiting | 15.0 3.8 0.0 6.0 3.0 3.0 1.9 0.6 0.0 1.9 | 3.0 0.0 0.4 0.0 0.0 0.0 0.0 0.0 0.4 0.0
Nalmefene
Mason BJ, Ritvo EC, Morgan RO, et al. (1994) | 21 | Side effect (Total) Rash Dizziness | 21.4 7.1 14.3 | 57.1 0.0 3

* Withdrawals due to side effects are not always mutually exclusive categories, since some patients may experience more than one side effect.

NOS = not otherwise specified.

Evidence Table 7: Acamprosate study designs[Evidence Tables]

Author, year | Study design and blinding | Alcohol dependence diagnosis and diagnostic instrument | Severity assessment | Detoxified | Abstinence period | Drug intervention | Co-intervention | Length of active trt | Initial/end study population (n) | Percent males initially | Mean age (SD) initially | Race | Co-morbidity | Other SA | Compliance measures | Outcome measures | Relapse definition | Craving measure
Gerra G, Caccavari R, Delsignore R, et al. (1992) | CX-R | DSM-III-R Instrument NA | NA | NA | NA | Placebo comparable to int grp Int grp 1: Acamprosate: 1332 mg/day | Weekly meetings | 4 wks for each treatment | 28/NA | 64.3 % | 43.5 (NA) | NA | None | No | NA | - unspecified self-report - proxy | NA | Four 5 pt scales for interest, desire, liking,& intoxication
Ladewig D, Knecht T, Leher P, et al. (1993) | CT-R-DB | DSM-III-R Instrument NA | MAST | Yes | 5 days | Placebo comparable to int grps Int grp 1: Acamprosate: 6 tabs/day (Dose NA) | NA | 24 wks | Placebo: 32/NA Int grp 1: 29/NA | NA | NA | NA | None | NA | None | - structured interview with individual - clinical observation - GGT | Any alcohol consumption | Not measured
Paille FM, Guelfi JD, Perkins AC, et al. (1995) | CT-R-DB | DSM-III-R by clinical observation/ interview | Standard drinks and duration of consumption | Yes | 7-28 days | Placebo comparable to int grps Int grp 1: Acamprosate: 1300 mg/day Int grp 2: Acamprosate: 2000 mg/day | NA | 52 wks | Placebo: 177/NA Int grp 1: 188/NA Int grp 2: 173/NA | Placebo: 83 % Int grp 1: 78 % Int grp 2: 79 % | Placebo: 42.5 (8.9) Int grp 1: 43.7 (8.6) Int grp 2: 43.3 (8.3) | NA | None | NA | Pill count in both groups | - clinical observation - GGT - MCV - blood alcohol | NA | 3-level ordinal scale
Roussaux JP, Hers D, Ferauge M (1996) | CT-R-DB | DSM-III Instrument NA | NA | Yes | 14 days | Placebo comparable to int grps Int grp 1: Acamprosate: 1998 mg/day (max) | All encouraged to attend group, individualized, and family counseling | 12 wks | Placebo: 64/46 Int grp 1: 63/44 | Placebo: 63 % Int grp 1: 78 % | Placebo: 41.7 (NA) Int grp 1: 42.7 (NA) | NA | None | NA | Pill count in both groups | - clinical observation - unspecified self-report - GGT - MCV - blood alcohol | NA | 4 pt VAS
Sass H, Soyka M, Mann K, et al. (1996) | CT-R-DB | DSM-III-R by Munich Alcoholism test | Munich alcoholism test | Yes | 14-18 days | Placebo comparable to int grps Int grp 1: Acamprosate: 1998 mg/day (max) | All received group and individual counseling and encouraged to attend AA | 48 wks | Placebo: 136/55 Int grp 1: 136/79 | Placebo: 80 % Int grp 1: 75 % | Placebo: 40.5 (8.6) Int grp 1: 41.9 (8.4) | NA | None | No | - urine marker in acamprosate group - pill count in both groups | - unspecified self-report - GGT - breath alcohol test - proxy | NA | 200mm VAS
Whitworth AB, Fischer F, Lesch OM, et al. (1996) | CT-R-DB | DSM-III Instrument NA | MAST | Yes | 5 days | Placebo comparable to int grps Int grp 1: Acamprosate: 1998 mg/day (max) | None | 52 wks | Placebo: 224/85 Int grp 1: 224/95 | Placebo: 83 % Int grp 1: 75 % | Placebo: 42.0 (8.8) Int grp 1: 41.9 (8.2) | NA | None | NA | None | - unspecified self-report - clinical observation - GGT - MCV | NA | Not measured
Geerlings PJ, Ansoms C, Van den Brink W (1997) | CT-R-DB | DSM-III Instrument NA | NA | Yes | 5 days | Placebo comparable to int grps Int grp 1: Acamprosate: 1998 mg/day (max) | NA | 24 wks | Placebo: 134/42 Int grp 1: 128/52 | Placebo: 76 % Int grp 1: 76 % | Placebo: 41.7 (8.1) Int grp 1: 40.3 (9.2) | NA | None | NA | Pill count in both groups | - unspecified self-report - GGT - CDT - MCV | NA | 4-pt ordinal scale
Pelc I, Verbanck P, Le Bon O, et al. (1997) | CT-R-DB | DSM-III-R Instrument NA | NA | Yes | NA | Placebo comparable to int grps Int grp 1: Acamprosate: 1332 mg/day Int grp 2: Acamprosate: 1998 mg/day (max) | NA | 12 wks | Placebo: 62/32 Int grp 1: 63/44 Int grp 2: 63/43 | NA | NA | NA | None | NA | Pill count in both groups | - diary and urine test for alcohol - GGT - MCV | NA | 4-step categorical scale
Poldrugo F (1997) | CT-R-DB | DSM-III Instrument NA | MAST Daily alcohol consumption | Yes | 5 days | Placebo comparable to int grps Int grp 1: Acamprosate: 1998 mg/day (max) | All received group, family, and individual counseling and participated in Club of Treated Alcoholics | 26 wks | Placebo: 124/47 Int grp 1: 122/65 | Placebo: 76.6 % Int grp 1: 68.9 % | Placebo: 44.9 (9.5) Int grp 1: 42.9 (9.9) | NA | NA | NA | None | - structured interview - CGT - MCV | NA | VAS scale length not specified

Evidence Table 8: Acamprosate study outcomes[Evidence Tables]

Author, year | Standard drinks | Drinking/Nondrinking days | Episodes of heavy drinking | Patients who resumed drinking | Time to first drink | Craving | Relapse over course of treatment | GGT/MCV/CDT | Compliance with treatment | Conclusions | Subgroup and followup analyses | Limitations | Quality score
Gerra G, Caccavari R, Delsignore R, et al. (1992) | Nonfamilial alcoholism: Placebo: NA Int grp 1: Start: 11.1 (SD: 0.9) End: 4.4 (SD: 0.6) p<.05 | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | - small sample size - cross-over design of questionable utility for studying the efficacy of drugs to treat alcohol dependence | C=90 M=53
Ladewig D, Knecht T, Leher P, et al. (1993) | NA | Nondrinking days: Placebo: 77.8 Int grp 1: 121.03 p="significant" | NA | Placebo: 58 % at 1 mo 73 % at 3 mo 77 % at 6 mo Int grp 1: 25 % at 1 mo 56 % at 3 mo 57 % at 6 mo P vs. 1 at 1 mo: p=.01 Others; p=NS | NA | NA | NA | NA | NA | Int showed efficacy over placebo: - greater # of nondrinking days - lower % of patients who resumed drinking at one month | 90 days post tx analysis showed no efficacy over placebo: Placebo: 77 % Int grp 1: 70 % p=.56 180 days post tx analysis did not show efficacy over placebo: Placebo: 77 % Int grp 1: 74 % p=.23 | | C=54 M=95
Paille FM, Guelfi JD, Perkins AC, et al. (1995) | NA | Nondrinking days: Placebo: 173 (SD: 126) Int grp 1: 198 (SD: 133) Int grp 2: 223 (SD: 134) p=.0005 | NA | Placebo: 66.7 % at 3 mo 81.4 % at 6 mo 88.7 % at 12 mo Int grp 1: 60.6 % at 3 mo 73.4 % at 6 mo 81.9 % at 12 mo Int grp 2: 59 % at 3 mo 68.2 % at 6 mo 80.9 % at 12 mo 3 mo: p=NS 6 mo: p=.018 12 mo: p=NS | Placebo: 102 days (SD: 165) Int grp 1: 135 days (SD: 189) Int grp 2: 153 days (SD: 197) p=.032 | Percent with no craving: Placebo: Start:<10 3 mo: 40 Int grp 1: Start:<1 3 mo: NA Int grp 2: Start:<10 % 3 mo: 59.4 % p=significant at the 3-month time period only | NA | GGT Mean (IU/L) at Day 90: Placebo: 44.8 (SD: 93.6) Int grp 1: 44.9 (SD: 72.8) Int grp 2: 37.2 (SD: 56.9) Mean (IU/L) at Day 180: Placebo: 45.3 (SD: 62.7) Int grp 1: 46.3 (SD: 81.6) Int grp 2: 64.3 (SD: 185.5) Mean (IU/L) at Day 360: Placebo: 44.6 (SD: 96.0) Int grp 1: 50.6 (SD: 127.3) Int grp 2: 32.5 (SD: 51.3) Mean (IU/L) at Day 540: Placebo: 34.2 (SD: 43.2) Int grp 1: 45.4 (SD: 58.8) Int grp 2: 37.8 (SD: 55.6) MCV Mean (f/L) at Day 180: Placebo: 94.8 (SD: 6.5) Int grp 1: 93.9 (SD: 5.3) Int grp 2: 93.3 (SD: 5.9) Mean (f/L) at Day 360: Placebo: 94.8 (SD: 7.5) Int grp 1: 92.9 (SD: 6.3) Int grp 2: 93.3 (SD: 5.7) Mean (f/L) at Day 540: Placebo: 93.9 (SD: 7.2) Int grp 1: 93.7 (SD: 6.0) Int grp 2: 92.4 (SD: 5.0) | Placebo: 35.6 % by attendance Int grp 1: 37.3 % by attendance Int grp 2: 54.9 % by attendance | Int grps 1& 2 showed efficacy over placebo: - more nondrinking days - greater time to first drink - marginal evidence of enhanced abstinence - dose response suggested | | - high dropout rate - compliance poor - time period for results not always clear (makes some results unusable) - #s don't always match tables, figures, or discussion | C=76 M=49
Roussaux JP, Hers D, Ferauge M (1996) | NA | NA | NA | Placebo: 48 % at 1 mo 67 % at 3 mo Int grp 1: 48 % at 1 mo 71 % at 3 mo p=NS | NA | Placebo: Start: .05 End: 1.67 Int grp 1: Start: .20 End: 1.75 p=NA | NA | GGT Mean (IU/L) at Day 0: Placebo: 18.3 (SD: 18.5) Int grp 1: 52.3 (SD: 43.1) Mean (IU/L) at Day 30: Placebo: 41.4 (SD: 29.8) Int grp 1: 45.9 (SD: 39.1) Mean (IU/L) at Day 90: Placebo: 35.8 (SD: 29.4) Int grp 1: 42.0 (SD: 37.8) p=NA MCV Mean (f/L) at Day 0: Placebo: 98.4 (SD: 7.2) Int grp 1: 98.4 (SD: 7.8) Mean (f/L) at Day 30: Placebo: 97.8 (SD: 5.1) Int grp 1: 97.0 (SD: 5.9) Mean (f/L) at Day 90: Placebo: 96.8 (SD: 4.5) Int grp 1: 94.5 (SD: 5.5) p=NA | NA | Int did not show efficacy over placebo | | - alcohol consumption unverified | C=69 M=61
Sass H, Soyka M, Mann K, et al. (1996) | NA | Nondrinking days: Placebo: 162.0 (SD: 132.2) Int grp 1: 224.6 (SD: 136.6) p=.001 | NA | Placebo: 79 % at 48 wks Int grp 1: 57 % at 48 wks p=.001 | Placebo: 112.3 days (SD: 126.5) Int grp 1: 165.2 days (SD: 143.8) p=.005 | Placebo: 70.6 (SD: 38.5) Int grp 1: 65.3 (SD: 41.6) p=NS | NA | GGT Mean (IU/L) at baseline: Placebo: 89.5 (SD: 118.3) Int grp 1: 62.6 (SD: 92.7) Mean (IU/L) at week 48: Placebo: 49 (SD: 75) Int grp 1: 26 (SD: 32) p=NS MCV Mean (f/L) at baseline: Placebo: 96.7 (SD: 5.4) Int grp 1: 96.4 (SD: 5.3) Mean (IU/L) at week 48: Placebo: 91.7 (SD: 5.7) Int grp 1: 90.6 (SD: 4.8) p=NS CDT Mean (IU/L) at baseline: Placebo: 20.5 (SD: 10.5) Int grp 1: 20.8 (SD: 13.6) Mean (IU/L) at week 48: Placebo: 21.3 (SD: 18.8) Int grp 1: 16.1 (SD: 11.6) p=NS | NA | Int showed efficacy over placebo: - greater # of nondrinking days - lower % of patients resumed drinking - more time to first drink | 48 week post tx analysis showed efficacy over placebo: - greater nondrinking days Placebo: 250.95 (SD: 244.63) Int grp 1: 387.14 (SD: 280.52) p<.001 - fewer patients who resumed drinking Placebo: 82.7 % Int grp 1: 60.1 % p<.003 | - diff. in psychotherapy between sites (not standardized, not adequately described) | C=91 M=90
Whitworth AB, Fischer F, Lesch OM, et al. (1996) | NA | Nondrinking days: Placebo: 103.8 (SD: 119.0) Int grp 1: 138.8 (SD: 137.5) p=.012 | NA | Placebo: 92.9 % Int grp 1: 81.7 % p=.007 | NA | NA | NA | NA | NA | Int showed efficacy over placebo: - more nondrinking days - increased abstinence rates | 12-month post tx analysis: - compared to start of trial, both placebo and int grp 1 had fewer nondrinking days at end of followup (2 yrs) Placebo: Start: 103.8 (SD: 119) End: 79.2 (SD: 135.8) p=.33 Int grp 1: Start: 138.8 (SD: 137.5) End: 92 (SD: 140.4) p=.012 - % of patients who resumed drinking Placebo: 95.1 % Int grp 1: 88.1 % p<.05 | - alcohol consumption unverified - high dropout rate | C=57 M=47
Geerlings PJ, Ansoms C, Van den Brink W (1997) | NA | Nondrinking days: Placebo: 43 (SD: 58) Int grp 1: 61 (SD: 70) p=.025 | NA | Placebo: 87 % at 6 mo Int grp 1: 75 % at 6 mo p=.06 | Placebo: 15 days Int grp 1: 45 days p=NA | NA | NA | NA | Placebo: 88 % by pill count Int grp 1: 86 % by pill count p=NA | Int showed efficacy over placebo: - greater # of nondrinking day - lower % of patients resumed drinking - longer time to first drink | NA | - high dropout rate | C=81 M=39
Pelc I, Verbanck P, Le Bon O, et al. (1997) | NA | Nondrinking days: Placebo: 34.3 Int grp 1: 51.9 Int grp 2: 56.6 P vs. 1: p<.05 P vs. 2: p<.05 | NA | Placebo: 74 % at 3 mo Int grp 1: 56 % at 3 mo Int grp 2: 49 % at 3 mo p<.05 | Placebo: 15 days Int grp 1: 55.5 days Int grp 2: 56.3 days P vs. 1: p<.002 P vs. 2: p<.001 | (% pts w/no desire for alcohol) Placebo: 31 % Int grp 1: 57 % Int grp 2: 58 % p<.03 | NA | NA | NA | Int grps 1& 2 showed efficacy over placebo: - more nondrinking days - greater time to first drink | | - high dropout rate - no demographics or hx of pts, so generalizability unknown - efficacy restricted to detoxified pts - drug modification of relapse rate poorly explained - period of drug usefulness unknown | C=73 M=59
Poldrugo F (1997) | NA | Nondrinking days: Placebo: 70.4 (SD: 74.1) Int grp 1: 99.1 (SD: 80.0) p=.004 | NA | Placebo: 67.7 % Int grp 1: 51.6 % p=.035 | Median: Placebo: 60.9 days Int grp 1: 150.5 days p=.0004 | Not significant | NA | GGT Percent of patients below 1.3 times the upper limit of normal GGT at 6 mos: Placebo: 21 % Int grp 1: 39 % p=.0017 | NA | Int did show efficacy over placebo Compared to placebo, int grp 1 patients had significantly: - more nondrinking days - fewer who returned to drinking - longer times to first drink -lower GGT values | Nondrinking days over 52-wk period: Placebo: 120.5 (SD: 146.8) Int grp 1: 167.7 (SD: 151.1) p=.014 % who had resumed drinking at 52 wks Placebo: 70.2 Int grp 1: 56.6 p=.05 | - some of the patients also used disulfiram during the treatment period - patients with little social support excluded | C=85 M=80

Evidence Table 9(a): Acamprosate study side effects [Evidence Tables]

Side effects ^*^ | Sample Size (total) | Active (%) | Placebo (%) | Statistical significance | Method of assessment** | Author and date
Body as a whole
- Lower limb paresthesia | 406 | 12.8 | 10.6 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Gastrointestinal
Gastrointestinal | 246 | NA | NA | NS | 1 | Poldrugo F (1997)
- Abdominal discomfort | 272 | 0.7 | NA | NA | 6 | Sass H, Soyka M, Mann K, et al. (1996)
- Abdominal discomfort | 406 | 4.2 | 6.0 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Gastralgia | 406 | 13.4 | 14.4 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Constipation | 406 | 3.7 | 5.5 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Diarrhea | 448 | 20.1 | 12.1 | p=.021 | 1 | Whitworth AB, Fischer F, Lesch OM, et al. (1996)
- Diarrhea | 188 | low-dose 43.0; high-dose 48.0 | 39.0 | NS | 2,5 | Pelc I, Verbanck P, Le Bon O, et al. (1997)
- Diarrhea | 262 | 19.5 | 11.5 | p=.06 | 6 | Geerlings PJ, Ansoms C, Van den Brink W (1997)
- Diarrhea | 406 | 13.0 | 7.0 | p=.04 | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Diarrhea | 272 | 7.4 | 8.1 | NA | 6 | Sass H, Soyka M, Mann K, et al. (1996)
- Diarrhea | 538 | low-dose 7.4; high-dose 12.1 | 3.4 | p<.01 | 3 | Paille FM, Guelfi JD, Perkins AC, et al. (1995)
- Gastric hemorrhage | 272 | 0.7 | NA | NA | 6 | Sass H, Soyka M, Mann K, et al. (1996)
- Nausea | 406 | 8.6 | 8.6 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Vomiting | 406 | 5.3 | 3.6 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Musculoskeletal
- Loin pain | 406 | 5.9 | 10.5 | p=.07 | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Muscular pain | 406 | 5.4 | 9.7 | p=.08 | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Central nervous system/psychiatric
Neuropsychological | 246 | NA | NA | NS | 1 | Poldrugo F. (1997)
- Sleep disturbance | 406 | 16.2 | 15.9 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Increased sleep duration | 406 | 8.9 | 10.8 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Inefficient sleep | 406 | 13.5 | 10.1 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Waking during night | 406 | 23.4 | 25.0 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Sleeplessness | 406 | 22.7 | 18.7 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Drowsiness | 406 | 11.6 | 9.7 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Memory impairment | 406 | 5.0 | 6.3 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Confusion | 406 | 4.3 | 1.6 | p=.08 | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Dizziness | 406 | 4.9 | 9.9 | p=.05 | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Fainting | 406 | 4.7 | 5.1 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Excitation | 406 | 23.6 | 19.1 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Headache | 272 | 5.1 | 6.6 | NA | 6 | Sass H, Soyka M, Mann K, et al. (1996)
- Headache | 406 | 13.7 | 13.4 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Headache | 246 | 4.1 | NA | NA | 1 | Poldrugo F (1997)
- Depression | 272 | 1.5 | NA | NA | 6 | Sass H, Soyka M, Mann K, et al. (1996)
- Difficulty in concentration | 406 | 4.0 | 7.9 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Cardiovascular
Cardiopulmonary | 246 | NA | NA | NS | 1 | Poldrugo F (1997)
- Chest pain | 406 | 5.7 | 3.2 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Palpitations | 406 | 8.5 | 8.8 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Dermatologic
Dermatologic | 246 | NA | NA | NS | 1 | Poldrugo F (1997)
- Itching | 406 | 11.0 | 7.0 | p=.0125 | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Increased sweating | 406 | 15.0 | 16.8 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Other skin symptoms | 406 | 5.7 | 3.4 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Respiratory
- Shortness of breath | 406 | 14.6 | 11.6 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Genitourinary
Genitourinary | 246 | NA | NA | NS | 1 | Poldrugo F (1997)
- Increased sexual desire | 188 | low-dose 0.0; high-dose 11.0 | 3.2 | p<.05 | 2,5 | Pelc I, Verbanck P, Le Bon O, et al. (1997)
- Increased sexual desire | 406 | 7.5 | 6.6 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Decreased sexual desire | 406 | 15.6 | 12.9 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Impotence | 406 | 10.7 | 8.8 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Menstrual disorder | 406 | 18.5 | 13.3 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Urinary disorder | 406 | 5.6 | 4.9 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
Miscellaneous
- Fatigue | 272 | 1.5 | NA | NA | 6 | Sass H, Soyka M, Mann K, et al. (1996)
- Fatigue | 406 | 16.8 | 20.7 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Ankle swelling | 406 | 2.7 | 1.1 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Cold intolerance | 406 | 11.0 | 9.1 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Heat intolerance | 406 | 6.9 | 5.9 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Decreased appetite | 406 | 15.1 | 14.5 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Dry mouth | 406 | 11.7 | 15.6 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Sour aftertaste | 406 | 3.5 | 6.5 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Tinnitus | 406 | 2.4 | 1.5 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)
- Visual disturbance | 406 | 5.5 | 8.1 | NS | 2 | Lhuintre JP, Moore N, Tran G, et al. (1990)

* Side effect categories are not mutually exclusive, since some patients may have experienced more than one side effect.

** Method of assessment:

1 Interviewer-administered side-effect checklist.
2 Self-administered side-effect checklist.
3 Open-ended question asked at each visit.
4 Investigator observed at each visit.
5 Spontaneous reporting by patient.
6 Not specified.

NA = not available. NS = not significant.

Evidence Table 9(b): Acamprosate study withdrawals [Evidence Tables]

Author and date | Sample size (total) | Reason for withdrawal | Active (%) | Placebo (%)
Withdrawals due to side effects ^*^
Whitworth AB, Fischer F, Lesch OM, et al. (1996) | 448 | Side effect (NOS) | 2.7 | 1.8
Paille FM, Guelfi JD, Perkins AC, et al. (1995) | 538 | Side effect (NOS) | low-dose 8.5; high-dose 6.9 | 8.5
Lhuintre JP, Moore N, Tran G, et al. (1990) | 569 | Diarrhea Itching | 0.4 0.7 | NA NA
Pelc I, Verbanck P, Le Bon O, et al. (1997) | 188 | Side effect (NOS) | low-dose 3.2; high-dose 1.6 | 1.6
Geerlings PJ, Ansoms C, Van den Brink W (1997) | 262 | Constipation Diarrhea Itching Stomach pain | 0.7 0.7 0.7 0.0 | 0.0 0.0 0.8 2.3
Sass H, Soyka M, Mann K, et al. (1996) | 272 | Side effect (NOS) | 0.7 | 1.5

* Withdrawals due to side effects are not always mutually exclusive categories, since some patients may experience more than one side effect.

NA = not available. NOS = not otherwise specified.

Evidence Table 10: Serotonergic agents study designs [Evidence Tables]

Author, year | Study design and blinding | Alcohol dependence diagnosis and diagnostic instrument | Severity assessment | Detoxified | Abstinence period | Drug intervention | Co-intervention | Length of active trt | Initial/end study population (n) | Percent males initially | Mean age (SD) initially | Race | Co-morbidity | Other SA | Compliance measures | Outcome measures | Relapse definition | Craving measure
Gerra G, Caccavari R, Delsignore R, et al. (1992) | CX-R | DSM-III-R Instrument NA | NA | NA | NA | Placebo comparable to int grp Int grp 1: Fluoxetine: 40 mg/day | Weekly meetings | 4 wks for each treatment | 28/NA | 64.3 % | 43.5 (NA) | NA | None | No | NA | - unspecified self-report - proxy | NA | Four 5-pt scales for interest, desire, liking, & intoxication
Gorelick DA, Paredes A (1992) | CT-N-DB | DSM-III Instrument NA | NA | NA | NA | Placebo comparable to int grps Int grp 1: fluoxetine: 80 mg/day (max) | None | 4 wks | Placebo: 10/7 Int grp 1: 10/10 | 100 % | Placebo: 47.1 (9.8) Int grp 1: 38.7 (9.7) | Placebo: 90 % (W) 10 % (H) Int grp 1: 70 % (W) 30 % (B) | None | No | Direct supervision in all groups | - volume of alcohol consumed | NA | 100 mm VAS
Kranzler HR, Del Boca F, Korner P, et al. (1993) | CT-R-DB | DSM-III-R by structured interview with individual | Last 6 mos of drinking quex | NA | NA | Placebo comparable to int grps Int grp 1: Fluvoxamine: 200 mg/day | Individual counseling for all groups | 12 wks | Placebo: 9/8 Int grp 1: 10/2 | Placebo: 100 % Int grp 1: 90 % | Placebo: 40.1 (10.3) Int grp 1: 45.7 (11.4) | NA | None | No | None | - TLFB - last 6 months of drinking quex | NA | Not measured
Sellers EM, Toneatto T, Romach MK, et al. (1994) | CT-R-DB | DSM-III-R by structured interview with individual | ADS | NA | NA | Placebo comparable to int grps Int grp 1: Ondansetron: 0.5 mg/day Int grp 2: Ondansetron: 4.0 mg/day | Individual counseling | 6 wks | Placebo: 23/17 Int grp 1: 23/18 Int grp 2: 25/21 | 100 % | 43.6 (9.7) | 99 % (W) | None | No | Urine marker and pill count for all grps | - TLFB - situational confidence quex - tobacco and caffeine consumption form - multiple adjective check list - goal setting - inventory of drinking situations - adverse events enquiry - daily log book | NA | 11-pt VAS
Kranzler HR, Burleson JA, Korner P, et al. (1995) Kranzler HR, Burleson JA, Brown J, et al.(1996) | CT-R-DB | DSM-III-R by structured interview with individual | MAST & DAC | NA | 7 days | Placebo comparable to int grps Int grp 1: Fluoxetine: 60 mg/day (max) | Group or individual counseling | 12 wks | Placebo: 50/49 Int grp 1: 51/46 | 80 % | 40.1 (8.6) | 95 % (W) | Depression | Yes | Urine marker >3 urine tests w/riboflavin for all groups | - self-report quex - TLFB - MAST - proxy | NA | NA
Janiri L, Gobbi G, Mannelli P, et al. (1996) | CT-R-DB | DSM-III-R Instrument NA | 66 % severe but assessment method not specified | Yes | >7 days | Placebo comparable to int grps Int grp 1: Fluoxetine: 20 mg/day | AA and individual counseling encouraged | 8 wks | Placebo: 29/16 Int grp 1: 21/17 | Placebo: 83 % Int grp 1: 76 % | Placebo: 45.0 (15.0) Int grp 1: 45.9 (21.1) | NA | Axis I and II psychiatric disorders | No | NA | - structured interview with individual - proxy | Continuous drinking Drinking >3 days with daily consumption higher than 50 g | 10 cm VAS
Kabel DI, Petty F (1996) | CT-N-DB | DSM-III-R by structured interview with individual | MAST and DAC | Yes | NA | Placebo comparable to int grps Int grp 1: Fluoxetine: 60 mg/day (max) | AA encouraged | 12 wks | Placebo: 13/10 Int grp 1: 15/9 | 100 % | 46.8 (9.1) | 54 % (W) 36 % (B) 10 % (O) | None | Yes | Self-report for all grps | - alcohol research quex - TLFB - proxy | >5 drinks/occ >5 days/wk - breath alcohol test | Quex on drinking urges
Malec E, Malec T, Gagne MA, et al. (1996) | CT-R-DB | DSM-III-R Instrument NA | MAST | NA | NA | Placebo comparable to int grps Int grp 1: Buspirone: 40 mg/day (max) | AA; group and individual counseling encouraged | 12 wks | Placebo: 29/20 Int grp 1: 28/16 | Placebo: 90 % Int grp 1: 75 % | Placebo: 41.5 (8.0) Int grp 1: 41.8 (7.6) | NA | Anxiety disorder and depression | No | Pill count for all groups | - MAST - alcohol use inventory - drinking behavior interview - craving scales - patient diary - proxy - GGT | NA | 10 cm VAS 5-pt OS
Tiihonen J, Ryynanen OP, Kauhanen J, et al. (1996) | CT-R-DB | DSM-III-R Instrument NA | MAST | NA | >7 days | Placebo comparable to int grps Int grp 1: Citalopram: 40 mg/day (max) | Individual counseling | 12 wks | Placebo: 31/13 Int grp 1: 31/21 | 100 % | Placebo: 46.8 (8.7) Int Grp 1: 44.7 (7.0) | NA | Anxiety disorder and depression | No | Blood levels in Int grp 1 only | - non-std drinking measure - proxy | NA | NA

Evidence Table 11: Serotonergic agents study outcomes[Evidence Tables]

Author, year | Standard drinks | Drinking/nondrinking days | Episodes of heavy drinking | Patients who resumed drinking | Time to first drink | Craving | Relapse over course of treatment | GGT/MCV/CDT | Compliance with treatment | Conclusions | Subgroup and followup analyses | Limitations | Quality score
Gerra G, Caccavari R, Delsignore R, et al. (1992) | Familial alcoholism: Placebo: NA Int grp 1: Start: 12.8 (SD: 1.3) End: 6.0 (SD: 0.8) (4 wks) p<.05 Standard = ml of 97.5 proof alcohol | NA | NA | NA | NA | NA | NA | NA | NA | - fluoxetine showed efficacy for patients w/familial alcoholism but not in those with non-familial alcoholism | NA | - small sample size - cross-over design of questionable utility for studying the efficacy of drugs to treat alcohol dependence | C=90 M=53
Gorelick DA, Paredes A (1992) | Standard = ml of 97.5 proof alcohol: Placebo: Start: 642 ml (SD: 98) End: 621 ml (SD: 126) Int grp 1: Start: 655 ml (SD: 113) End: 617 ml (SD: 13) p=NS | NA | NA | NA | NA | Fluoxetine patients reported less craving than placebo group. p=NS | NA | NA | NA | - int did not show efficacy over placebo | NA | - no psychotherapy - study design not comparable to any others reviewed | C=91 M=53
Kranzler HR, et al. (1993) | NA | NA | NA | NA | NA | NA | NA | NA | NA | - int did not show efficacy over placebo | NA | - very small sample size (of 10 in int grp, 8 dropped out; of 9 in placebo grp, 1 dropped out) | 0
Sellers EM, Toneatto T, Romach MK, et al. (1994) | Lighter drinkers only: Placebo: Chg: -1.4 (SD: 1.92) Int grp 1: Chg: -2.8 (SD: 2.00) Int grp 2: Chg: -0.7 (SD: 1.99) Int grp 1 vs. Placebo: p=.03 Heavy drinkers: no significant differences | NA | NA | NA | NA | NA | NA | NA | No individual patient who completed the study was noncompliant by urine or pill count by >10 % p=NA | - int showed efficacy at low dose but not at high dose in light drinkers only | NA | - small sample size - only 50 % of potentially eligible entered trial | C=89 M=75
Kranzler HR, Burleson JA, Korner P, et al. (1995) Kranzler HR, Burleson JA, Brown J, et al. (1996) | Drinks per drinking day: Placebo: Start: 9.8 (SD: 6.2) End: 2.7 (SD: 5.3) p<.001 Int grp 1: Start: 9.8 (SD: 4.5) End: 3.2 (SD: 5.2) p<.001 | Drinking days: Placebo: Start: 43.4 (SD: 12.4) End: 4.4 (SD: 9.0) p<.001 Int grp 1: Start: 45.3 (SD: 12.6) End: 7.6 (SD: 14.2) p<.001 | NA | NA | NA | NA | NA | GGT used to validate self-report for # drinking days (r=0.58) and drinks per day (r=0.49) | Placebo: 90 % by urine marker Int grp 1: 77 % by urine marker p=.03 | - fluoxetine was not more efficacious than placebo - in both placebo and int grp, there was a significant reduction in drinking during the active drug period | Compliant subjects showed decreased drinking in both placebo and int group. | - comorbid depression was not controlled for | C=92 M=53
Janiri L, Gobbi G, Mannelli P, et al. (1996) | NA | NA | NA | Placebo: 65.5 % Int grp 1: 38.1 % p=.05 | NA | Placebo: Start: 10.4 (SD: 7.0) End: 7.5 (SD: 5.5) Int grp 1: Start: 7.3 (SD: 4.8) End: 9.5 (SD: 6.0) Start: p=NS End: p< .05 | Placebo: 34.5 % Int grp 1: 28.6 % p=.05 | NA | NA | - int showed efficacy over placebo - fewer patients resumed drinking | Depression subgroup: 6 of 6 depressed patients on fluoxetine remained abstinent. 2 of 4 depressed placebo patients remained abstinent. | - small sample size - alcohol consumption unverified | C=98 M=40
Kabel DI, Petty F (1996) | NA | NA | NA | NA | NA | Placebo: Start: 1.8 End: 2.0 Int grp 1: Start: 2.9 End: 0.7 p=.02 | Placebo: 31 % Int grp 1: 47 % p=NS | NA | NA | - int did not show efficacy over placebo - fluoxetine patients who remained sober reported reduced craving | Supportive living arrangements reduced relapse rates. 47 % of those who returned to the community relapsed compared to 89 % of those who went to a VA home. p=.03 | - small sample size - high drop out rate - individual counseling not given | C=86 M=87
Malec E, Malec T, Gagne MA, et al. (1996) | Study completers: Placebo: Start: 8.01/day (SD: 4.45) End: 5.33/day (SD: 4.48) Int grp 1: Start: 12.19/day (SD: 16.06) End: 8.52/day (SD: 16.53) p=NS | Drinking days in preceding 2 wks: Study completers: Placebo: Start: 12.70 (SD: 2.27) End: 2.71 (SD: 6.06) Int grp 1: Start: 12.00 (SD: 2.53) End: 3.5 (SD: 3.5) p=NS | NA | Placebo: 85 % (varied length) Int grp 1: 88 % (varied length) p=NS | NA | Study completers: Placebo: Start: 22.45 (SD: 26.82) End: 11.00 (SD: 28.85) Int grp 1: Start: 18.88 (SD: 22.97) End: 11.00 (SD: 24.97) p=NS | NA | Study completers: GGT: Placebo: Start: 59.3 (SD: 40.7) End: 16.5 (SD: 23.4) Int grp 1: Start: 70.0 (SD: 67.7) End: 14.6 (SD: 27.2) | NA | - int did not show efficacy over placebo | NA | - small sample size - high dropout rate | C=82 M=53
Tiihonen J, Ryynanen OP, Kauhanen J, et al. (1996) | NA | NA | Placebo: 90 % (3 mos) Int grp 1: 81 % (3 mos) p=NS | NA | NA | NA | NA | GGT (% of patients with 20 % decrease) Placebo: 16 % Int grp 1: 36 % p=NS | Placebo: NA Int grp 1: 100 % of completers by blood concentration p=NA | - int did not show efficacy over placebo | NA | - high dropout rate | C=45 M=87

Evidence Table 12: Serotonergic agents in comorbid depressed or anxious populations study designs[Evidence Tables]

Author, year | Study design and blinding | Alcohol dependence diagnosis and diagnostic instrument | Severity assessment | Detoxified | Abstinence period | Drug intervention | Co-intervention | Length of active trt | Initial/end study population (n) | Percent males initially | Mean age (SD) initially | Race | Co-morbidity | Other SA | Compliance measures | Outcome measures | Relapse definition | Craving measure
Kranzler HR, Burleson JA, Del Boca FK, et al. (1994) | CT-R-DB | DSM-III-R by structured interview with individual and CDIS | MAST | NA | 7 days | Placebo comparable to int grps Int grp 1: Buspirone: 60 mg/day (max) | Individual counseling AA encouraged | 12 wks | Placebo: 30/16 Int grp 1: 31/26 | Placebo: 80 % Int grp 1: 74.2 % | Placebo: 40.4 (9.6) Int grp 1: 38.5 (9.1) | Placebo: 90 % (W) Int grp 1: 100 % (W) | Anxiety disorder | Yes | Urine marker for all groups | - unspecified self-report - TLFB - MAST - breath alcohol test - proxy | NA | NA
Malcolm R, Anton RF, Randall CL, et al. (1992) Thevos AK, Brown JM, Malcolm R, et al. (1996) | CT-R-DB | DSM-III-R by structured interview with individual | ASI | Yes | 14 days | Placebo comparable to int grps Int grp 1: Buspirone: 60 mg/day (max) | AA encouraged | 26 wks | Placebo: 34/10 Int grp 1: 33/10 | 100 % | Placebo: 41.7 (1.3) Int grp 1: 44.3 (1.6) | Placebo: 85 % (W) 15 % (B) Int grp 1: 82 % (W) 18 % (B) | Anxiety disorder | No | Urine marker and pill count for all groups | - TLFB - breath alcohol test - proxy | NA | 100 mm VAS
Cornelius JR, Salloum IM, Ehler JG, et al. (1997) | CT-R-DB | DSM-III-R by structured interview with individual | ASI > 5 DSM criteria | Yes | 10 days | Placebo comparable to int grps Int grp 1: Fluoxetine: 40 mg/day (max) | Individual counseling Weekly supportive therapy AA encouraged | 12 wks | Placebo: 26/NA Int grp 1: 25/NA 46 completed the study | Placebo: 50 % Int grp 1: 52 % | Placebo: 34.0 (10.0) 35.7 (10.4) | Placebo: 46 % (W) Int grp 1: 48 % (W) | Depression | Yes | Pill count for both groups, plasma drug level for int grp 1 | - timeline method - ASI - proxy | NA | NA

Evidence Table 13: Serotonergic agents in comorbid depressed or anxious populations study outcomes[Evidence Tables]

Author, year | Standard drinks | Drinking/nondrinking days | Episodes of heavy drinking | Patients who resumed drinking | Time to first drink | Craving | Relapse over course of treatment | GGT/MCV/CDT | Compliance with treatment | Conclusions | Subgroup and followup analyses | Limitations | Quality score
Kranzler HR, Burleson JA, Del Boca FK, et al. (1994) | Drinks per days during trial: Placebo: 2.1 (SD: 4.6) Int grp 1: .7 (SD: 2.9) p=NS | Drinking days during trial: Placebo: 9.6 (SD: 13.3) Int grp 1: 3.6 (SD: 11.0) p=NS | NA | NA | Time to first heavy drinking increased in int grp 1 over placebo (graphic only) p=.03 | NA | NA | NA | Placebo: 96 % by urine marker Int grp 1: 93 % by urine marker p=NS | Int showed efficacy over placebo. Greater time to first heavy drinking | Six-month followup analysis showed: - fewer drinking days for int group compared to placebo p<.01 - fewer drinks/day for int grp compared to placebo p<.10 | - small sample size - half of placebo group dropped out | C=100 M=90
Malcolm R, Anton RF, Randall CL, et al. (1992) Thevos AK, Brown JM, Malcolm R, et al. (1996) | Excluding nondrinkers: Placebo: 78.3 per 28-day period Int grp 1: 122.0 per 28-day period p=NS | NA | NA | Placebo: 45 % Int grp 1: 48 % p=NS | Placebo: 4.2 mos (median) Int grp 1: 2.1 mos (median) p=NS | No significant difference found between groups. | NA | NA | Mean riboflavin level Placebo: 5.3 µg/ml (SD: 4.0) Int grp 1: 4.6 µg/ml (SD: 1.7) p=NA | Int did not show efficacy over placebo | | - high dropout rate - small sample size - inconsistency between tables on numbers in study groups | C=90 M=90
Cornelius JR, Salloum IM, Ehler JG, et al. (1997) | Cumulative over 12 wks: Placebo: 215.5 (248.5) Int grp 1: 70.2 (100.7) p<.03 | Drinking days over 12 wks: Placebo: 20.3 (SD: 18.3) Int grp 1: 10.6 (SD: 15.6) p<.05 | Days of heavy drinking over 12 wks: Placebo: 16.0 (SD: 18.0) Int grp 1: 4.8 (SD: 7.0) p=.04 | Placebo: 84.6 % Int grp 1: 72 % p=.27 | Wks to first drink: Placebo: 3.9 (SD: 4.0) Int grp 1: 5.5 (SD: 4.5) p=.08 | NA | NA | NA | Significant levels of drug found in >99 % of blood specimens for patients on fluoxetine p=NA | Int showed efficacy over placebo: - fewer std drinks - fewer drinking days - fewer days of heavy drinking | | - modest sample size - compliance was not assessed in placebo group | C=97 M=89

Evidence Table 14(a): Serotonergic drugs study side effects[Evidence Tables]

Side effects ^*^ | Sample size (total) | Active (%) | Placebo (%) | Statistical significance | Method of assessment ^**^ | Author and date
Buspirone
Gastrointestinal
- Nausea | 36 | 25.0 | 3.0 | p=.01 | 6 | Malec E, Malec T, Gagne MA, et al. (1996)
Central nervous system/psychiatric
- Dizziness | 67 | 45.0 | 0.0 | p<.0001 | 3 | Malcolm R, Anton RF, Randall CL, et al. (1992)/Thevos AK, Brown JM, Malcolm R, et al. (1996)
- Dizziness | 51 | 34.6 | 16.0 | NA | 5 | Tollefson GD, Lancaster SP, Montague-Clouse J (1991)/Tollefson GD, Montague-Clouse J, Tollefson SL (1992)
- Dizziness | 36 | 57.0 | 17.0 | p=.004 | 6 | Malec E, Malec T, Gagne MA, et al. (1996)
- Drowsiness | 36 | 14.0 | 0.0 | p=.05 | 6 | Malec E, Malec T, Gagne MA, et al. (1996)
- Drowsiness | 61 | 35.5 | 30.0 | NS | 2 | Kranzler HR, Burleson JA, Del Boca FK, et al. (1994)
- Headache | 61 | 25.8 | 33.3 | NS | 2 | Kranzler HR, Burleson JA, Del Boca FK, et al. (1994)
- Lightheadedness | 36 | 25.0 | 0.0 | p=.005 | 6 | Malec E, Malec T, Gagne MA, et al. (1996)
- Dizziness or lightheadedness | 61 | 48.4 | 30.0 | NS | 2 | Kranzler HR, Burleson JA, Del Boca FK, et al. (1994)
- Sensation of impaired mentation | 61 | 25.8 | 16.7 | NS | 2 | Kranzler HR, Burleson JA, Del Boca FK, et al. (1994)
Genitourinary
- Increased sexual desire/performance | 61 | 25.8 | 26.7 | NS | 2 | Kranzler HR, Burleson JA, Del Boca FK, et al. (1994)
Miscellaneous
- Appetite increase | 61 | 19.4 | 23.3 | NS | 2 | Kranzler HR, Burleson JA, Del Boca FK, et al. (1994)
Citalopram
Body as a whole
- Asthenia/lassitude (weakness) | 63 | 49.0 | 24.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
Gastrointestinal
- Diarrhea | 63 | 28.0 | 10.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
- Diarrhea | 82 | 17.1 | 0.0 | p<.05 | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Nausea | 62 | NA | NA | p<.05 | 5 | Naranjo CA, Bremner KE, Lanctot KL (1995)
- Nausea | 82 | 9.8 | 0.0 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Nausea and vomiting | 63 | 47.0 | 2.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
Central nervous system/psychiatric
Drowsiness | 63 | 23.0 | 7.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
Drowsiness | 82 | 14.6 | 4.9 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Headaches | 16 | NA | NA | p >.05 | 6 | Naranjo CA, Poulos CX, Bremner KE, et al. (1992)
- Headaches | 82 | 4.9 | 14.6 | NA | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Increased sleep duration | 63 | 37.0 | 10.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
- Increased sleep duration | 82 | 17.1 | 7.3 | p<.05 | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Sleep disturbance | 62 | NA | NA | p<.05 | 5 | Naranjo CA, Bremner KE, Lanctot KL (1995)
- Sleep disturbance | 82 | 12.2 | 2.4 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
Dermatologic
- Increased sweating | 63 | 33.0 | 15.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
- Increased sweating | 82 | 12.2 | 0.0 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
Genitourinary
- Sexual dysfunction | 62 | NA | NA | p<.05 | 5 | Naranjo CA, Bremner KE, Lanctot KL (1995)
Decreased sexual desire | 63 | 33.0 | 5.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
Decreased sexual desire | 82 | 14.6 | 2.4 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
Ejaculatory dysfunction | 63 | 35.0 | 2.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
Ejaculatory dysfunction | 82 | 4.9 | 0.0 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
Miscellaneous
- Appetite loss | 16 | NA | NA | p >.05 | 6 | Naranjo CA, Poulos CX, Bremner KE, et al. (1992)
- Appetite loss | 62 | NA | NA | p<.05 | 5 | Naranjo CA, Bremner KE, Lanctot KL (1995)
- Appetite loss | 82 | 9.8 | 0.0 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Dry throat | 16 | NA | NA | p >.05 | 6 | Naranjo CA, Poulos CX, Bremner KE, et al. (1992)
- Dry throat | 63 | 44.0 | 22.0 | p<.05 | 1 | Balldin J, Berggren U, Engel J, et al. (1994)
- Dry throat | 82 | 7.3 | 2.4 | NS | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Fatigue | 16 | NA | NA | p >.05 | 6 | Naranjo CA, Poulos CX, Bremner KE, et al. (1992)
- Fatigue | 82 | 26.8 | 4.9 | p<.05 | 2 | Naranjo CA, Sellers EM, Sullivan JT, et al. (1987)
- Yawning | 62 | NA | NA | p<.05 | 5 | Naranjo CA, Bremner KE, Lanctot KL (1995)
Fluoxetine
Gastrointestinal
- Constipation | 20 | 0.0 | 20.0 | NA | 1 | Gorelick DA, Paredes A (1992)
- Diarrhea | 20 | 0.0 | 10.0 | NA | 1 | Gorelick DA, Paredes A (1992)
- Diarrhea | 29 | low-dose 20; high-dose 46.2 | 7.1 | p<.05 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
- Nausea | 20 | 0.0 | 30.0 | NA | 1 | Gorelick DA, Paredes A (1992)
- Nausea | 32 | 18.8 | 6.3 | NA | 1,3 | Naranjo CA, Poulos CX, Bremner KE, et al. (1994)
- Vomiting | 32 | 12.5 | 0.0 | NA | 1,3 | Naranjo CA, Poulos CX, Bremner KE, et al. (1994)
- Dyspepsia | 20 | 20.0 | 40.0 | NA | 1 | Gorelick DA, Paredes A (1992)
Central nervous system/psychiatric
- Anxiety | 29 | low-dose 0.0; high-dose 38.5 | 7.1 | p<.01 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
- Dizziness | 20 | 0.0 | 10.0 | NA | 1 | Gorelick DA, Paredes A (1992)
- Dizziness | 95 | 23.0 | 22.0 | NS | 2 | Kranzler HR, Burleson JA, Korner P, et al. (1995)/Kranzler HR, Burleson JA, Brown J, et al. (1996)
- Drowsiness | 20 | 0.0 | 10.0 | NA | 1 | Gorelick DA, Paredes A (1992)
- Drowsiness | 29 | low-dose 40.0; high-dose 42.2 | 0.0 | p<.05 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
- Drowsiness | 95 | 42.0 | 34.0 | NS | 2 | Kranzler HR, Burleson JA, Korner P, et al. (1995)/Kranzler HR, Burleson JA, Brown J, et al. (1996)
- Sleep disturbance | 32 | 31.3 | <6.3 | p >.05 | 1,3 | Naranjo CA, Poulos CX, Bremner KE, et al. (1994)
Dermatologic
- Excessive sweating | 20 | 0.0 | 10.0 | NA | 1 | Gorelick DA, Paredes A (1992)
- Excessive sweating | 32 | 25.0 | <6.3 | p >.05 | 1,3 | Naranjo CA, Poulos CX, Bremner KE, et al. (1994)
- Excessive sweating | 29 | low-dose 30.0; high-dose 53.8 | 0.0 | p<.05 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
Genitourinary
- Decreased sexual desire/performance | 95 | 35.0 | 18.0 | p=.05 | 2 | Kranzler HR, Burleson JA, Korner P, et al. (1995)/Kranzler HR, Burleson JA, Brown J, et al. (1996)
- Increased sexual desire/performance | 95 | 27.0 | 12.0 | NS | 2 | Kranzler HR, Burleson JA, Korner P, et al. (1995)/ Kranzler HR, Burleson JA, Brown J, et al. (1996)
Miscellaneous
- Appetite loss | 32 | 37.5 | 0.0 | p<.05 | 1,3 | Naranjo CA, Poulos CX, Bremner KE, et al. (1994)
- Appetite increase | 95 | 35 | 32 | NS | 2 | Kranzler HR, Burleson JA, Korner P, et al. (1995)/Kranzler HR, Burleson JA, Brown J, et al. (1996)
- Dry mouth | 95 | 31.0 | 24.0 | NS | 2 | Kranzler HR, Burleson JA, Korner P, et al. (1995)/Kranzler HR, Burleson JA, Brown J, et al. (1996)
- Fatigue | 29 | low-dose 50.0; high-dose 53.8 | 28.6 | p >.05 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
- Fatigue | 32 | 37.5 | <6.3 | p >.05 | 1,3 | Naranjo CA, Poulos CX, Bremner KE, et al. (1994)
- Feeling cold | 29 | low-dose 0.0; high-dose 23.1 | 0.0 | p<.05 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
- Tremors | 29 | low-dose 0.0; high-dose 23.1 | 0.0 | p<.05 | 1 | Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990)
Fluvoxamine
Central nervous system/psychiatric
- Depression | 8 | 25.0 | NA | NA | 4 | O'Carroll RE, Moffoot AP, Ebmeier KP, et al. (1994)

* Side effect categories are not mutually exclusive, since some patients may have experienced more than one side effect.

** Method of Assessment:

1 Interviewer-administered side-effect checklist.
2 Self-administered side-effect checklist.
3 Open-ended question asked at each visit.
4 Investigator observed at each visit.
5 Spontaneous reporting by patient.
6 Not specified.

NA=not available. NS=not significant.

Evidence Table 14(b): Serotonergic drugs study withdrawls[Evidence Tables]

Author and date | Sample size (total) | Reason for withdrawal | Active (%) | Placebo (%)
Withdrawals due to side effects ^*^
Buspirone Tollefson GD, Lancaster SP, Montague-Clouse J (1991)/Tollefson GD, Montague-Clouse J, Tollefson SL (1992) Kranzler HR, Burleson JA, Del Boca FK, et al. (1994) Malec E, Malec T, Gagne MA, et al. (1996) Malcolm R, Anton RF, Randall CL, et al. (1992)/Thevos AK, Brown JM, Malcolm R, et al. (1996) | 51 61 57 67 | Side effects (NOS) Side effects (NOS) Side effects (NOS) Side effects (NOS) | 11.5 6.5 0.0 3.0 | 4.0 13.3 3.4 0.0
Citalopram Naranjo CA, Bremner KE, Lanctot KL (1995) Naranjo CA, Poulos CX, Bremner KE, et al. (1992) | 99 24 | Nausea Fatigue Vomiting Fatigue Headache Dry mouth Anxiety Sleep disturbance Disorientation Heart pounding, excessive sweating, and loss of appetite | 11.3 5.7 1.9 8.3 4.2 4.2 4.2 8.3 4.2 4.2 | 0.0 0.0 0.0 0.0 0.0 0.0 0.0 0.0 0.0 0.0
Fluoxetine Kranzler HR, Burleson JA, Korner P, et al. (1995)/Kranzler HR, Burleson JA, Brown J, et al. (1996) Naranjo CA, Kadlec KE, Sanhueza P, et al. (1990) Naranjo CA, Poulos CX, Bremner KE, et al. (1994) | 95 37 48 | Serum-sickness- like reaction Side effects (NOS) Nausea Diarrhea Vomiting | 2.2 4.3 12.5 4.2 8.3 | 0.0 0.0 4.2 0.0 0.0
Fluvoxamine (open trial) Kranzler HR, Del Boca F, Komer P, et al. (1993) (controlled trial) Kranzler HR, Del Boca F, Komer P, et al. (1993) | 16 16 19 | Side effect (Total) Hepatitis Side effects (Total) | 25.0 6.3 60.0 | 0.0 0.0 0.0

* Withdrawals due to side effects are not always mutually exclusive categories, since some patients may experience more than one side effect.

NOS=not otherwise specified.

Evidence Table 15: Lithium study designs[Evidence Tables]

Author, year | Study design and blinding | Alcohol dependence diagnosis and diagnostic instrument | Severity assessment | Detoxified | Abstinence period | Drug intervention | Co-intervention | Length of active trt | Initial/end study population (n) | Percent males initially | Mean age (SD) initially | Race | Co-morbidity | Other SA | Compliance measures | Outcome measures | Relapse definition | Craving measure
Kline NS, Wren JC, Cooper TB, et al. (1974) | CX-R-DB | DSM-III by clinical observation | NA | Yes | 1 mo | Placebo comparable to int grps Lithium: 0.6-1.2 | NA | 48-96 wks | 73/30 | NA | Age 25-30: 30 % 35-44: 30 % 45-54: 43 % 55-64: 23 % | NA | Depression | NA | Serum lithium levels | - hospitalizations for disabling drinking episodes | NA | NA
Merry J, Reynolds CM, Bailey J, et al. (1976) | CT-R-DB | WHO definition (1952) Glossary of mental disorders (#303) | NA | Yes | NA | Non-depressed placebo Depressed placebo Non-depressed int grp 1: 0.8-1.2 mmol/l Depressed int grp 1: 0.8-1.2 mmol/l | NA | approx 52 wks | Non-depressed Placebo: 19/11 Depressed Placebo: 16/7 Non-depressed Int grp 1: 18/11 Depressed Int grp 1: 18/9 | NA | NA | NA | As a strata | NA | Blood levels for int grps only | - unspecified self-report | NA | NA
Pond SM, Becker CE, Vandervoort R, et al. (1981) | CX-R-DB | National Council on Alcoholism | NA | NA | NA | Placebo comparable to int grps Lithium: 900 mg to maintain 0.6 to 1.2 mEq/l | NA | 12 wks | 47/19 | 100 % | For completers only: 43.1 (10) | NA | Depression | NA | Lithium blood level 0.6-1.2 mEq/l Pill count in both grps | - unspecified self-report | NA | NA
Clark DC, Fawcett J (1989) Fawcett J, Clark DC, Gibbons RD, et al. (1984) Fawcett J, Clark DC, Aagesen CA, et al. (1987) Pisani VD, Fawcett J, Clark DC, et al. (1993) | CT-R-DB with last subjects assigned to lithium | DSM-III by clinical interview and SADS | DAC | NA | NA | Placebo comparable to int grps Lithium: 900 mg/day | AA encouraged for all groups | 72 wks | Placebo: 55/NA Int grp 1: 67/NA | 88 % | Placebo: 39.5 (9.6) Int grp 1: 40.3 (10.4) | 89 % (W) 5 % (B) 6 % (O) | Bipolar disorder Depression | No | Blood levels Self-report and proxy in all grps | - unspecified self-report - clinical interview - proxy | NA | Not measured
de la Fuente JR, Morse RM, Niven RG, et al. (1989) | CT-R-DB | National Council on Alcoholism | NA | Yes | >7 days | Placebo comparable to int grps Int grp 1: Lithium: 814 mg/day (mean dose) | AA; group, individual, and family counseling during detox only | 26 wks | Placebo: 25/13 Int grp 1: 28/14 | 74 % | 44 (14) | NA | Depression | NA | Blood levels for int grp only | - unspecified self-report - alcoholism - screening test - proxy | NA | NA
Dorus W, Ostrow DG, Anton R, et al. (1989) | CT-R-DB | DSM-III by DIS | ASI | Yes | 25-30 days | Non-depressed placebo Depressed placebo Non-depressed int grp 1: 600-1200 mg/day Depressed int grp 1: 600-1200 mg/day | AA; group, individual, and family counseling encouraged for all groups | 52 wks | Non-depressed Placebo: 147/97 Depressed Placebo grp: 82/53 Non-depressed Int grp 1: 139/75 Depressed Int grp 1: 89/55 | 100 % | Non-depressed Placebo: 41.3 (9.0) Depressed Placebo grp: 41.4 (9.2) Non-depressed Int grp 1: 42.5 (8.9) Depressed Int grp 1: 40.8 (9.1) | Non-depressed Placebo: 65 % (W) 33 % (B) 2 % (O) Depressed Placebo: 78 % (W) 21 % (B) 1 % (O) Non-depressed Int grp 1: 64 % (W) 35 % (B) 1 % (O) Depressed Int grp 1: 67 % (W) 28 % (B) 5 % (O) | As a strata | No | Took medication >50 % of the study visits, >4 compliant visits during the year, interviewed at 52 wks | - unspecified self-report - breath alcohol test - proxy | NA | NA

Evidence Table 16: Lithium study outcomes[Evidence Tables]

Author, year | Standard drinks | Drinking/nondrinking days | Episodes of heavy drinking | Patients who resumed drinking | Time to first drink | Craving | Relapse over course of treatment | GGT/MCV/CDT | Compliance with treatment | Conclusions | Subgroup and followup analyses | Limitations | Quality score
Kline NS, Wren JC, Cooper TB, et al. (1974) | NA | NA | Disabling episodes: Placebo: Start: 64 % End: 64 % Int grp 1: Start: 69 % End: 25 % p=.05 | NA | NA | NA | NA | NA | NA | Int showed efficacy over placebo: - fewer disabling episodes of drinking | NA | - alcohol consumption unverified - high dropout rate | C=60 M=43
Merry J, Reynolds CM, Bailey J, et al. (1976) | NA | Drinking days: Non-depressed placebo: NA Depressed placebo: 5.1 (SE: 2.2) Non-depressed int grp 1: NA Depressed int grp 1: 0.7 (SE: 0.4) Int vs. placebo, depressed pts, p<.05 | % time incapacitated: Non-depressed placebo: NA Non-depressed lithium: NA Depressed placebo: 1.5 (SE: 0.6) Depressed lithium: 0.4 (SE: 0.3) Int vs. placebo, depressed pts, p<.05 | NA | NA | NA | NA | NA | NA | Int showed efficacy in depressed subgroup: - fewer drinking days - fewer heavy drinking days | | - alcohol consumption unverified - high dropout rate - alcohol outcomes poorly defined | C=72 M=45
Pond SM, Becker CE, Vandervoort R, et al. (1981) | NA | NA | NA | NA | NA | NA | NA | NA | Pill containers returned for 70 % of study wks with only 10 % of pills reported as unconsumed. p=NA | All results not significant Placebo subjects drank 888 g (± 4,205) more alcohol than int grp subjects p=.2 | Depressed subgroup: Depressed patients reported less alcohol than non-depressed patients but data was not stratified by treatment group. | - cross-over design may not be approp for studies of alcohol pharmacotherapies - analyses excluded patients who consumed no alcohol | C=64 M=67
Clark DC, Fawcett J. (1989); Fawcett J, Clark DC, Gibbons RD,et al. (1984); Fawcett J, Clark DC, Aagesen CA (1987); Pisani VD, Fawcett J, Clark DC, et al. (1993) | NA | NA | NA | NA | NA | NA | NA | NA | See subgroup analysis | Int showed efficacy over placebo when patients were compliant | High blood level lithium (n=28) Low blood level lithium (n=18) Lithium noncompliant (n=21) Placebo compliant (n=42) Placebo noncompliant (n=13) 18 months % abstinent High blood level lithium: 57 % Low blood level lithium: 28 % Lithium noncompliant: 10 % Placebo compliant: 36 % Placebo noncompliant: 0 % 18 months % rehospitalized for alcoholism p=.006 High blood level lithium: 7 % Low blood level lithium: 28 % Lithium noncompliant: 29 % Placebo compliant: 24 % Placebo noncompliant: 23 % | - small sample size - factors potentially biasing subject selection - difficulty in verification of abstinence - poor presentation of results - did not evaluate comorbid patients separately from non-comorbid patients | C=94 M=60
de la Fuente JR, Morse RM, Niven RG, et al. (1989) | NA | Drinking days: Placebo: End: 128 (of 3,235 study days) Int grp 1: End: 105 (of 3,904 study days) p=NS | NA | Placebo: End: 56 % at 6 mos Int grp 1: End: 21 % at 6 mos p<.01 | NA | NA | NA | NA | - 85 % of patients reported taking medications in both groups - 65 % of int grp had therapeutic blood levels p=NA | Int showed efficacy over placebo: - fewer drinking days - lower number of patients resumed drinking | Depression subgroup: Placebo: 16 % abstinent Int grp 1: 15 % abstinent | - many dropouts - compliance not optimal in int grp - did not evaluate comorbid patients separately from non-comorbid patients | C=72 M=69
Dorus W, Ostrow DG, Anton R, et al. (1989) | NA | Drinking days per 4 wks: Non-depressed placebo: End: 5.3 (SD: 0.6) Depressed placebo: End: 4.4 (SD: 0.7) Non-depressed int grp 1: End: 5.0 (SD: 0.6) Depressed int grp 1: End: 4.1 (SD: 0.7) p=NS | NA | Non-depressed placebo: End: 71.6 % at 12 mos Depressed placebo: End: 63.7 % at 12 mos Non-depressed int grp 1: End: 61.8 % at 12 mos Depressed int grp 1: End: 68.4 % at 12 mos p=NS | NA | NA | NA | NA | Completers (depressed and non-depressed) Placebo: 59 % Int grp 1: 63 % p=NA | Int grp did not show efficacy over placebo | | - 30 % to 40 % drop-out rates | C=100 M=87

Evidence Table 17: Lithium study side effects and study withdrawals[Evidence Tables]

Side effects ^*^ | Sample size (total) | Active (%) | Placebo (%) | Statistical significance | Method of assessment ^**^ | Author and date
Gastrointestinal
- Diarrhea | 286 | 42.5 | 31.0 | p=.03 | 1 | Dorus W, Ostrow DG, Anton R, et al. (1989) (non-depressed)
- Diarrhea | 171 | 46.4 | 30.5 | p=.03 | 1 | Dorus W, Ostrow DG, Anton R, et al. (1989) (depressed)
Miscellaneous
- Tremors | 286 | 38.8 | 28.2 | p=.04 | 1 | Dorus W, Ostrow DG, Anton R, et al. (1989)(non-depressed)
- Tremors | 171 | 50.0 | 29.3 | p=.005 | 1 | Dorus W, Ostrow DG, Anton R, et al. (1989)(depressed)
- Trouble walking | 171 | 31.0 | 14.6 | p=.01 | 1 | Dorus W, Ostrow DG, Anton R, et al. (1989) (depressed)
Study withdrawals due to side effects
NA | NA | NA | NA | NA | NA | NA

* Side effect categories are not mutually exclusive, since some patients may have experienced more than one side effect.

** Method of assessment:

1 Interviewer-administered side-effect checklist.
2 Self-administered side-effect checklist.
3 Open-ended question asked at each visit.
4 Investigator observed at each visit.
5 Spontaneous reporting by patient.
6 Not specified.

NA = not available.