# Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency for Health Care Policy and Research. We acknowledge the assistance of Jacqueline Besteman, J.D., M.A., the AHCPR Project Officer for the Evidence-based Practice Center Program, and Ernestine Murray, the AHCPR Task Order Officer for this project. The investigators appreciate the considerable help of the data abstractors: David Overstreet, Ph.D., Alexei Kampov, Ph.D., Nancy Berkman, Ph.D., and Alicia Wilson, M.S.R.Ph. We thank the following individuals from the University of North Carolina at Chapel Hill: Gordon DeFriese, Ph.D., Co-Director of the RTI-UNC Evidence-based Practice Center; Joanne M. Garrett, Ph.D.; and Lynn Whitener, M.S.L.S. We also thank the following individuals from Research Triangle Institute: Nicole Walker for her valuable contract assistance and Linda Fonville for excellent secretarial support.