# Discussion

## Introduction

In this chapter, we discuss the overall conclusions and implications of our analysis of information presented in the evidence tables and in Chapter 3.The discussion is presented in descending order of demonstrated efficacy of the medications we studied for this report.

## Medication-Specific Conclusions and Implications

### Naltrexone and Acamprosate

Overall, the evidence-based review demonstrated that two pharmacologic agents - naltrexone and acamprosate - have moderate and strong evidence of efficacy in treating patients with alcohol dependence. Specifically, we found evidence that: naltrexone and acamprosate lead to reductions in drinking frequency; naltrexone leads to a reduction in drinking quantity, an outcome not measured in the acamprosate trials; acamprosate and (to a lesser extent) naltrexone help maintain abstinence from alcohol in some studies; naltrexone helps prevent relapse to heavy drinking, another measure not ascertained in the acamprosate trials; and naltrexone may be effective in reducing the "high" in response to drinking in alcohol-dependent patients. We considered the evidence for efficacy to be at an "A level" for both these agents because each has been demonstrated to be more efficacious than placebo in more than one RCT with adequate sample sizes and without evidence of substantial harm. Currently, naltrexone is approved for the treatment of alcohol dependence in the United States and at least 18 other countries. Eighteen trials targeting about 3,000 subjects are being conducted under the sponsorship of the National Institute on Alcohol Abuse and Alcoholism (NIAAA), and 600 subjects will be studied in a cooperative trial funded by the Department of Veterans Affairs. Acamprosate, currently approved in many European countries, is undergoing a large-scale clinical trial in this country seeking FDA approval. The trial is being sponsored by Lipha Pharmaceuticals and involves about 450 subjects.

The evidence for efficacy of these agents in the treatment of alcohol dependence is strong, but the magnitude of the benefit is variable. For example, as documented in the evidence tables, acamprosate consistently reduced drinking frequency by 40 to 60 percent over 6 to 12 months, although its effects on maintaining abstinence ranged from no effect to a doubling of abstinence rates. However, a majority of patients receiving acamprosate did return to some degree of drinking during these trials. With naltrexone, drinking frequencies and relapse rates were reduced by about 50 percent over the 3 months of the trials; compliance being a significant predictive factor of drug effect in one study (Volpicelli, Rhines, Rhines, et al., 1997). In the naltrexone trials, a majority of subjects also returned to some degree of drinking regardless of medication status so that only marginal evidence was found that naltrexone enhanced abstinence.

Therefore, although the studies consistently demonstrate that both acamprosate and naltrexone are more effective than placebo in treating patients with alcohol dependence, the magnitude of the benefit is open to interpretation. If the goal of treatment is to ensure continuous abstinence, a goal of most programs, then the effects of the medications appear modest at best. If, however, the goal of treatment is to diminish the intensity and frequency of alcohol consumption, then the outcomes are more impressive. Finally, clinicians will recognize that these results are averages across study populations; if a medication is beneficial to an individual, then the effect for that one patient can be substantial.

The benefits observed with naltrexone and acamprosate also must be considered in the context of study settings that probably maximize the benefit of the therapy. Many of the trials were performed either at or in conjunction with academic centers. Patients were willing to commit to a controlled study, with all of the attendant effort of having an extensive introductory physical and psychological evaluation, completing forms, and returning for followup visits more frequently than might be the case in a practice situation. Thus, the patients enrolled in these trials probably had a somewhat greater commitment to abstinence and an overall better prognosis than would the average alcohol-dependent patient. The quality of care provided within controlled studies is generally excellent, so the trials are representative of "best case" clinical care.

These two issues (volunteer effect and excellent clinical care in the controlled study context) do not affect the above statements regarding the efficacy of naltrexone and acamprosate, but they may affect the generalizability of the results. The reported efficacy probably represents the greatest benefit that might be expected given committed patients, first-rate care settings, and skilled caregivers. Average patients in typical care settings will likely show less benefit than reported in these trials. Thus, an important next step would be to conduct effectiveness studies of these medications.

Patients in these controlled studies were almost always receiving either individualized or group therapy for their alcohol dependence, typically provided in a substance abuse treatment setting. The nature of the co-intervention varied, including cognitive-behavioral and supportive treatment, but multiple models were used. Many of the co-interventions, particularly in the acamprosate trials, were not described in sufficient detail to allow detailed assessment of the co-intervention or replication studies. Future research should describe these co-interventions better.

The available data do not allow a determination of the efficacy of these medications if used with minimal psychosocial co-intervention in a setting such as a primary care physician's office. We recommend that these two issues - use of the medication with varying intensities of psychosocial treatment, and studies of these medications in primary care settings - be the subjects of future research since both factors may substantially affect the cost and generalizability of medication use.

Another issue that emerges from the naltrexone trials is the importance of ensuring patient compliance with the medication in order to detect and obtain a pharmacologic effect. The 1997 Volpicelli, et al., report is noteworthy here, as it documented limited effects of naltrexone in the overall trial but significant naltrexone effects in subjects considered compliant with pharmacotherapy. These findings suggest that studies of intervention methods designed to enhance compliance with pharmacotherapy represent another important area for future research in alcohol dependence.

### Disulfiram

The efficacy grade for disulfiram was a B. Sufficient data of reasonable quality were available to evaluate efficacy, but the results were inconsistent across studies and even within studies. Given these diverse findings from clinical trials, the role of disulfiram in the treatment of alcoholism remains ambiguous.

Disulfiram has been available for the treatment of alcoholism for close to 50 years, and initially there was great hope that it might revolutionize the treatment of the disease. Many articles were published about disulfiram's effectiveness, but the majority were about open trials or case series and subject to all the biases associated with such designs. The completion of double-blind, placebo-controlled trials provided the first opportunity for the field to evaluate the efficacy of disulfiram in a scientifically controlled fashion. Perhaps surprisingly, given the longevity of the clinical use of the drug, the results of these trials were not uniformly supportive of the efficacy of disulfiram. For example, no evidence was found that disulfiram enhanced abstinence, although two studies, including the large, high-quality trial by Fuller, Branchey, Brightwell, et al. (1986) and a study by Chick, Gough, Falkowski, et al. (1992), did find that disulfiram was associated with fewer drinking days.

Disulfiram is unique among the pharmacotherapeutic agents reviewed because it is the only medication that attempts to exert a therapeutic effect by producing a negative consequence should alcohol be consumed. This action, in turn, complicates interpretation of double-blind, placebo-controlled clinical trials because subjects receiving placebo are faced with the same psychological deterrent effect as those receiving disulfiram. Subjects who then take their medication and believe they are on disulfiram might be discouraged from drinking regardless of whether they are on placebo or disulfiram. In fact, Fuller, Branchey, Brightwell, et al. (1986) found that, independent of drug condition, subjects who complied with treatment demonstrated much higher abstinence rates than those who did not. The compliance factor was stronger than the medication factor when abstinence was the measured outcome.

Subjects who sample alcohol while on a sensitizing dose of disulfiram will experience adverse reactions, so this effect should reinforce the psychological deterrent effect and represent a true pharmacological effect of the drug. One of the few positive outcomes for disulfiram in some of the controlled trials is that subjects on disulfiram had significantly fewer drinking days. This effect might arise if subjects who were not deterred from drinking by the threat of a disulfiram-ethanol reaction were deterred from drinking further when they experienced adverse responses upon drinking. This cannot be ascertained from the trials, but it may represent a useful hypothesis to test.

With compliance emerging as an important factor in the use of disulfiram, the question of how to maximize compliance becomes an important consideration. Supervised disulfiram administration is one method to enhance compliance, but this method has been studied in only one controlled trial (Chick, Gough, Falkowski, et al., 1992). In that trial patients receiving disulfiram drank less alcohol and drank less frequently although their rates of abstinence were not reported. However, the patients were unblinded to their medication condition once randomization had occurred, so this trial does not meet the criteria for a double-blind, placebo-controlled trial.

Finally, the use of disulfiram implants has also been tested as a method to ensure compliance. These trials have produced mixed although primarily negative findings. Again, the issue of the psychological deterrent effect must be considered in the results of these trials and their general failure to find significant drug effects.

The problem of the bioavailability of disulfiram implants is, perhaps, the most substantive methodological concern. The trials generally implanted standard disulfiram tablets at doses of 800 to 1000 mg at the beginning of the trial and then followed patients for up to 48 weeks. The bioavailability of disulfiram under these conditions would not be expected to be adequate to ensure a sensitizing effect late in the course of treatment. Johnsen, Stowell, Bache-Wiig, et al. (1987) found no differences in response to repeated ethanol challenges between disulfiram and sham implant subjects over a 20-week trial. Efforts to improve disulfiram implants continue; only when this methodology is shown to provide adequate disulfiram bioavailability can the effectiveness of implants be better evaluated.

### Lithium

The lithium data are sufficient to suggest that lithium is not an effective treatment for primary alcoholism, and lithium received a grade of C. The results from the highest-quality controlled study in alcoholics without comorbid mood disorders were negative (Dorus, Ostrow, Anton, et al., 1989). Even the data on use of lithium in depressed alcoholic populations are mixed, and we did not review the efficacy of lithium with respect to misuse of alcohol in bipolar subjects. Based on all the lithium studies that were reviewed, additional investigation of lithium in primary alcoholics without mood disorders is likely to be of little value.

### Serotonergic Agents

#### Selective Serotonergic Reuptake Inhibitors

The use of SSRIs as a treatment for primary alcoholism was given an I rating, which indicates that the data to determine efficacy were judged to be insufficient. The total sample size, considering all the reviewed trials, was fewer than 250 subjects. The largest study (Kranzler, Burleson, Korner, et al., 1995) involved 101 subjects, some of whom also had comorbid depression. With so few studies, each with a small sample size, a determination of efficacy could not be made. The data that do exist are not very promising; thus, additional studies of SSRIs in primary alcoholism would appear to have limited value. Data on the use of SSRIs in alcohol-dependent persons with comorbid depression or anxiety also are limited, but results from seven ongoing studies sponsored by the NIAAA involving on the order of 1,100 subjects and a large multisite trial of sertraline sponsored by Pfizer Pharmaceuticals may be able to provide a more definitive answer on drug efficacy in this important subgroup of alcohol-dependent patients.

#### Buspirone and Ondansetron

Like the SSRIs, very limited information was available regarding the efficacy of buspirone and ondansetron for treatment of alcohol dependence, resulting in a grade of I. As with the SSRIs, the available data are not strongly supportive of further study of buspirone and ondansetron in primary alcoholics. The data regarding the use of buspirone in alcoholism with comorbid anxiety also are limited and mixed, but in our judgment additional study of this population may have value.

## Overall Comments

The preponderance of evidence demonstrates that several pharmacologic agents benefit patients with alcohol dependence when they are used in tandem with psychosocial therapy. Many patients who receive these therapies will not remain completely abstinent. The social and health impacts of reduced alcohol consumption in an alcohol-dependent patient population have not been examined in sufficient detail, and this should be the subject of future research. Among the key questions are whether receipt of such therapy reduces time off from work, reduces health care costs, and improves relationships with spouses, partners, or other family members.

The gains made in the pharmacologic treatment of alcohol dependence over the past decade are exciting. Nonetheless, they are not sufficient to conclude that currently available medications alone can solve this continuing and enormous health and social problem. An analogy may be appropriate in this setting: in the 1950s medications were discovered that were effective for treating patients with depression. Before this time, the idea of using a medication to treat a disorder that involved decreased self-esteem, guilt, and even suicidal tendencies appeared far-reaching. Once the efficacy of these agents was established, the development of the pharmacological treatment of depression accelerated rapidly. New agents with fewer side effects were developed; the need for long-term maintenance treatment for some depressed patients was made clear in placebo-controlled trials; and the heterogeneity of drug response, whereby some patients will respond to one class of antidepressants but not to another, was noted.

This analogy can be applied to the status of the pharmacotherapy of alcohol dependence in the late 1990s. New agents with new mechanisms of action have been identified and shown to be superior to placebo in the treatment of alcoholism. These promising findings should encourage clinicians and researchers to demonstrate the generalizability of the findings to other treatment settings and patient populations, to develop other agents (or combinations of existing agents) that will be successful in more patients, and to evaluate the benefits of longer-term pharmacotherapy. We pick up the thread of the research issues in the following chapter.