# Appendix C. Abstraction Forms

## Adverse Events (AE) for Pharmacologic Treatments of Alcoholism - Abstraction FormProject 6919-105

Adverse Events (AE) for Pharmacologic Treatments of Alcoholism - Abstraction Form Project 6919-105 Appendix C. Abstraction Forms

Adverse Events (AE) for Pharmacologic Treatments of Alcoholism - Abstraction Form Project 6919-105 Appendix C. Abstraction Forms

Drug: ____________________ | | | | Code: ______
AE | Active (%) | Placebo (%) | Statistical significance | How AE measured | Comments

## Data Extraction Elements for Pharmacotherapies in Alcohol Dependence

### I. STUDY CHARACTERISTICS

Name of Reviewer | ___ ___ ___ | Date | ___ ___/___ ___ | Unique Article Identifier | \|__\|__\|__\|
| (Initials) | | (Mo/Day) | | (ProCite #, 3 digits)

Study Design (check one) Randomized controlled trial (traditional methods) Non-randomized controlled trial/Prospective cohort study with concurrent control group Prospective cohort study with historical control group Retrospective cohort study with control group (any type) Case-control Other (describe in space to right) ________________________________________ Not stated

Blinding: | [image] Single | [image] Double | [image] Not stated | [image] None
Length of Efficacy Study
Blinded period of study: | | _____ | [image] Weeks | [image] Months
Unblinded period of study: | | _____ | [image] Days | [image] Weeks | [image] Unspecified | [image] None
Total length of Active Drug Treatment: | | | _____ | [image] Weeks | [image] Months
Dose Titration Used? | | [image] Yes | No/Not stated
Recruitment Setting: | | [image] Inpatient | [image] Outpatient | Not stated
Pre-Treatment:
Detox | [image] Yes | [image] No | [image] Not stated
Abstinent | [image] Yes | [image] No | [image] Not stated
| [image] ___ | [image] Days | [image] Weeks | [image] Months | [image] Not stated

Psychosocial Treatment [image] Inpatient[image] Day hospital[image] Outpatient[image] Mixed[image] None

Practice Setting: Number of Sites: ___________

University Affiliation: | [image] Academic | [image] Non-academic | [image] Not stated
Geographic Locale: | [image] United States | [image] Europe | [image] Other | [image] Not stated

[image] Not Stated

Definition of Alcohol Dependence: (Describe how authors define alcoholism or alcohol dependence. EXCLUDE ARTICLES THAT USE HEAVY SOCIAL DRINKING OR ALCOHOL ABUSE):

- Criteria for Alcohol Dependence Diagnosis:
- DSM-III
- DSM-III-R
- DSM-IV
- ICD-9
- ICD-10
- National Council on Alcoholism
- If none of the above are checked, specify criteria for alcohol dependence diagnosis:

- How were criteria assessed: (Check all that apply)
- Structured interview with individual (self-report) (e.g., SCID)
- Diagnostic Interview Schedule (DIS)
- Computerized Diagnostic Interview Schedule (CDIS)
- Structured interview with proxy
- Clinical observation/interview
- Other (specify) ____________________
- Not stated/Don't know

- Inclusion Criteria
- Age
- Sex
- Medical illnesses (both specified and unspecified)
- Psychiatric illness -> Depression Anxiety
- Laboratory values
- Pattern of alcohol consumption
- Length of abstinence
- Other
- Not stated

- Exclusion Criteria
- Age
- Sex
- Medical illnesses (both specified and unspecified)
- Non-alcohol drug abuse
- Psychiatric illness
- Previous alcoholism treatment
- Current medications
- Laboratory values
- Pregnant/lactating women
- Length of abstinence
- Other
- Not stated

- Author's Definition of Relapse: (Check all that apply)
- Any alcohol consumption
- Number of drinks in a given unit of time (specify) ___________________________
- Number of days of drinking in a given unit of time (specify) ________________________
- Blood alcohol level/Breathalizer
- Other
- Not stated

- How relapse measured: (Check all that apply)
- Structured interview with individual (self-report)
- Unspecified self-report
- Structured interview with proxy
- Clinical observation/interview
- Liver function tests
- Carbohydrate deficient transferrin (CDT)
- Other (specify) _________________
- Not stated
- Not measured

- Craving
- Analog scale
- Ordinal scale
- Other (specify) _____________________________________
- Not stated/Don't know
- Not measured

Compliance with Treatment | Method Used ([image] all that apply) | Specify Acceptable Range | Measured in Both Placebo and Active ([image])
Urine marker, e.g., % visits with active drug
Blood levels, e.g., mg/ml
Pill count, e.g., % of drug taken
Self-report of compliance
Proxy report of compliance
Visit attendance, i.e., % visits with appropriate treatment
Other (specify) _____________________________

Statistical Analysis

- Statistical Methods:
- Student's t-test
- Fisher's Exact Test
- Kaplan Meier
- Chi-square
- ANOVA
- ANACOVA (Analysis of covariance) or ANCOVA
- MANCOVA
- Regression
- Non-parametric tests (Rankings such as Wilcoxen, Mann-Whitney U, etc.)
- Multiple comparisons
- Other (specify) __________
- Not stated

Specifies Intent to Treat Analysis? [image] Yes [image] No [image] Not stated

Demographic information for randomized population only.
| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other

History of Alcohol Dependence of Control Group: Not stated

[Control Group]

Age at onset: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated
Years since onset of alcohol dependence: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated

### II. Characteristics of the Study Population

(Any control/comparison group should be listed first.)

#### [Control Group]

CONTROL Group No Control Group

Drug intervention(s) of Control Group: | Frequency of administration comparable to intervention groups?
Placebo | [image] Yes [image] No
No Drug

Psychosocial intervention(s) of Control Group: | Program Intensity ([image])
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Controls: Not stated

Screened _____ | Initially entered trial _____ (after randomization) | Final number at end of trial _____

Note: | Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.

- Dropout:Number _____Rate _____ Not statedDropout due to adverse events:Number _____Rate _____ Not statedLoss to followup:Number _____Rate _____ Not stated

Family History of Alcohol Dependence or Alcoholism of Control Group: Not stated Number ___________ Percent ___________

[image] Not stated
Addiction Severity at Study Entry of Control Group | Check all that apply ([image])

[image] Not stated
Comorbidities of Control Group: | Check all that apply ([image]) | Number | Percentage

Number of Prior Substance Abuse Treatment Experiences of Control Group:

- Not measured
- Mean _____ Range _____ Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

#### INTERVENTION Group 1

Drug intervention(s) of Intervention Group 1: | Maximum dose/day | Units | Dosage varies ([image])
Disulfiram | | [image] mg [image] Other (specify) ________________
Naltrexone | | [image] mg [image] Other (specify) ________________
Acamprosate | | [image] mg [image] Other (specify) ________________
Serotonergic Agent: ___________________________ | | [image] mg [image] Other (specify) ________________
Lithium (all types) | | [image] mg [image] Other (specify) ________________
Placebo | | [image] mg [image] Other (specify) ________________

Psychosocial intervention(s) of Intervention Group 1: | Program Intensity ([image])
Psychosocial intervention(s) of Intervention Group 1: | Required attendance | Encouraged attendance
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Patients in Intervention Group 1: Not stated

Screened _____ | Initially entered trial _____ (after randomization) | Final number at end of trial _____

Note: | Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.

- Dropout:Number _____Rate _____ Not statedDropout due to adverse events:Number _____Rate _____ Not statedLoss to followup:Number _____Rate _____ Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Control Group: [image] Not stated

Age at onset: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated
Years since onset of alcohol dependence: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated

Family History of Alcohol Dependence or Alcoholism of Intervention Group 1: Not stated Number _____ Percent _____

[image] Not stated
Addiction Severity at Study Entry of Intervention Group 1 | Check all that apply ([image])

[image] Not stated
Comorbidities of Intervention Group 1: | Check all that apply([image]) | Number | Percentage

Number of Prior Substance Abuse Treatment Experiences of Intervention Group 1: Not measured

Mean _____ | Range _____ | Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

#### INTERVENTION Group 2

Drug intervention(s) of Intervention Group 2: | Maximum dose/day | Units | Dosage varies ([image])
Disulfiram | | [image] mg [image] Other (specify) ________________
Naltrexone | | [image] mg [image] Other (specify) ________________
Acamprosate | | [image] mg [image] Other (specify) ________________
Serotonergic Agent: __________________________ | | [image] mg [image] Other (specify) ________________
Lithium (all types) | | [image] mg [image] Other (specify) ________________
Placebo | | [image] mg [image] Other (specify) ________________

Psychosocial intervention(s) of Intervention Group 2: | Program Intensity ([image])
Psychosocial intervention(s) of Intervention Group 2: | Required attendance | Encouraged attendance
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Patients in Intervention Group 2: Not stated

Screened _____ | Initially entered trial _____ (after randomization) | Final number at end of trial _____

- Note: Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.
- Dropout:Number _____Rate _____ Not statedDropout due to adverse events:Number _____Rate _____ Not statedLoss to followup:Number _____Rate _____ Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Intervention Group 2: [image] Not stated

Age at onset: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated
Years since onset of alcohol dependence: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated

Family History of Alcohol Dependence or Alcoholism of Intervention Group 2: Not stated Number _____ Percent _____

[image] Not stated

[image] Not stated
Comorbidities of Intervention Group 2: | Check all that apply ([image]) | Number | Percentage

Number of Prior Substance Abuse Treatment Experiences of Intervention Group 2: Not measured

- Mean _____ Range _____ Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

#### INTERVENTION Group 3

Drug intervention(s) of Intervention Group 3: | Maximum dose/day | Units | Dosage varies ([image])
Disulfiram | | [image] mg [image] Other (specify) ________________
Naltrexone | | [image] mg [image] Other (specify) ________________
Acamprosate | | [image] mg [image] Other (specify) ________________
Serotonergic Agent: | | [image] mg [image] Other (specify) ________________
Lithium (all types) | | [image] mg [image] Other (specify) ________________
Placebo | | [image] mg [image] Other (specify) ________________

Psychosocial intervention(s) of Intervention Group 3: | Program Intensity ([image])
Psychosocial intervention(s) of Intervention Group 3: | Required attendance | Encouraged attendance
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract > [image] Yes [image] No [image] Not stated

Total Number of Patients in Intervention Group 3: Not stated

- Screened _____ Initially entered trial _____ (after randomization) Final number at end of trial _____

- Note: Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.
- Dropout:Number _____Rate _____ Not statedDropout due to adverse events:Number _____Rate _____ Not statedLoss to followup:Number _____Rate _____ Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % African Americans | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Intervention Group 3: [image] Not stated

Age at onset: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated
Years since onset of alcohol dependence: | Mean ______ | Range ______ | Std Dev: ______ | [image] Not stated

Family History of Alcohol Dependence or Alcoholism of Intervention Group 3: Not stated Number _____ Percent _____

[image] Not stated

[image] Not stated

Number of Prior Substance Abuse Treatment Experiences of Intervention Group 3: Not measured

Mean _____ | Range _____ | Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

### III. Results

What were the changes in outcome(s) that resulted from the intervention for each group? These should be recorded in units used as the outcome measure(s) (e.g., reduction in the number of standard drinks consumed per time period, time to relapse, number of episodes of heavy drinking per time period, etc.). Any measures of central tendency or dispersion (i.e., standard deviation) should be reported. Test statistics and significance levels should be included.

#### [Control Group]

CONTROL GROUP Enter information for all outcomes that apply: Alcohol Intake of Control Group

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

#### Intervention Group 1

Enter information for all outcomes that apply: Alcohol Intake of Intervention Group 1

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

#### Intervention Group 2

Enter information for all outcomes that apply: Alcohol Intake of Intervention Group 2

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

#### Intervention Group 3

Enter information for all outcomes that apply: Alcohol Intake of Intervention Group 3

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### IV. Study Summary

Analysis by Groups on Side Effects: (Article must provide a rate or percent by treatment group or have sufficient information so that rates or percents can be calculated in order to check "yes" and flag.)

- Yes (flag article)
- No
- Not stated

Factors Controlled for in the Analysis

- Age
- Sex
- Family history of alcoholism
- Others (Specify) ____________
- Not stated

Limitations Noted in Article by Authors No limitations in the article

- Sub-therapeutic dosing
- Alcohol consumption unverified
- High dropout rate
- Low severity of alcohol dependence
- Compliance problem
- Others (Specify) ____________

Limitations Noted by Reviewer No limitations by reviewer

- Sub-therapeutic dosing
- Alcohol consumption unverified
- High dropout rate
- Low severity of alcohol dependence
- Compliance problem
- Others (Specify) ____________

Conclusions Noted in Article

- Intervention(s) showed efficacy
- Intervention(s) did not show efficacy
- Others (Specify) ____________
- Not stated

Attachments: Comorbid Groups Followup Results

Comments

- Subgroup analysis
- Additional outcomes recorded here

### V. Quality Rating Scale

for Alcohol Dependence Pharmacotherapy Review

Category 1: Problem or Question Studied (5 points)
| Not at All | Somewhat | Okay
Alcohol dependence problem clearly stated? | 0 | 1 | 2
| Little or No | Yes
Significance of alcohol dependence problem discussed? | 0 | 1
| No | Yes
Is research question capable of being answered with the methods proposed? | 0 | 1
| No | Yes
Is the question placed in the broader context of alcohol research? | 0 | 1

Category 2: Sampling (5 points)
| No | Yes
Random allocation of treatment? | 0 | 2
| Unknown or >40% | <40%
Dropout rate of patients invited into the study? | 0 | 1
| No | Yes
Diagnostic criteria clearly specified? | 0 | 1
| No | Yes
Is the sample clearly described? | 0 | 1

Category 3: Measurement (5 points)
| No | Yes
Reliability/validity of the diagnostic measurement tool specified or referenced? | 0 | 1
| No | Yes
Reliability/validity of the outcome measurement tool specified or referenced? | 0 | 2
| No | Yes
Compliance with regimen assessed (pill count, biologic marker, etc.)? | 0 | 1
| No | Yes
Are the outcome measurements clinically relevant? | 0 | 1

Category 4: Internal Validity (5 points)
| No | Yes | NA
Are potential confounding effects addressed (differences between two groups such as age, gender, type of alcohol dependence, other substance abuse)? | 0 | 1
| No | Yes
Was the co-intervention (e.g., psychotherapy) similar between two study groups? | 0 | 1 | [image]
| No | Yes
Was the co-intervention (e.g., psychotherapy) compliance monitored? | 0 | 1 | [image]
| No | Yes
Was a concurrent control group present? | 0 | 2

Category 5: External Validity (5 points)
| No | Yes
Do the study conclusions apply to U.S. alcohol-dependent patients? | 0 | 3
| No | Yes
Is the clinical setting specified clearly? | 0 | 2

Category 6: Construct Validity (5 points)
| No | Yes
Appropriate alcohol dependence diagnostic criteria used? | 0 | 2
| No | Yes
Do the measured outcomes relate to the construct of alcohol dependence? | 0 | 2
| No | Yes
Are other variables clearly described in terms of their relationship to alcohol dependence? | 0 | 1

Category 7: Statistical Conclusions (5 points)
| No | Yes | NA
If multiple univariate tests performed, multiple comparisons taken into account? | 0 | 1 | [image]
| No | Yes
Power analysis performed? | 0 | 1
| No | Yes
In regression analysis, is number of variables in model less than 1/10th of the sample size? | 0 | 1 | [image]
| No | Yes
Are statistically significant findings clinically significant? | 0 | 1
| No | Yes
Are statistical tests used appropriate to the data? | 0 | 1

Category 8: Justification for Conclusions (5 points)
| No | Yes
Are the conclusions warranted from the data? | 0 | 5

## [Comorbid Intervention]

### [Control Group]

Reviewer ___ ___ ___ | Date ___ ___ / ___ ___ | Unique Article ID | \|__\|__\|__\| (ProCite #, 3 digits)
Comorbid Condition: | [image] depression [image] anxiety [image] other (Specify) _______________
IIA. CHARACTERISTICS OF THE COMORBID STUDY POPULATION
(Any control/comparison group should be listed first.)

COMORBID CONTROL Group No Control Group

Drug intervention(s) of Comorbid Control Group: | Frequency of administration comparable to intervention groups?
Placebo | [image] Yes [image] No
No Drug

Psychosocial intervention(s) of Comorbid Control Group: | Program Intensity ([image])
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Comorbid Controls: Not stated

Screened _____ | Initially entered trial _____ (after randomization) | Final number at end of trial _____

Note: | Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.

Dropout: | Number _____ | Rate _____ | [image] Not stated
Dropout due to adverse events: | Number _____ | Rate _____ | [image] Not stated
Loss to followup: | Number _____ | Rate _____ | [image] Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Comorbid Control Group: [image] Not stated

- Age at onset:Mean ______Range ______Std Dev: ______ Not statedYears since onset of alcohol dependence:Mean ______Range ______Std Dev: ______ Not stated

Family History of Alcohol Dependence or Alcoholism of Comorbid Control Group: [image] Not stated Number _____ Percent _____

[image] Not stated

[image] Not stated

Number of Prior Substance Abuse Treatment Experiences of Comorbid Control Group: Not measured

- Mean _____ Range _____ Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

### COMORBID INTERVENTION Group 1

Drug intervention(s) of Comorbid Intervention Group 1: | Maximum dose/day | Units | Dosage varies ([image])
Disulfiram | | [image] mg [image] Other (specify) ______________
Naltrexone | | [image] mg [image] Other (specify) ______________
Acamprosate | | [image] mg [image] Other (specify) ______________
Serotonergic Agent: _________________ | | [image] mg [image] Other (specify) ______________
Lithium (all types) | | [image] mg [image] Other (specify) ______________
Placebo | | [image] mg [image] Other (specify) ______________

Psychosocial intervention(s) of Comorbid Intervention Group 1: | Program Intensity ([image])
Psychosocial intervention(s) of Comorbid Intervention Group 1: | Required attendance | Encouraged attendance
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Patients in Comorbid Intervention Group 1: Not stated

- Screened _____ Initially entered trial _____ (after randomization)Final number at end of trial _____
- Note: Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.
- Dropout:Number _____Rate _____ Not statedDropout due to adverse events:Number _____Rate _____ Not statedLoss to followup:Number _____Rate _____ Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Comorbid Intervention Group 1: [image] Not stated

- Age at onset:Mean ______Range ______Std Dev: ______ Not statedYears since onset of alcohol dependence:Mean ______Range ______Std Dev: ______ Not stated

Family History of Alcohol Dependence or Alcoholism of Comorbid Intervention Group 1: [image] Not stated

Number _____ | Percent _____

[image] Not stated

[image] Not stated

Number of Prior Substance Abuse Treatment Experiences of Comorbid Intervention Group 1: Not measured

- Mean _____ Range _____ Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

### COMORBID INTERVENTION Group 2

Drug intervention(s) of Comorbid Intervention Group 2: | Maximum dose/day | Units | Dosage varies ([image])
Disulfiram | | [image] mg [image] Other (specify) ______________
Naltrexone | | [image] mg [image] Other (specify) ______________
Acamprosate | | [image] mg [image] Other (specify) ______________
Serotonergic Agent: _________________ | | [image] mg [image] Other (specify) ______________
Lithium (all types) | | [image] mg [image] Other (specify) ______________
Placebo | | [image] mg [image] Other (specify) ______________

Psychosocial intervention(s) of Comorbid Intervention Group 2: | Program Intensity ([image])
Psychosocial intervention(s) of Comorbid Intervention Group 2: | Required attendance | Encouraged attendance
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Patients in Comorbid Intervention Group 2: Not stated

Screened _____ | Initially entered trial _____ (after randomization) | Final number at end of trial _____

Note: | Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.

Dropout: | Number _____ | Rate _____ | [image] Not stated
Dropout due to adverse events: | Number _____ | Rate _____ | [image] Not stated
Loss to followup: | Number _____ | Rate _____ | [image] Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Comorbid Intervention Group 2: [image] Not stated

- Age at onset:Mean ______Range ______Std Dev: ______ Not statedYears since onset of alcohol dependence:Mean ______Range ______Std Dev: ______ Not stated

Family History of Alcohol Dependence or Alcoholism of Comorbid Intervention Group 2: [image] Not stated

- Number _____ Percent _____

[image] Not stated

[image] Not stated

Number of Prior Substance Abuse Treatment Experiences of Comorbid Intervention Group 2: Not measured

- Mean _____ Range _____ Standard deviation _____

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

### COMORBID INTERVENTION Group 3

Drug intervention(s) of Comorbid Intervention Group 3: | Maximum dose/day | Units | Dosage varies ([image])
Disulfiram | | [image] mg [image] Other (specify) ______________
Naltrexone | | [image] mg [image] Other (specify) ______________
Acamprosate | | [image] mg [image] Other (specify) ______________
Serotonergic Agent: _________________ | | [image] mg [image] Other (specify) ______________
Lithium (all types) | | [image] mg [image] Other (specify) ______________
Placebo | | [image] mg [image] Other (specify) ______________

Psychosocial intervention(s) of Comorbid Intervention Group 3: | Program Intensity ([image])
Psychosocial intervention(s) of Comorbid Intervention Group 3: | Required attendance | Encouraged attendance
Alcoholics Anonymous
Group program/counseling
Individualized program/counseling
Family counseling
Unspecified
None
Contract [image] Yes [image] No [image] Not stated

Total Number of Patients in Comorbid Intervention Group 3: Not stated

Screened _____ | Initially entered trial _____ (after randomization) | Final number at end of trial _____

Note: | Information on dropouts and loss to followup on randomized subjects only, to explain difference between number entered and final number.

Dropout: | Number _____ | Rate _____ | [image] Not stated
Dropout due to adverse events: | Number _____ | Rate _____ | [image] Not stated
Loss to followup: | Number _____ | Rate _____ | [image] Not stated

Demographic information for randomized population only.

| N | % | Mean Age | Age SD | % White | % Black | % Hispanic | % Native American | % Other
Total
Males
Females

History of Alcohol Dependence of Comorbid Intervention Group 3: [image] Not stated

- Age at onset:Mean ______Range ______Std Dev: ______ Not statedYears since onset of alcohol dependence:Mean ______Range ______Std Dev: ______ Not stated

Family History of Alcohol Dependence or Alcoholism of Comorbid Intervention Group 3: [image] Not stated

- Number _____ Percent _____

[image] Not stated

[image] Not stated

Number of Prior Substance Abuse Treatment Experiences of Comorbid Intervention Group 3: Not measured

- Mean _____ Range _____ Standard deviation _____

COMORBID INTERVENTION Group 3

Patients with prior treatments | Number | Percentage
None
One or More
Unspecified Substance Abuse

## IIIa. Comorbid Results

What were the changes in outcome(s) that resulted from the intervention for each group? These should be recorded in units used as the outcome measure(s) (e.g., reduction in the number of standard drinks consumed per time period, time to relapse, number of episodes of heavy drinking per time period, etc.). Any measures of central tendency or dispersion (i.e., standard deviation) should be reported. Test statistics and significance levels should be included.

### Comorbid Control Group

Enter information for all outcomes that apply: Alcohol Intake of Comorbid Control Group

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### COMORBID INTERVENTION Group 1

Enter information for all outcomes that apply: Alcohol Intake of Comorbid Intervention Group 1

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### COMORBID INTERVENTION Group 2

Enter information for all outcomes that apply: Alcohol Intake of Comorbid Intervention Group 2

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### COMORBID INTERVENTION Group 3

Enter information for all outcomes that apply: Alcohol Intake of Comorbid Intervention Group 3

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

## [Followup Results]

Reviewer ___ ___ ___ | Date ___ ___ / ___ ___ | Unique Article ID | \|__\|__\|__\| (ProCite #, 3 digits)
IIIB. FOLLOWUP RESULTS--POST EFFICACY STUDY

What were the changes in outcome(s) that resulted from the intervention for each group during the followup period? These should be recorded in units used as the outcome measure(s) (e.g., reduction in the number of standard drinks consumed per time period, time to relapse, number of episodes of heavy drinking per time period, etc.). Any measures of central tendency or dispersion (i.e., standard deviation) should be reported. Test statistics and significance levels should be included.

THE ONLY RESULTS TO GO ON THIS FORM APPLY TO THE FOLLOWUP PERIOD. Length of Post Efficacy Period _____ Weeks Months Population included in followup period?

- Original efficacy population (with some dropouts)
- Subgroup (Specify) __________________________________

### Followup Control Group

Enter information for all outcomes that apply: Alcohol Intake of Followup Control Group

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### FOLLOWUP INTERVENTION Group 1

Enter information for all outcomes that apply: Alcohol Intake of Followup Intervention Group 1

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### FOLLOWUP INTERVENTION Group 2

Enter information for all outcomes that apply: Alcohol Intake of Followup Intervention Group 2

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

### FOLLOWUP INTERVENTION Group 3

Enter information for all outcomes that apply: Alcohol Intake of Followup Intervention Group 3

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated

[image] Not Stated