# Appendix A. Selection, Composition, and Role of Technical Expert Advisory Group

We gratefully acknowledge the substantial involvement of and assistance from the Technical Expert Advisory Group (TEAG). TEAG members are listed at the end of this appendix. The TEAG was meant in part to contribute to (a) advancing AHCPR's broader goals of creating and maintaining "science partnerships" and "public-private partnerships" and (b) meeting the needs of a broad array of potential customers and users of its products. Thus, it was both a substantive resource and a sounding board throughout the study, and it is the body from whom "expert inputs" were formally sought at several points throughout the project.

We constituted our TEAG from three types of technical experts and other partners. These types are (1) technical/clinical experts; (2) patients or representatives of organizations whose mission concerns the interests and perspectives of patients and consumers; and (3) potential users of the final evidence report or other materials, including explicitly a representative of the organization that nominated the topic (in this case, the American Society of Addiction Medicine [ASAM]). All in all, we had three clinical/technical experts, two individuals representing patient populations, and two individuals representing potential user groups, for a total of eight on the TEAG.

The final decision about TEAG membership was based on candidates' availability for scheduled conference calls and other input, willingness to review materials and provide advice and assistance within a short turnaround time, and approval by the AHCPR TO Officer.

The RTI-UNC Center team solicited the views of local and national experts on the TEAG from the start of the project. Their input at this stage was intended to make sure that the clinical questions we had posed about pharmacotherapy for alcohol dependence were important to patients and for high-quality patient care and that they could be satisfactorily addressed in an evidence report.

In addition, we sought input and direction from the clinical experts on the TEAG to assist us in the identification of pharmaceuticals that are being evaluated for the treatment of alcohol dependence but may not have been registered with the U.S. Food and Drug Administration (FDA). These pharmaceuticals may be undergoing clinical study in countries other than the United States. We also asked these experts to assist in identifying patient and consumer groups that represent patients at highest risk for alcohol dependence and in pinpointing practice settings that may be most directly affected by changes in treatment for this condition. The TEAG also provided input to our literature review process by advising us on the extent to which practices for the treatment of alcohol dependence vary across the Nation, settings, and clinicians.

In keeping with AHCPR's standards for employing a multidisciplinary approach to the development of evidence reports, we called on our TEAG for inputs at two key points during this task. First, the group was asked to comment on the literature synthesis and to give us feedback on our overall plans at that stage of the analysis, which included approaches to developing evidence tables and to summarizing information about patient outcomes and the estimated benefits and harms associated with the treatment options being studied for alcohol dependence. Second, they were asked to review the preliminary evidence tables to ascertain whether or not a meta-analysis was feasible and purposeful.

## TEAG Members

- Raymond F. Anton, M.D.
- Medical University of South Carolina
- Institute of Psychiatry

- Charles P. O'Brien, M.D., Ph.D.
- University of Pennsylvania
- Treatment Research Center

- Stephanie S. O'Malley, Ph.D.
- Yale University
- Department of Psychiatry
- Substance Abuse Treatment Unit

- Linda Powell, MSW, CCSW
- Merit Behavioral Care Corp.
- Raleigh, NC

- Bill Renn, CCSW, CSAC, CCS
- University of North Carolina at Chapel Hill
- School of Medicine, Department of Psychiatry
- Formerly of the Behavioral Medicine Center for
- Cumberland Hospital, Fayetteville, NC

- Connie Weisner, Dr.P.H.
- Alcohol Research Group and Kaiser Permanente
- Medical Care Program of Northern California

- Michael Mayo-Smith, M.D., M.P.H.
- Manchester Veterans Affairs Medical Center
- Manchester, NH

- Raye Z. Litten III, Ph.D.
- National Institute on Alcohol Abuse and
- Alcoholism
- Treatment Research Branch