# Bibliography

This bibliography does not contain the codes for the different categories of studies. A bibliography with codes in electronic form in a reference manager program is available upon request to the developers of the report.

Adelson PD, Kochanek PM. Head injury in children. J Child Neurol. 1998;13(1):2-15. [pmid: 9477242].
Alexander M. Acquired disabilities: new directions. Dev Med Child Neurol. 1993;35(9):753-4. [pmid: 8354428].
Alexander RC, Schor DP, Smith WL Jr. Magnetic resonance imaging of intracranial injuries from child abuse. J Pediatr. 1986;109(6):975-9. [pmid: 3783342].
Anderson VA. Residual attention deficits following childhood head injury: implications for ongoing development. Neuropsychol Rehabil. 1998;8(3):283-300.
Anderson VA, Moore C. Age at injury as a predictor of outcome following pediatric head injury: a longitudinal perspective. Child Neuropsychol. 1995;1:187-202.
Anderson VA, Morse SA, Klug G, et al. Predicting recovery from head injury in young children: a prospective analysis. J Int Neuropsychol Soc. 1997;3(6):568-80. [pmid: 9448370].
Anderson VA, Smibert E, Godber T. Declines in neuropsychological functioning following cranial irradiation therapy in childhood.[Abstract]. J Int Neuropsychol Soc. 1995;204.
Andrews TK, Rose FD, Johnson DA. Social and behavioural effects of traumatic brain injury in children. Brain Inj. 1998;12(2):133-8. [pmid: 9492960].
Anonymous. Learn family background of children with brain injury. Hosp Peer Rev. 1995;20(1):9-13. [pmid: 10153649].
Appleton R. Head injury rehabilitation for children. Nurs Times. 1994;90(22):29-31. [pmid: 8029039].
Aram DM. Spoken syntax in children with acquired unilateral hemisphere lesions. Brain Lang. 1986;27:75-100. [pmid: 3947945].
Aram DM. Language sequelae of unilateral brain lesions in children. Lang Commun Brain 1988:171-97. [pmid: 2451846].
Aram DM, Eisele JA. Intellectual stability in children with unilateral brain lesions. Neuropsychologia. 1994;32:85-95. [pmid: 8818157].
Aram DM, Ekelman BL, Rose DF, et al. Verbal and cognitive sequelae following unilateral lesions acquired in early childhood. J Clin Exp Neuropsychol. 1985;7(1):55-78. [pmid: 3980681].
Aram DM, Ekelman BL, Whitaker HA. Lexical retrieval in left and right brain-lesioned children. Brain Lang. 1987;31:61-87. [pmid: 3580840].
Armstrong RW, Steinbok P, Cochrane DD, et al. Intrathecally administered baclofen for treatment of children with spasticity of cerebral origin. J Neurosurg. 1997;87(3):409-14. [pmid: 9285607].
Arnarson EO, Halldorsson JG. Head trauma among children in Reykjavik. Acta Paediatr. 1995;84(1):96-9. [pmid: 7734911].
Asarnow RF, Satz P, Light R, et al. Behavior problems and adaptive functioning in children with mild and severe closed head injury. J Pediatr Psychol. 1991;16(5):543-55. [pmid: 1744804].
Asarnow RF, Satz P, Light R, et al. The UCLA study of mild closed head injury in children and adolescents. In: Broman S, Michel, ME, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Ashwal S, Eyman RK, Call TL. Life expectancy of children in a persistent vegetative state. Pediatr Neurol. 1994;10(1):27-33. [pmid: 8198669].
Asikainen I, Kaste M, Sarna S. Patients with traumatic brain injury referred to a rehabilitation and re-employment programme: social and professional outcome for 508 Finnish patients 5 or more years after injury. Brain Inj. 1996;10(12):883-99. [pmid: 8939307].
Asikainen I, Kaste M, Sarna S. Predicting late outcome for patients with traumatic brain injury referred to a rehabilitation programme: a study of 508 Finnish patients 5 years or more after injury. Brain Inj. 1998;12(2):95-107. [pmid: 9492958].
Bagnato SJ, Feldman H. Closed head injury in infants and preschool children: research and practice issues. Infant Young Child. 1989;2(1):1-13.
Bagnato SJ, Mayes SD. Patterns of developmental and behavioral progress for young brain-injured children during interdisciplinary intervention. Dev Neuropsychol. 1986;2:213-40.
Bagnato SJ, Mayes SD, Nichter C, et al. An interdisciplinary neurodevelopmental assessment model for brain-injured infants and preschool children. J Head Trauma Rehabil. 1988;3(2):75-86.
Bagnato SJ, Neisworth JT. Tracing developmental recovery from early brain injury. Remedial Spec Educ. 1986;7(5):31-6.
Bagnato SJ, Neisworth JT. Neurodevelopmental outcomes of early brain injury: a follow-up of fourteen case studies. Top Early Child Spec Educ. 1989;9(1):72-89.
Bailey DJ, Burchinal M, McWilliam R. Age of peers and early childhood development. Child Dev. 1993;64:287-309.
Baltes P. Theoretical propositions of life-span development psychology: on dynamics of growth and decline. Dev Psychol. 1987;23(5):611-26.
Baltes P, Reese H, Nesselroade J. Life-span development psychology: introduction to research methods. Monterey, CA: Brooks/Cole; 1977.
Banja JD, Jann BB. Ethical issues in treating pediatric rehabilitation patients. Neurorehabil. 1995;3(3):44-52.
Baracchini-Muratorio G, Cantini R, Pruneti CA. Neuropsychological sequelae after head injury with mesencephalic coma in childhood. J Neurosurg Sci. 1985;29(4):305-11. [pmid: 3841915].
Barry CT, Taylor HG, Klein S, et al. The validity of neurobehavioral symptoms reported in children with traumatic brain injury. Child Neuropsychol. 1996;2:193-203.
Barry P, Clark D. Effects of intact versus non-intact families on adolescent head injury rehabilitation. Brain Inj. 1992;6(3):229-32. [pmid: 1581746].
Bassett SS, Slater EJ. Neuropsychological function in adolescents sustaining mild closed head injury. J Pediatr Psychol. 1990;15(2):225-36. [pmid: 2374077].
Basso A, Scarpa MT. Traumatic aphasia in children and adults: a comparison of clinical features and evolution. Cortex. 1990;26(4):501-14. [pmid: 1706973].
Bawden HN, Knights RM, Winogron HW. Speeded performance following head injury in children. J Clin Exp Neuropsychol. 1985;7(1):39-54. [pmid: 3980680].
Beattie TF. Minor head injury. Arch Dis Child. 1997;77(1):82-5. [pmid: 9279162].
Beca J, Cox PN, Taylor MJ, et al. Somatosensory evoked potentials for prediction of outcome in acute severe brain injury. J Pediatr. 1995;126(1):44-9. [pmid: 7815222].
Beers SR. Cognitive effects of mild head injury in children and adolescents. Neuropsychol Rev. 1992;3(4):281-320. [pmid: 1284851].
Benz G, McIntosh A, Kallieris D, et al. A biomechanical study of bicycle helmets' effectiveness in childhood. Eur J Pediatr Surg. 1993;3(5):259-63. [pmid: 8292575].
Berger E, Worgotter G, Oppolzer A, et al. Neurological rehabilitation in children and adolescents. Pediatr Rehabil. 1997;1(4):229-33. [pmid: 9689259].
Berger K. The developing person through the life span. New York: Worth; 1998.
Bergman A. Brain Injury Association, Alexandria, VA. Personal communication, December 1998.
Bergman L, Eklund G, Magnusson D. Problems and methods in longitudinal research: stability and change. In: Magnusson D, Bergman L, Kudinger G, et al, editors, Studying individual development: problems and methods. New York: Cambridge University Press; 1991.
Berk L. Development through the lifespan. Boston: Allyn & Bacon; 1998.
Berney J, Favier J, Froidevaux AC. Paediatric head trauma: influence of age and sex. I. Epidemiology. Child Nerv Syst. 1994;10(8):509-16. [pmid: 7882373].
Berney J, Favier J, Rilliet B. Head injuries in children: a chronicle of a quarter of a century. Child Nerv Syst. 1995;11(5):256-64. [pmid: 7648565].
Berney J, Froidevaux AC, Favier J. Paediatric head trauma: influence of age and sex. II. Biomechanical and anatomo-clinical correlations. Child Nerv Syst. 1994;10(8):517-23. [pmid: 7882374].
Biagas KV, Gaeta ML. Treatment of traumatic brain injury with hypothermia. Curr Opin Pediatr. 1998;10(3):271-7. [pmid: 9716889].
Bigler ED, Clark E, Farmer JE. Childhood traumatic brain injury: diagnosis, assessment, and intervention. Austin, TX: Pro Ed, Inc; 1997.
Bijur PE, Haslum M, Golding J. Cognitive outcomes of multiple mild head injuries in children. J Dev Behav Pediatr. 1996;17(3):143-8. [pmid: 8783059].
Bijur PE, Haslum M, Golding J. Cognitive and behavioral sequelae of mild head injury in children. Pediatrics. 1990;86:337-44. [pmid: 2388783].
Bijur P, Haslum M. Cognitive, behavioral and motoric sequelae of mild head injury in a national birth cohort. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Bijur PE. Cognitive outcomes. J Dev Behav Pediatr. 1996;17(3). [pmid: 8783066].
Bishop D. Plasticity and specificity of language localization in the developing brain. Dev Med Child Neurol. 1981;23. [pmid: 7274599].
Bishop DS, Miller IW. Traumatic brain injury: empirical family assessment techniques. J Head Trauma Rehabil. 1988;3(4):16-30.
Blau A. Mental changes following head trauma in children. Arch Neurol Psychol 1936:723-65.
Blendonohy PM, Philip PA. Precocious puberty in children after traumatic brain injury. Brain Inj. 1991;5(1):63-8. [pmid: 2043909].
Blosser JL, DePompei R. The head-injured student returns to school: recognizing and treating deficits. Top Lang Disorders. 1989;9:67-77.
Blosser JL, DePompei R. A proactive model for treating communication disorders in children and adolescents with traumatic brain injury. Clin Commun Disorders. 1992;2(2):52-65. [pmid: 1301897].
Blosser JL, DePompei R. Creating an effective classroom environment. In: Savage R, editors, Educational dimensions of acquired brain injury. Austin, TX: Pro-Ed. Inc; 1994. p. 413-51.
Blosser J, Pearson S. Transition coordination for students with brain injury: a challenge schools can meet. J Head Trauma Rehabil. 1997;12(2):21-31.
Bohn D. Tools for predicting outcome in the neurologically injured child. Crit Care Med. 1993;21(9 Suppl):S332-3. [pmid: 8365212].
Bowen JM, Clark E, Bigler ED, et al. Childhood traumatic brain injury: neuropsychological status at the time of hospital discharge. Dev Med Child Neurol. 1997;39(1):17-25. [pmid: 9003725].
Boyer MG, Edwards P. Outcome 1 to 3 years after severe traumatic brain injury in children and adolescents. Injury. 1991;22(4):315-20. [pmid: 1937730].
Braciszeski T. Family systems issues associated with closed head injuries. Annual Children's Center Spring Conference;1987; Detroit, MI; 1987. p. 1-7.
Brett AW, Laatsch L. Cognitive rehabilitation therapy of brain-injured students in a public high school setting. Pediatr Rehabil. 1998;2(1):27-31. [pmid: 9661709].
Brink J, Garrett AL, Hale WR, et al. Recovery of motor and intellectual function in children sustaining severe head injuries. Dev Med Child Neurol. 1970;12. [pmid: 5477940].
Brink JD, Hoffer MM. Rehabilitation of brain injured children. Orthop Clin North Am. 1978;9(2):451-4. [pmid: 662311].
Brink JD, Imbus C, Woo-Sam J. Physical recovery after severe closed head trauma in children and adolescents. J Pediatr. 1980;97(5):721-7. [pmid: 7431163].
Brodsky P. Follow-up on the youngest REHABIT client: importance of caution. Percep Mot Skills. 1988;66(2):383-6. [pmid: 3399313].
Broman SH, Michel ME, editors. Traumatic head injury in children. New York: Oxford University Press; 1994.
Brookes M, MacMillan R, Cully S, et al. Head injuries in accident and emergency departments: how different are children from adults?. J Epidemiol Community Health. 1990;44(2):147-51. [pmid: 2370504].
Brooks N, Campsie L, Symington C, et al. The five year outcome of severe blunt head injury: a relative's view. J Neurol Neurosurg Psychiatr. 1986;49(7):764-70. [pmid: 3746307].
Brown G, Chadwick O, Shaffer D, et al. A prospective study of children with head injuries. III. Psychiatric sequelae. Psychol Med. 1981;11(1):63-78. [pmid: 7208747].
Bruce DA, Schut L, Sutton LN. Brain and cervical spine injuries occurring during organized sports activities in children and adolescents. Clin Sports Med. 1982;1(3):495-514. [pmid: 6764894].
Bryan MR. The pre-school child sustains a traumatic brain injury: developmental and learning issues. Neurorehabil. 1995;5(4):323-30.
Bryk A, Raudenbush S. Application of hierarchical linear models to assessing change. Psychol Bull. 1987;101:147-58.
Bryk A, Raudenbush S. Hierarchical linear models: applications and data analysis methods. Newbury Park, CA: Sage Publications; 1992.
Burchinal M, Appelbaum M. Estimating individual developmental functions: methods and their assumptions. Child Dev. 1991;62:23-43.
Burke E. From one family member to another. Cognit Rehabil. 1984;2(6):16-9.
Burke WH, Wesolowski MD, Guth ML. Comprehensive head injury rehabilitation: an outcome evaluation. Brain Inj. 1988;2(4):313-22. [pmid: 3203177].
Burke WH, Wesolowski MD, Buyer DM, et al. The rehabilitation of adolescents with traumatic brain injury: outcome and follow-up. Brain Inj. 1990;4(4):371-8. [pmid: 2252969].
Burkett KW. Trends in pediatric rehabilitation. Nurs Clin North Am. 1989;24(1):239-55. [pmid: 2522192].
Butinar D, Gostisa A. Brainstem auditory evoked potentials and somatosensory evoked potentials in prediction of posttraumatic coma in children. Pflugers Arch Eur J Physiol. 1996;431:R289-90. [pmid: 8739378].
Campbell D, Stanley J. Experimental and quasi-experimental designs for research. Chicago: Rand McNally; 1966.
Campbell TF, Dollaghan CA. Expressive language recovery in severely brain-injured children and adolescents. J Speech Hear Disorders. 1990;55(3):567-81. [pmid: 2381198].
Campbell TF, Dollghan CA. Speaking rate, articulatory speed, and linguistic processing in children and adolescents with TBI. J Speech Hear Disorders. 1995;38(4):864-875. [pmid: 7474979].
Capruso DX, Levin HS. Cognitive impairment following closed head injury. Neurol Clin. 1992;10(4):879-93. [pmid: 1435662].
Carney J, Gerring J. Return to school following severe closed head injury: a critical phase in pediatric rehabilitation. Pediatrician. 1990;17(4):222-9. [pmid: 2259674].
Carney J, Schoenbrodt L. Educational implications of traumatic brain injury. Pediatr Ann. 1994;23(1):47-52. [pmid: 8152864].
Carter S. Traumatic brain injury: the role of schools in assessment. Eugene, OR: Western Regional Resource Center; 1993.
Casey R, Ludwig S, McCormick MC. Morbidity following minor head trauma in children. Pediatrics. 1986;78(3):497-502. [pmid: 3748687].
Cattelani R, Lombardi F, Brianti R, et al. Traumatic brain injury in childhood: intellectual, behavioural and social outcome into adulthood. Brain Inj. 1998;12(4):283-96. [pmid: 9562911].
Centers for Disease Control and Prevention. Traumatic brain injury in the United States. Unpublished data from the National Center for Injury Prevention and Control, May 1998.
Chadwick O, Rutter M, Brown G, et al. A prospective study of children with head injuries. II. Cognitive sequelae. Psychol Med. 1981;11(1):49-61. [pmid: 7208746].
Chadwick O, Rutter M, Shaffer D, et al. A prospective study of children with head injuries. IV. Specific cognitive deficits. J Clin Neuropsychol. 1981;3(2):101-20. [pmid: 7276199].
Chadwick O, Rutter M, Thompson J, et al. Intellectual performance and reading skills after localized head injury in childhood. J Child Psychol Psychiatr. 1981;22:117-39. [pmid: 7276109].
Chapman SB, Culhane KA, Levin HS, et al. Narrative discourse after closed head injury in children and adolescents. Brain Lang. 1992;43(1):42-65. [pmid: 1643511].
Chapman SB, Levin HS, Wanek A, et al. Discourse after closed head injury in young children. Brain Lang. 1998;61(3):420-49. [pmid: 9570872].
Cioni G, Prechtl HFR, Ferrari F, et al. Which better predicts later outcome in fullterm infants: quality of general movements or neurological examination?. Early Hum Dev. 1997;50:71-85. [pmid: 9467695].
Citta-Peitrolungo D, Alexander M, Cook S, et al. Complications of tracheostomy and decannulation in pediatric and young patients with traumatic brain injury. Arch Phys Meds Rehabil. 1993;74:905-9. [pmid: 8379834].
Clark E. Children and adolescents with traumatic brain injury: reintegration challenges in educational settings. J Learn Disabil. 1996;29(5):549-60. [pmid: 8870524].
Cockrell J. Pediatric brain injury rehabilitation. In: Horn LJ, Zasler ND, editors, Medical rehabilitation of traumatic brain injury. Philadelphia: Hanley & Belfus; 1996: 171-96.
Cockrell JL, Gregory SA. Audiological deficits in brain-injured children and adolescents. Brain Inj. 1992;6(3):261-6. [pmid: 1581748].
Connell J, Skinner E. Predicting trajectories of academic engagement: a growth curve analysis of children's motivation in school. Paper presented at: Meeting of the American Educational Research Association;1990; Boston.
Connor DF, Steingard RJ. A clinical approach to the pharmacotherapy of aggression in children and adolescents. Ann NY Acad Sci. 1996;794:290-307. [pmid: 8853610].
Conoley JC, Sheridan SM. Pediatric traumatic brain injury: challenges and interventions for families. J Learn Disabil. 1996;29(6):662-9. [pmid: 8942310].
Cooley, E, Singer G. On serving students with head injuries: are we reinventing the wheel that doesn't role. J Head Trauma Rehabil. 1991;6(1):47-55.
Costeff H, Abraham E, Brenner T, et al. Late neuropsychologic status after childhood head trauma. Brain Develop. 1988;10(6):371-4. [pmid: 3218710].
Costeff H, Groswasser Z, Landman Y, et al. Survivors of severe traumatic brain injury in childhood. II. Late residual disability. Scand J Rehabil Med Suppl. 1985;12:10-5. [pmid: 3868033].
Coster WJ, Haley S, Baryza MJ. Functional performance of young children after traumatic brain injury: a six month follow-up study. Am J Occup Ther. 1994;48:211-8. [pmid: 8178914].
Crowley JA, Miles MA. Cognitive remediation in pediatric head injury: a case study. J Pediatr Psychol. 1991;16(5):611-27. [pmid: 1744809].
Cunning JE. Emotional aspects of head trauma in children. Rehabil Lit. 1976;37(11-12):335-9. [pmid: 996357].
D'Amato RC, Rothlisberg BA. How education should respond to students with traumatic brain injury. J Learn Disabil. 1996;29(6):670-83. [pmid: 8942311].
Dalby PR, Obrzut JE. Epidemiologic characteristics and sequelae of closed head-injured children and adolescents: a review. Dev Neuropsychol. 1991;7:35-68.
Dall'Oglio AM, Bates E, Volterra V, et al. Early cognition, communication and language in children with focal brain injury. Dev Med Child Neurol. 1994;36:1076-98. [pmid: 7958522].
Dam Hieu P, Sizun J, Person H, et al. The place of decompressive surgery in the treatment of uncontrollable post-traumatic intracranial hypertension in children. Child Nerv Syst. 1996;12(5):270-5. [pmid: 8737804].
Davidson DA. Occupational therapy intervention with an adolescent with brain injury and behavioral disorders. Am J Occup Ther. 1990;44(2):168-71. [pmid: 2309881].
Day PS, Ulatowska HK. Perceptual, cognitive and linguistic development after early hemispherectomy: two case studies. Brain Lang. 1979;7:17-33. [pmid: 435973].
Deaton AV, Poole C, Long D. Improving the work potential of brain-injured adolescents and young adults: a model for evaluation and individualized training. Occup Ther Health Care. 1987;4(2):147-59.
Deaton AV, Metzger S, Wheeler AM. Agitation in pediatric brain injury: a useful communication or a hurdle to overcome?. Neurorehabil. 1995;5(4):317-21.
Deaton AV, Waaland P. In: Savage R, editor, Educational dimensions of acquired brain injury. Austin, TX: Pro-Ed. Inc; 1994.
Dennis M. Intelligence after early brain injury: predicting IQ scores from medical variables. J Clin Exp Neuropsychol. 1985;7:526-54. [pmid: 4066908].
Dennis M. Word finding in children and adolescents with a history of brain injury. Top Lang Disorders. 1992;13(1):66-82.
Dennis M, Barnes MA. Knowing the meaning, getting the point, bridging the gap, and carrying the message: aspects of discourse following closed head injury in childhood and adolescence. Brain Lang. 1990;39:428-46. [pmid: 2285861].
Dennis M, Barnes MA, Donnelly RE, et al. Appraising and managing knowledge: meta-cognitive skills after childhood head injury. Dev Neuropsychol. 1996;12:77-103.
Dennis M, Barnes MA, Wilkinson M, et al. How children with head injury represent real and deceptive emotion in short narratives. Brain Lang. 1998;61(3):450-83. [pmid: 9570873].
Dennis M, Lovett M, Wiegel-Crump CA. Written language acquisition after left or right hemidecortication in infancy. Brain Lang. 1981;12:54-91. [pmid: 7225791].
Dennis M, Whitaker HA. Language acquisition following hemidecortication: linguistic superiority of the left over the right-hemisphere. Brain Lang. 1976;3:404-33. [pmid: 949594].
Dennis M, Wilkinson M, Koski L, et al. Attention deficits in the long term after childhood head injury. In: Broman S. Michel M, editors, Traumatic brain injury in children. New York: Oxford University Press; 1994.
DePompei R. School of Speech-Language Pathology and Audiology, University of Akron, Akron, OH. Personal communication, December 1998.
DePompei R, Blosser J. Families of children with traumatic brain injury as advocates in school reentry. Neurorehabil. 1991;1(2):29-37.
DePompei R, Blosser JL. Staff development and clinical intervention in brain injury rehabilitation. In: Durgin CJ, editor, Aspen, CO: Aspen Publishing; 1993. p. 229-56.
DePompei R, Blosser JL. Preface. J Head Trauma Rehabil. 1997;12(2).
DePompei R, Williams J. Working with families after TBI: a family-centered approach. Top Lang Disorders. 1994;15(1):68-81.
DeVos KJ, Wyllie E, Geckler C, et al. Language dominance in patients with early childhood tumors near left-hemisphere language areas. Neurology. 1995;45:349-56. [pmid: 7854538].
DiScala C, Grant CC, Brooke MM, et al. Functional outcome in children with traumatic brain injury. Am J Phys Med Rehabil. 1992;71(3):145-8. [pmid: 1385712].
DiScala C, Osberg JS, Savage RC. Children hospitalized for traumatic brain injury: transition to postacute care. J Head Trauma Rehabil. 1997;12(2):1-10.
Doelling J, Bryde S, Parette HPJ. What are multidisciplinary and ecobehavioral approaches?And how can they make a difference for students with traumatic brain injuries?. Teach Except Child. 1997;30(1):56-60.
Donders J. Academic placement after traumatic brain injury. Annual Meeting of the International Neuropsychological Society; Office of Educational Research and Improvement, U.S. Department of Education; 1992.
Donders J. Premorbid behavioral and psychosocial adjustment of children with traumatic brain injury. J Abnorm Child Psychol. 1992;20(3):233-46. [pmid: 1619132].
Donders J. Validity of the Kaufman Assessment Battery for Children when employed with children with traumatic brain injury. J Clin Psychol. 1992;48(2):225-30. [pmid: 1573024].
Donders J. Validity of two short forms of the WISC-R in children with traumatic brain injury. J Clin Psychol. 1992;48(3):364-70. [pmid: 1602027].
Donders J. Bereavement and mourning in pediatric rehabilitation settings. Death Stud. 1993;17(6):517-27. [pmid: 10130378].
Donders J. Memory functioning after traumatic brain injury in children. Brain Inj. 1993;7(5):431-7. [pmid: 8401485].
Donders J. Academic placement after traumatic brain injury. J Sch Psychol. 1994;32(1):53-65.
Donders J, Ballard E. Psychological adjustment characteristics of children before and after moderate to severe traumatic brain injury. J Head Trauma Rehabil. 1996;11(3):67-73.
Donders J, Strom D. The effect of traumatic brain injury on children with learning disability. Pediatr Rehabil. 1997;1(3):179-84. [pmid: 9689253].
dos Santos AL, Plese JP, Ciquini Jr O, et al. Extradural hematomas in children. Pediatr Neurosurg. 1994;21(1):50-4. [pmid: 7947310].
Duhaime AC, Eppley M, Margulies S, et al. Crush injuries to the head in children. Neurosurgery. 1995;37(3):401-7. [pmid: 7501102].
Education for All Handicapped Children Act of 1975. Public Law No 94-142, 89 Stat 773.
Edwards PA. Rehabilitation outcomes in children with brain injury. Rehabil Nurs. 1987;12(3):125-7. [pmid: 3647554].
Eiben CF, Anderson TP, Lockman L, et al. Functional outcome of closed head injury in children and young adults. Arch Phys Med Rehabil. 1984;65(4):168-70. [pmid: 6712433].
Eisele J, Aram D. Differential effects of early hemisphere damage on lexical comprehension and production. Aphasiology. 1993;7(5):513-23.
Eisele JA, Aram DM. Comprehension and imitation of syntax following early hemisphere damage. Brain Lang. 1994;46:212-31. [pmid: 8137143].
Eisele JA, Lust B, Aram D. Presupposition and implication of truth: linguistic deficits following early brain lesions. Brain Lang. 1998;61:376-94. [pmid: 9570870].
Emanuelson I, Von Wendt L. Medical management in south-west Sweden of children and adolescents with serious traumatic brain injury. Injury. 1998;29(3):193-8. [pmid: 9709420].
Emanuelson I, Von Wendt L, Beckung E, et al. Late outcome after severe traumatic brain injury in children and adolescents. Pediatr Rehabil. 1998;2(2):65-70. [pmid: 9744024].
Emanuelson IM, Von Wendt L, Bjure J, et al. Computed tomography and single-photon emission computed tomography as diagnostic tools in acquired brain injury among children and adolescents. Dev Med Child Neurol. 1997;39(8):502-7. [pmid: 9295844].
Emanuelson I, Von Wendt L, Lundalv E, et al. Rehabilitation and follow-up of children with severe traumatic brain injury. Child Nerv Syst. 1996;12(8):460-5. [pmid: 8891364].
Engberg A, Teasdale TW. Traumatic brain injury in children in Denmark: a national 15-year study. Eur J Epidemiol. 1998;14(2):165-73. [pmid: 9556176].
Eriksson P, Perfilieva E, Bjork-Eriksson T, et al. Neurogenesis in the adult human hippocampus. Nat Med. 1998;11(4):1313-7. [pmid: 9809557].
Ersahin Y, Mutluer S, Mirzai H, et al. Pediatric depressed skull fractures: analysis of 530 cases. Child Nerv Syst. 1996;12(6):323-31. [pmid: 8816297].
Eslinger PJ, Grattan LM, Damasio H, et al. Developmental consequences of childhood frontal lobe damage. Arch Neurol. 1992;49:764-9. [pmid: 1497505].
Ewing-Cobbs L. Neurobehavioral sequelae following head injury in children: educational implications. J Head Trauma Rehabil. 1986;1:57-65.
Ewing-Cobbs L, Brookshire B, Scott MA, et al. Children's narratives following traumatic brain injury: linguistic structure, cohesion, and thematic recall. Brain Lang. 1998;61(3):395-419. [pmid: 9570871].
Ewing-Cobbs L, Fletcher JM, Levin HS. Intellectual, motor and language sequelae following closed head injury in infants and preschoolers. J Pediatr Psychol. 1989;14:531-47. [pmid: 2607392].
Ewing-Cobbs L, Fletcher JM, Levin HS, et al. Longitudinal neuropsychological outcome in infants and preschoolers with traumatic brain injury. J Int Neuropsychol Soc. 1997;3(6):581-91. [pmid: 9448371].
Ewing-Cobbs L, Kramer L, Prasad M, et al. Neuroimaging, physical, and developmental findings after inflicted and noninflicted traumatic brain injury in young children. Pediatrics. 1998;102:300-7. [pmid: 9685430].
Ewing-Cobbs L, Levin HS, Eisenberg HM, et al. Language functions following closed head injury in children and adolescents. J Clin Exp Neuropsychol. 1987;9:575-92. [pmid: 2444619].
Ewing-Cobbs L, Levin HS, Fletcher JM, et al. The Children's Orientation and Amnesia Test: relationship to severity of acute head injury and to recovery of memory. Neurosurgery. 1990;27(5):683-91. [pmid: 2259396].
Ewing-Cobbs L, Thompson NM, Miner ME, et al. Gunshot wounds to the brain in children and adolescents: age and neurobehavioral development. Neurosurgery. 1994;35:225-33. [pmid: 7969829].
Farley JA. The comatose child: analysis of factors affecting intracranial pressure. Dimens Crit Care Nurs. 1990;9(4):216-22. [pmid: 2364860].
Farmer JE, Clippard DS, Luehr-Wiemann Y, et al. Assessing children with traumatic brain injury during rehabilitation: promoting school and community reentry. J Learn Disabil. 1996;29(5):532-48. [pmid: 8870523].
Farmer J, Peterson L. Pediatric traumatic brain injury: promoting successful school reentry. Sch Psychol Rev. 1995;24:230-43.
Farmer M, Singer H, Mellits E, et al. Neurobehavioral sequelae of minor head injuries in children. Pediatr Neurosci. 1987;13:304-8. [pmid: 3503992].
Fay GC, Jaffe KM, Polissar NL, et al. Mild pediatric traumatic brain injury: a cohort study. Arch Phys Med Rehabil. 1993;74(9):895-901. [pmid: 8379832].
Fay GC, Jaffe KM, Polissar NL, et al. Outcome of pediatric traumatic brain injury at three years: a cohort study. Arch Phys Med Rehabil. 1994;75(7):733-41. [pmid: 8024416].
Feeney TJ, Ylvisaker M. Choice and routine: antecedent behavioral interventions for adolescents with severe traumatic brain injury. J Head Trauma Rehabil. 1995;10(3):67-86.
Feeney TJ, Ylvisaker M. Students with acquired brain injury: the school's response. In: Glang A, editor, Students with acquired brain injury: the school's response. Paul H. Brookes, Publishing; 1997.
Feldman HM, Holland AL, Brown RE. A fluent language disorder following antepartum left-hemisphere brain injury. J Commun Disord. 1992;25(2-3):125-42. [pmid: 1487564].
Feldman HM, Holland AL, Kemp SS, et al. Language development after unilateral brain injury. Brain Lang. 1992;42:89-102. [pmid: 1547471].
Feldman HM, Janosky JE, Scher MS, et al. Language abilities following prematurity, periventricular brain injury, and cerebral palsy. J Commun Disord. 1994;27(2):71-90. [pmid: 7929881].
Feldman KW, Brewer DK, Shaw DW. Evolution of the cranial computed tomography scan in child abuse. Child Abuse Negl. 1995;19(3):307-14. [pmid: 9278730].
Fields AI, Coble DH, Pollack MM, et al. Outcomes of children in a persistent vegetative state. Crit Care Med. 1993;21(12):1890-4. [pmid: 8252894].
Filley CM, Cranberg LD, Alexander MP, et al. Neurobehavioral outcome after closed head injury in childhood and adolescence. Arch Neurol. 1987;44:194-8. [pmid: 3813936].
Fisher MD. Pediatric traumatic brain injury. Crit Care Nurs Q. 1997;20(1):36-51. [pmid: 9165776].
Fletcher J. Behavioral changes after closed head injury in children. J Consult Clin Psychol. 1990;58:93-8. [pmid: 2319050].
Fletcher J, Ewing-Cobbs L, Francis D, et al. Variability in outcomes after traumatic brain injury in children: a developmental perspective. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Fletcher J, Levin H. Neurobehavioral effects of brain injury in children. In: Handbook of Pediatric Psychology. New York: Guilford Press; 1988.
Fletcher JM, Levin HS, Lachar D, et al. Behavioral outcomes after pediatric closed head injury: relationships with age, severity, and lesion size. J Child Neurol. 1996;11(4):283-90. [pmid: 8807417].
Fletcher-Janzen E, Kade HD. Rehabilitation in a neurodevelopmental milieu. In: Reynolds CR, editor, Handbook of clinical child neuropsychology. Critical issues in neuropsychology. New York: Plenum Press; 1997. p. 452-81.
Fowler WE, Kriel RL, Krach LE. Movement disorders after status epilepticus and other brain injuries. Pediatr Neurol. 1992;8(4):281-4. [pmid: 1388417].
Frances A, Jensen PS. Separating psychological factors from brain trauma in treating a hyperactive child. Hosp Community Psychiatr. 1985;36(7):711-3. [pmid: 4018745].
Francis D, Fletcher J, Stuebing K, et al. Analysis of change: modeling individual growth. J Consult Clin Psychol. 1991;59:27-37. [pmid: 2002140].
Franzen KM, Roberts MA, Schmits D, et al. Cognitive remediation in pediatric traumatic brain injury. Child Neuropsychol. 1996;2(3):176-84.
Freeman EA, Burrell BJ, Sedger RA. Severe brain injury: intensive family involvement in community-based rehabilitation. Med J Aust. 1990;153(11-12):730-2. [pmid: 2247002].
Frewen TC, Sumabat WO, Del Maestro RF. Cerebral blood flow, metabolic rate, and cross-brain oxygen consumption in brain injury. J Pediatr. 1985;107(4):510-3. [pmid: 4045600].
Fuld PA, Fisher P. Recovery of intellectual ability after closed head-injury. Dev Med Child Neurol. 1977;19:495-502. [pmid: 892246].
Gaidolfi E, Vignolo LA. Closed head injuries of school-age children: neuropsychological sequelae in early adulthood. Ital J Neurol Sci. 1980;1(2):65-73. [pmid: 7338453].
Gambardella G, Zaccone C, Cardia E, et al. Intracranial pressure monitoring in children: comparison of external ventricular device with the fiberoptic system. Child Nerv Syst. 1993;9(8):470-3. [pmid: 8124675].
Genuardi FJ, King WD. Inappropriate discharge instructions for youth athletes hospitalized for concussion. Pediatrics. 1995;95(2):216-8. [pmcid: 161813]. [pmid: 7838638].
Gerberich SG, Finke R, Madden M, et al. An epidemiological study of high school ice hockey injuries. Child Nerv Syst. 1987;3(2):59-64. [pmid: 3621231].
Gill M, Cohen M, Korn C, et al. Vocational outcome of aphasic patients following severe traumatic brain injury. Brain Inj. 1996;10(1):39-45. [pmid: 8680391].
Glang, A. Teaching Research. Eugene, OR. Personal Communication, 1999.
Glang A, Singer G, Cooley E, et al. Tailoring direct instruction techniques for use with elementary students with brain injury. J Head Trauma Rehabil. 1992;7(4):93-108.
Glang A, Todis B, Cooley E, et al. Building social networks for children and adolescents with traumatic brain injury: a school-based intervention. J Head Trauma Rehabil. 1997;12(2):32-47.
Glass P, Bulas DI, Wagner AE, et al. Pattern of neuropsychological deficit at age five years following neonatal unilateral brain injury. Brain Lang. 1998;63(3):346-56. [pmid: 9672764].
Godbout A. Structured habituation training for movement provoked vertigo after severe traumatic brain injury: a single-case experiment. Brain Inj. 1997;11(9):629-41. [pmid: 9376831].
Gold S. No miracles. Acad Ther. 1985;21(2):177-82.
Goldberg AL, Sachs PR. A guide to evaluating residential post-acute programs for children and adolescents with brain injury. J Cognit Rehabil. 1992;10(2):28-32.
Goldstein B, DeKing D, DeLong DJ, et al. Autonomic cardiovascular state after severe brain injury and brain death in children [published erratum appears in Crit Care Med 1994 Nov;22(11):1889]. Crit Care Med. 1993;21(2):228-33. [pmid: 8428474].
Goldstein F. Intellectual and academic outcome following closed head injury in children and adolescents: research strategies and empirical findings. Dev Neuropsychol. 1985;1:195-214.
Goshen E, Zwas ST, Shahar E, et al. The role of 99Tcm-HMPAO brain SPET in paediatric traumatic brain injury. Nucl Med Commun. 1996;17(5):418-22. [pmid: 8736519].
Gordon, W. Mount Sinai Medical Center, New York, NY. Personal communication, January 1999.
Gotschall CS, Papero PH, Snyder HM, et al. Comparison of three measures of injury severity in children with traumatic brain injury. J Neurotrauma. 1995;12(4):611-9. [pmid: 8683612].
Greenhalgh A. Miracles do happen. Aust Nurs J. 1978;8(1):28-9. [pmid: 102317].
Greenspan AI. Functional recovery following head injury among children. Curr Probl Pediatr. 1996;26:170-7. [pmid: 8858198].
Greenspan AI, MacKenzie EJ. Functional outcome after pediatric head injury. Pediatrics. 1994;94:425-32. [pmid: 7936848].
Greenwald BM, Ghajar J, Notterman DA. Critical care of children with acute brain injury. Adv Pediatr. 1995;42:47-89. [pmid: 8540436].
Gronwall D, Wrightson P, McGinn V. Effect of mild head injury during the pre-school years. J Int Neuropsychol Soc. 1997;3(6):592-7. [pmid: 9448372].
Groswasser Z, Costeff H, Tamir A. Survivors of severe traumatic brain injury in childhood: incidence, background and hospital course. Scand J Rehabil Med Suppl. 1985;12:6-9. [pmid: 3868051].
Guerriere D, McKeever P. Mothering children who survive brain injuries: playing the hand you're dealt. J Soc Pediatr Nurs. 1997;2(3):105-15. [pmid: 9292853].
Gulbrandsen GB. Neuropsychological sequelae of light head injuries in older children 6 months after trauma. J Clin Neuropsychol. 1984;6(3):257-68. [pmid: 6470164].
Gutentag SS, Naglieri JA, Yeates KO. Performance of children with traumatic brain injury on the cognitive assessment system. Assessment. 1998;5(3):263-72. [pmid: 9728033].
Haley SM, Cioffi MI, Lewin JE, et al. Motor dysfunction in children and adolescents after traumatic brain injury. J Head Trauma Rehabil. 1990;5(4):77-90.
Hall DM, Johnson SL, Middleton J. Rehabilitation of head injured children. Arch Dis Child. 1990;65(5):553-6. [pmid: 2192690].
Hall JR, Reyes HM, Meller JL, et al. The outcome for children with blunt trauma is best at a pediatric trauma center. Pediatr Surg. 1996;31:72-7. [pmid: 8632290].
Hall JW. Auditory evoked responses in the management of acutely brain-injured children and adults. Am J Otol. 1988;9:36-46. [pmid: 3202138].
Hallett TL. Linguistic competence in paediatric closed head injury. Pediatr Rehabil. 1997;1(4):219-28. [pmid: 9689258].
Hammill D, Irwin OC. IQ differences of right and left spastic hemiplegic children. Percept Mot Skills. 1966;22:193-4. [pmid: 5906716].
Hanigan WC, Wright SM, Wright RM. Clinical utility of magnetic resonance imaging in pediatric neurosurgical patients. J Pediatr. 1986;108(4):522-9. [pmid: 3958824].
Harris JR. Verbal rehearsal and memory in children with closed head injury: a quantitative and qualitative analysis. J Commun Disord. 1996;29(2):79-93. [pmid: 9157177].
Hart BL, Dudley MH, Zumwalt RE. Postmortem cranial MRI and autopsy correlation in suspected child abuse. Am J Forensic Med Pathol. 1996;17(3):217-24. [pmid: 8870872].
Hart K, Faust D. Prediction of the effects of mild head injury: a message about the Kennard Principle. J Clin Psychol. 1988;44(5):780-2. [pmid: 3192717].
Hayward R. Management of children with head injuries in district general hospitals. Arch Dis Child. 1987;62(12):1283-6. [pmid: 3435168].
Hegel MT. Application of a token economy with a non-compliant closed head-injured male. Brain Inj. 1988;2(4):333-8. [pmid: 3203179].
Heindl UT, Laub MC. Outcome of persistent vegetative state following hypoxic or traumatic brain injury in children and adolescents. Neuropediatrics. 1996;27(2):94-100. [pmid: 8737825].
Heiskanen O, Kaste M. Late prognosis of severe brain injury in children. Dev Med Child Neurol. 1974;16:11-4. [pmid: 4205076].
Helfaer MA, Wilson MD. Head injury in children. Curr Opin Pediatr. 1993;5(3):303-9. [pmid: 8374649].
Helgadottir HL. Psychosocial issues following serious head injury: a case study of an adolescent girl. Rehabil Nurs. 1996;21(5):258-61. [pmid: 8868757].
Hemphill L, Feldman HM, Camp L, et al. Developmental changes in narrative and non-narrative discourse in children with and without brain injury. J Commun Disord. 1994;27(2):107-33. [pmid: 7929876].
Hendrickson SLG, Becker H. A bruise on the brain: conveying the meaning of head injury to children. Rehabil Nurs Res. 1996;5(2):35-42.
Hennes H, Lee M, Smith D, et al. Clinical predictors of severe head trauma in children. Am J Dis Child. 1988;142(10):1045-47. [pmid: 3177299].
Henry K. Cognitive rehabilitation and the head-injured child. Journal of Children in a Contemporary Society. 1983;16(1-2):189-205.
Hicks RA, Gaughan DC. Understanding fatal child abuse. Child Abuse Negl. 1995;19(7):855-63. [pmid: 7583743].
Hinnant CA. Thromboembolic infarcts occurring after mild traumatic brain injury in a paediatric patient with Noonan's syndrome. Brain Inj. 1994;8(8):719-27. [pmid: 7849691].
Hirsch B, DuBois D. The identification and prediction of contrasting longitudinal trajectories. J Youth Adolesc. 1991;20:53-72.
Hofer T. Glasgow scale relationships in pediatric and adult patients. J Neurosci Nurs. 1993;25(4):218-27. [pmid: 8228393].
Hornyak JE, Nelson VS, Hurvitz EA. The use of methylphenidate in pediatric traumatic brain injury. Paediatr Rehabil. 1997;1(1):15-7. [pmid: 9689233].
Horton AM Jr. Behavior modification with brain-injured children: a brief note on directions for research. Percep Mot Skills. 1996;82(2):425-6. [pmid: 8724911].
Hu X, Wesson D, Kenney B, et al. Risk factors for extended disruption of family function after severe injury to a child. Can Med Assoc J. 1993;149:421-7. [pmid: 8348424]. [pmcid: 1485644].
Hudspeth WJ, Pribram KH. Stages of brain and cognitive maturation. J Educ Psychol. 1990;82:881-4.
Humphreys RP, Hendrick EB, Hoffman HJ. The head-injured child who "talks and dies": a report of 4 cases. Child Nerv Syst. 1990;6(3):139-42. [pmid: 2357710].
Hurvitz EA, Mandac BR, Davidoff G, et al. Risk factors for heterotopic ossification in children and adolescents with severe traumatic brain injury. Arch Phys Med Rehabil. 1992;73(5):459-62. [pmid: 1580774].
Individuals with Disabilities Education Act (IDEA) of 1990. Public Law 101-476, 20 U.S.C. § 1400.
Jaffe KM, Fay GC, Polissar NL, et al. Severity of pediatric traumatic brain injury and early neurobehavioral outcome: a cohort study. Arch Phys Med Rehabil. 1992;73(6):540-7. [pmid: 1622302].
Jaffe KM, Fay GC, Polissar NL, et al. Severity of pediatric traumatic brain injury and neurobehavioral recovery at one year: a cohort study. Arch Phys Med Rehabil. 1993;74(6):587-95. [pmid: 8503748].
Jaffe KM, Hays RM. Pediatric head injury: rehabilitative medical management. J Head Trauma. 1986;1:30-40.
Jaffe KM, Massagli TL, Martin KM, et al. Pediatric traumatic brain injury: acute and rehabilitation costs. Arch Phys Med Rehabil. 1993;74(7):681-6. [pmid: 8328886].
Jaffe KM, McDonald CM. Rehabilitation following childhood injury. Pediatr Ann. 1992;21(7):438-9, 443-7. [pmid: 1408415].
Jaffe KM, Okamoto GA, Lemire C. Inpatient pediatric rehabilitation: a five-year review. Rehabil Lit. 1986;47(11-12):286-9. [pmid: 3823598].
Jaffe KM, Polissar NL, Fay GC, et al. Recovery trends over three years following pediatric traumatic brain injury. Arch Phys Med Rehabil. 1995;76(1):17-26. [pmid: 7811169].
James HE, Madauss WC, Tibbs PA, et al. The effect of high dose dexamethasone in children with severe closed head injury: a preliminary report. Acta Neurochir. 1979;45(3-4):225-36. [pmid: 371348].
Johnson BP. One family's experience with head injury: a phenomenological study. J Neurosci Nurs. 1995;27(2):113-8. [pmid: 7622948].
Johnson DA. Head injured children and education: a need for greater delineation and understanding. Br J Educ Psychol. 1992;62(Pt 3):404-9. [pmid: 1467260].
Johnson DA, Roethig-Johnston K, Middleton J. Development and evaluation of an attentional test for head injured children: information processing capacity in a normal sample. J Child Psychol Psychiatr. 1988;29(2):199-208. [pmid: 3372616].
Johnson DL, Krishnamurthy S. Send severely head-injured children to a pediatric trauma center. Pediatr Neurosurg. 1996;25(6):309-14. [pmid: 9348151].
Johnston MV, Gerring JP. Head trauma and its sequelae. Pediatr Ann. 1992;21(6):362-8. [pmid: 1377814].
Johnstone A, Zuberi S, Scobie W. Skull fractures in children: a population study. J Accid Med. 1996;13:386-9. [pmid: 8947793].
Jordan F, Ashton R. Language performance of severely closed head injured children. Brain Inj. 1996;10(2):91-7. [pmid: 8696319].
Jordan FM, Cannon A, Murdoch BE. Language abilities of mildly closed head-injured children 10 years post injury. Brain Inj. 1992;6(1):39-44. [pmid: 1739851].
Jordan FM, Cremona-Meteyard S, King A. High level linguistic disturbances subsequent to childhood closed head injury. Brain Inj. 1996;10(10):729-38. [pmid: 8879663].
Jordan FM, Murdoch BE. Linguistic status following closed head injury in children: a followup study. Brain Inj. 1990;4:147-54. [pmid: 1691939].
Jordan FM, Murdoch BE. Severe closed head injury in childhood: linguistic outcomes into adulthood. Brain Inj. 1994;8(6):501-8. [pmid: 7527267].
Jordan FM, Murdoch BE, Buttsworth DL. Closed head injured children's performance on narrative tasks. J Speech Hear Res. 1991;34(3):572-82. [pmid: 2072682].
Jordan FM, Ozanne AE, Murdoch BE. Long-term speech and language disorders subsequent to closed head injury in children. Brain Inj. 1988;2:175-85. [pmid: 3139117].
Jordan FM, Ozanne AE, Murdoch BE. Performance of closed head-injured children on a naming task. Brain Inj. 1990;4(1):27-32. [pmid: 2297597].
Kaiser G, Pfenninger J. Effect of neurointensive care upon outcome following severe head injuries in childhood: a preliminary report. Neuropediatrics. 1984;15(2):68-75. [pmid: 6738819].
Karepov VG. Domicile period in the recovery system of young patients subject to traumatism. Sante Publique. 1984;27(3):249-51. [pmid: 6523336].
Kaufmann PM, Fletcher JM, Levin HS, et al. Attentional disturbance after pediatric closed head injury. J Child Neurol. 1993;8:348-53. [pmid: 8228030].
Keefe KA, Feldman HM, Holland AL. Lexical learning and language abilities in preschoolers with perinatal brain damage. J Speech Hear Disorders. 1989;54:395-402. [pmid: 2755102].
Kehle TJ, Clark E, Jenson WR. Interventions for students with traumatic brain injury: managing behavioral disturbances. J Learn Disabil. 1996;29(6):633-42. [pmid: 8942307].
Kennedy C, Freeman J. Post-traumatic seizures and post-traumatic epilepsy in children. J Head Trauma Rehabil. 1986;1:66-73.
Kersenbrock P, Kirchner KM, Sammons J. Transdisciplinary approach to a brain injured child. Rehabil Nurs. 1983;8(6):22-3. [pmid: 6558754].
Kinsella G, Prior M, Sawyer M, et al. Neuropsychological deficit and academic performance in children and adolescents following traumatic brain injury. J Pediatr Psychol. 1995;20(6):753-67. [pmid: 8558376].
Kinsella GJ, Prior M, Sawyer M, et al. Predictors and indicators of academic outcome in children 2 years following traumatic brain injury. J Int Neuropsychol Soc. 1997;3(6):608-16. [pmid: 9448374].
Kissoon N, Dreyer J, Walia M. Pediatric trauma: differences in pathophysiology, injury patterns and treatment compared with adult trauma. Can Med Assoc J. 1990;142(1):27-34. [pmid: 2403481].
Kleinpeter U. Social integration after brain trauma during childhood. Acta Paedopsychiatr. 1976;42(2):68-75. [pmid: 788458].
Klonoff H, Clark C, Klonoff PS. Long-term outcome of head injuries: a 23 year follow up study of children with head injuries. J Neurol Neurosurg Psychiatr. 1993;56(4):410-5. [pmid: 8482963].
Klonoff H, Clark C, Klonoff P. Outcome of head injuries from childhood. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Klonoff H, Low MD, Clark C. Head injuries in children: a prospective five-year followup. J Neurol Neurosurg Psychiatr. 1977;40:1211-9. [pmid: 591990].
Klonoff H, Paris R. Immediate, short-term and residual effects of acute head injuries in children. Clinical Neuropsychology: Current Status and Applications 1974:178-210.
Knights R, Ivan L, Ventureyra E, et al. The effects of head injury in children on neuropsychological and behavioral functioning. Brain Inj. 1991;5:339-51. [pmid: 1786497].
Koelfen W, Freund M, Dinter D, et al. Long-term follow up of children with head injuries classified as "good recovery" using the Glasgow Outcome Scale: neurological, neuropsychological and magnetic resonance imaging results. Eur J Pediatr. 1997;156(3):230-5. [pmid: 9083767].
Kolb B. Brain development, plasticity, and behavior. Am Psychol. 1989;44(9):1203-12. [pmid: 2782728].
Krach LE, Kriel RL, Morris WF, et al. Central autonomic dysfunction following acquired brain injury in children. J Neurol Rehabil. 1997;11(1):41-5.
Krashen S. Lateralization, language learning, and the critical period: some new evidence. Lang Learn. 1973;23(1):63-74.
Kraus JF, Fife D, Conroy C. Pediatric brain injuries: the nature, clinical course, and early outcomes in a defined United States' population. Pediatrics. 1987;79(4):501-7. [pmid: 3822667]. [pmcid: 126266].
Kraus JF, Fife D, Cox P, et al. Incidence, severity, and external causes of pediatric brain injury. Am J Dis Child. 1986;140(7):687-93. [pmid: 3717107].
Kraus JF, Rock A, Hemyari P. Brain injuries among infants, children, adolescents, and young adults. Am J Dis Child. 1990;144(6):684-91. [pmid: 2346150].
Krell MJ. For the love of Josie. Rehabil Nurs. 1997;22(2):98-9. [pmid: 9110853].
Kriel RL, Krach LE, Panser LA. Closed head injury: comparison of children younger and older than 6 years of age. Pediatr Neurol. 1989;5(5):296-300. [pmid: 2803387].
Kumar R, West C, Quirke C, et al. Do children with severe head injury benefit from intensive care?. Child Nerv Syst. 1991;7:299-304. [pmid: 1764703].
Kurtz LA, Scull SA. Rehabilitation for developmental disabilities. Pediatr Clin North Am. 1993;40(3):629-43. [pmid: 7684125].
Kuyper M, van Tol-de Jager M, Post MWM, et al. Functional health status of rehabilitated adolescents with traumatic brain injury measured by the SIP68. J Rehabil Sci. 1996;9(4):117-21.
Lange-Cosack H, Riebel U, Grumme T, et al. Possibilities and limitations of rehabilitation after traumatic apallic syndrome in children and adolescents. Neuropediatrics. 1981;12(4):337-65. [pmid: 7335158].
Lash M, Scarpino C. School reintegration for children with traumatic brain injuries: conflicts between medical and educational systems. Neurorehabil. 1995;3(3):13-25.
Lawson MJ, Rice DN. Effects of training in use of executive strategies on a verbal memory problem resulting from closed head injury. J Clin Exp Neuropschol. 1989;11(6):842-54. [pmid: 2592526].
Leathem JM, Body CM. Neuropsychological sequelae of head injury in a New Zealand adolescent sample. Brain Inj. 1997;11(8):565-75. [pmid: 9251865].
Lehr E. A Developmental perspective. In: Lehr E, editor, Psychological management of traumatic brain injuries in children and adolescents. Rockville, MD: Aspen Publishers; 1990. p. 41-98.
Lehr E. Psychological management of traumatic brain injuries in children and adolescents. Rockville, MD: Aspen Publishers; 1990. p. 248.
Lehr E. Counseling students with acquired brain injury. In: Glang A, editor, Students with acquired brain injury: the school's response. Baltimore: Paul H. Brookes Publishing; 1997.
Leichtman M. Psychotherapeutic interventions with brain-injured children and their families. I. Diagnosis and treatment planning. Bull Menninger Clin. 1992;56(3):321-37. [pmid: 1504677].
Levin HS. Neurobehavioral recovery. J Neurotrauma. 1992;9:S359-73. [pmid: 1588627].
Levin HS. Head trauma. Curr Opin Neurol. 1993;6(6):841-6. [pmid: 8293157].
Levin HS, Culhane KA, Fletcher JM, et al. Dissociation between delayed alternation and memory after pediatric head injury: relationship to MRI findings. J Child Neurol. 1994;9(1):81-9. [pmid: 8151091].
Levin HS, Culhane KA, Mendelsohn D, et al. Cognition in relation to magnetic resonance imaging in head-injured children and adolescents. Arch Neurol. 1993;50(9):897-905. [pmid: 8363443].
Levin HS, Eisenberg HM. Neuropsychological impairment after closed head injury in children and adolescents. J Pediatr Psychol. 1979;4:389-402.
Levin HS, Eisenberg HM. Neuropsychological outcome of closed head injury in children and adolescents. Child Brain. 1979;5(3):281-92. [pmid: 456104].
Levin HS, Eisenberg HM, Wigg NR, et al. Memory and intellectual ability after head injury in children and adolescents. Neurosurgery. 1982;11:668-73. [pmid: 7155331].
Levin HS, High WM, Ewing-Cobbs L, et al. Memory functioning during the first year after closed head injury in children and adolescents. Neurosurgery. 1988;22(6):1043-52. [pmid: 3419566].
Levy ML, Masri LS, Levy KM, et al. Penetrating craniocerebral injury resultant from gunshot wounds: gang-related injury in children and adolescents. Neurosurgery. 1993;33(6):1018-24. [pmid: 8133986].
Levy Y, Amir N, Shaley R. Linguistic development of a child with a congenital localized left-hemisphere lesion. Cognit Neuropsychol. 1992;9:1-32.
Lewis DO, Shanok SS, Pincus JH, et al. The medical assessment of seriously delinquent boys: a comparison of pediatric, psychiatric, neurologic, and hospital record data. J Adolesc Health Care. 1982;3(3):160-4. [pmid: 6984043].
Lieh-Lai MW, Theodorou AA, Sarnaik AP, et al. Limitations of the Glasgow Coma Scale in predicting outcome in children with traumatic brain injury. J Pediatr. 1992;120(2 Pt 1):195-9. [pmid: 1735814].
Light R, Neumann E, Lewis R, et al. An evaluation of a neuropsychologically based reeducation project for the head-injured child. J Head Trauma Rehabil. 1987;2(1):11-25.
Linder CW, Leshner RT. The child with impaired consciousness. Postgrad Med. 1982;72(5):176-9, 182-5. [pmid: 6813833].
Littell RC, Milliken GA, Stroup WW, et al. SAS system for mixed models. Cary, NC: SAS Institute, 1996.
Lloyd CW, Martin WJ, Taylor BD, et al. Pharmacokinetics and pharmacodynamics of cimetidine and metabolites in critically ill children. J Pediatr. 1985;107(2):295-300. [pmid: 4020559].
Lord-Maes J, Obrzut JE. Neuropsychological consequences of traumatic brain injury in children and adolescents. J Learn Disabil. 1996;29(6):609-17. [pmid: 8942305].
Loroni L, Ciucci G, Piccinini G, et al. Approach to head trauma in childhood in a district general hospital. Eur J Emerg Med. 1996;3(3):141-8. [pmid: 9023492].
Luerssen TG. Intracranial pressure: current status in monitoring and management. Semin Pediatr Neurol. 1997;4(3):146-55. [pmid: 9323785].
Luerssen TG, Klauber MR, Marshall LF. Outcome from head injury related to patient's age: a longitudinal prospective study of adult and pediatric head injury. J Neurosurg. 1988;68:409-16. [pmid: 3343613].
Luiselli JK, Gardner R, Arons M, et al. Comprehensive community-based education and neurorehabilitation for children and adolescents with traumatic brain injury. Behav Interven. 1998;13(3):181-200.
Lumenta CB, Kramer M, Sprick C, et al. Measurements of brain-stem auditory evoked potentials in infancy, childhood, and adolescence. Child Nerv Syst. 1985;1(6):337-40. [pmid: 3833336].
Macnab AJ. Optimal escort for interhospital transport of pediatric emergencies. J Trauma. 1991;31(2):205-9. [pmid: 1994080].
MacNeill A. Behavior modification with brain-injured children: a brief note on directions for research. Percept Mot Skills. 1996;82:425-6. [pmid: 8724911].
Mahoney WJ, D'Souza BJ, Haller JA, et al. Long-term outcome of children with severe head trauma and prolonged coma. Pediatrics. 1983;71(5):756-62. [pmcid: 126266]. [pmid: 6835758].
Manchester D, Hodgkinson A, Pfaff A, et al. A non-aversive approach to reducing hospital absconding in a head-injured adolescent boy. Brain Inj. 1997;11(4):271-7. [pmid: 9134201].
Mansfield RT. Head injuries in children and adults. Crit Care Clin. 1997;13(3):611-28. [pmid: 9246533].
Marchman V, Miller R, Bates E. Babble and first words in children with focal brain injury. Appl Psycholing. 1991;12(1):1-22. [pmid: 1786231].
Martin DA. Children and adolescents with traumatic brain injury: impact on the family. J Learn Disabil. 1988;21(8):464-70. [pmid: 3053950].
Massagli TL, Jaffe KM. Pediatric traumatic brain injury: prognosis and rehabilitation. Pediatr Ann. 1994;23(1):29-30, 3-6. [pmid: 8152862].
Massagli TL, Jaffe KM, Gay GC, et al. Neurobehavioral sequelae of severe pediatric traumatic brain injury: a cohort study. Arch Phys Med Rehabil. 1996;77(3):223-31. [pmid: 8600862].
Massagli TL, Michaud LJ, Rivara FP. Association between injury indices and outcome after severe traumatic brain injury in children. Arch Phys Med Rehabil. 1996;77(2):125-32. [pmid: 8607735].
Mateer CA, Kerns KA, Eso KL. Management of attention and memory disorders following traumatic brain injury. J Learn Disabil. 1996;29(6):618-32. [pmid: 8942306].
Matousek M, Peterson, I. Frequency analysis of the EEG background activity by means of age dependent age quotients. In: Peterson PKI, editor, Automation of clinical electroencephalography. New York: Raven Press. 1973.
Matthews DJ. Survival and functional outcome of children following severe traumatic brain injury. Crit Care Med. 1997;25(8):1272. [pmid: 9267935].
Max J, Castillo C, Bokura H, et al. Oppositional defiant disorder symptomatology after traumatic brain injury: a prospective study. J Nerv Ment Dis. 1998;186:325-332. [pmid: 9653415].
Max JE, Arndt S, Castillo CS. Attention-deficit hyperactivity symptomalogy after traumatic brain injury: a prospective study. J Am Acad Child Adol Psychiatr. 1998;37(8):841-7. [pmid: 9695446].
Max JE, Bowers WA, Baldus D, et al. Pediatric traumatic brain injury and burn patients in the civil justice system: the prevalence and impact of psychiatric symptomatology. J Am Acad Psychiatr Law. 1998;26(2):247-58. [pmid: 9664260].
Max JE, Castillo CS, Robin DA, et al. Predictors of family functioning after traumatic brain injury in children and adolescents. J Am Acad Child Adolesc Psychiatr. 1998;37(1):83-90. [pmid: 9444904].
Max JE, Koele SL, Lindgren SD, et al. Adaptive functioning following traumatic brain injury and orthopedic injury: a controlled study. Arch Phys Med Rehabil. 1998;79:893-9. [pmid: 9710159].
Max JE, Koele SL, Smith WL, et al. Psychiatric disorders in children and adolescents after severe traumatic brain injury: a controlled study. J Am Acad Child Adolesc Psychiatr. 1998;37(8):832-40. [pmid: 9695445].
Max JE, Lindgren SD, Knutson C, et al. Child and adolescent traumatic brain injury: psychiatric findings from a paediatric outpatient specialty clinic. Brain Inj. 1997;11(10):699-711. [pmid: 9354246].
Max JE, Lindgren SD, Knutson C, et al. Child and adolescent traumatic brain injury: correlates of disruptive behaviour disorders. Brain Inj. 1998;12(1):41-52. [pmid: 9483336].
Max JE, Lindgren SD, Knutson C, et al. Child and adolescent traumatic brain injury: correlates of injury severity. Brain Inj. 1998;12(1):31-40. [pmid: 9483335].
Max JE, Lindgren SD, Robin DA, et al. Traumatic brain injury in children and adolescents: psychiatric disorders in the second three months. J Nerv Ment Dis. 1997;185(6):394-401. [pmid: 9205426].
Max JE, Robin DA, Lindgren SD, et al. Traumatic brain injury in children and adolescents: psychiatric disorders at two years. J Am Acad Child Adol Psychiatr. 1997;36(9):1278-84. [pmid: 9291730].
Max JE, Robin DA, Lindgren SD, et al. Traumatic brain injury in children and adolescents: psychiatric disorders at one year. J Neuropsychiatr Clin Neurosci. 1998;10(3):290-7. [pmid: 9706536].
Max JE, Sharma A, Qurashi MI. Traumatic brain injury in a child psychiatry inpatient population: a controlled study. J Am Acad Child Adolesc Psychiatr. 1997;36(11):1595-601. [pmid: 9394945].
Mayer T, Walker ML. Emergency intracranial pressure monitoring in pediatrics: management of the acute coma of brain insult. Clin Pediatr. 1982;21(7):391-6. [pmid: 7083709].
Mazza C, Pasqualin A, Feriotti G, et al. Traumatic extradural haematomas in children: experience with 62 cases. Acta Neurochir. 1982;65(1-2):67-80. [pmid: 7136879].
McArdle J, Epstein D. Latent growth curves within developmental structural equation models. Child Dev. 1987;58:110-33. [pmid: 3816341].
McClelland CQ, Rekate H, Kaufman B, et al. Cerebral injury in child abuse: a changing profile. Child Brain. 1980;7(5):225-35. [pmid: 7471912].
McCrea M, Kelly JP, Kluge J, et al. Standardized assessment of concussion in football players. Neurology. 1997;48(3):586-8. [pmid: 9065531]. [pmcid: 107739].
McDonald CM, Jaffe KM. Neurobehavioral and family functioning following traumatic brain injury in children. West J Med. 1992;157(6):664. [pmid: 1475953].
McDonald CM, Jaffe KM, Fay GC, et al. Comparison of indices of traumatic brain injury severity as predictors of neurobehavioral outcome in children. Arch Phys Med Rehabil. 1994;75(3):328-37. [pmid: 8129588].
McLean DE, Kaitz ES, Keenan CJ, et al. Medical and surgical complications of pediatric brain injury. J Head Trauma Rehabil. 1995;10(5):1-12.
Melamed LE, Wozniak JR. Neuropsychological assessment. In: Vance HB, editor, Psychological assessment of children: best practices for school and clinical settings. New York: John Wiley & Sons; 1998. p. 60-86.
Merten DF, Osborne DR. Craniocerebral trauma in the child abuse syndrome. Pediatr Ann. 1983;12(12):882-7. [pmid: 6657316].
Michaud LJ. Evaluating efficacy of rehabilitation after pediatric traumatic brain injury. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Michaud LJ. Preface. J Head Trauma Rehabil. 1995;10(5):vi-vii.
Michaud LJ, Duhaime A. Gunshot wounds to the brain in children. J Head Trauma Rehabil. 1995;10(5):25-35.
Michaud L, Rivara FP, Grady MS, et al. Predictors of survival and severity of disability after severe brain injury in children. Neurosurgery. 1992;31:254-64. [pmid: 1513431].
Michaud LJ, Rivara FP, Jaffe KM, et al. Traumatic brain injury as a risk factor for behavioral disorders in children. Arch Phys Med Rehabil. 1993;74(4):368-75. [pmid: 8466417].
Milton SB, Scaglione C, Flanagan T, et al. Functional evaluation of adolescent students with traumatic brain injury. J Head Trauma Rehabil. 1991;6(1):35-46.
Minde KK. The impact of prematurity on the later behavior of children and on their families. Clin Perinatol. 1984;11(1):227-44. [pmid: 6370549].
Miner ME, Cabrera JA, Ford E, et al. Intracranial penetration due to BB air rifle injuries. Neurosurgery. 1986;19(6):952-4. [pmid: 3808242].
Mira M, Colson S. Acquired cerebral trauma: additional educational issues. J Learn Disabil. 1988;21(10). [pmid: 3225539].
Mira MP, Tucker BF, Tyler JS. Traumatic brain injury in children and adolescents: a sourcebook for teachers and other school personnel. Austin, TX: Pro-Ed; 1992.
Mira MP, Tyler JS. Students with traumatic brain injury: making the transition from hospital to school. Focus Excep Child. 1991;23(5):1-12.
Mitchell T, Cusick A. Evaluation of a client-centered paediatric rehabilitation programme using goal attainment scaling. Aust Occup Ther J. 1998;45(1):7-17.
Mittenberg W, Wittner MS, Miller LJ. Postconcussion syndrome occurs in children. Neuropsychology. 1997;11(3):447-52. [pmid: 9223149].
Molnar GE, Easton JK, Badell A, et al. Pediatric rehabilitation. 2. Brain damage causing disability. Arch Phys Med Rehabil. 1989;70(5-S):S166-9. [pmid: 2655555].
Montado L, Schmitt M. Issues in applied developmental psychology: a life-span perspective. In: Baltes P, Brim O, editors, Life-span development and behavior. New York: Academic Press; 1982.
Montgomery SI. A head-injured teen goes home: a parent's perspective. Virginia Nurse. 1984;52(1):31-3. [pmid: 6562837].
Moviat MAM, Janssen CLW, Jaeken D, et al. Kluver-Bucy syndrome in brain injured children: neurological, neuroradiological, behavioural and neuropsychological findings. J Rehabil Sci. 1995;8(4):106-9.
Muller RA, Rothermel RD, Behen ME, et al. Brain organization of language after early unilateral lesion: a PET study. Brain Lang. 1998;62(3):422-51. [pmid: 9593617].
Mwaria CB. The concept of self in the context of crisis: a study of families of the severely brain-injured. Soc Sci Med. 1990;30(8):889-93. [pmid: 2315754].
Nass R, Koch D. Temperament differences in toddlers with early unilateral right and left brain damage. Dev Neuropsychol. 1987;3(2):93-9.
Newcombe F. The psychological consequences of closed head injury: assessment and rehabilitation. Injury. 1982;14(2):111-36. [pmid: 6754607].
Newman JE, Lovett MW, Dennis M. The use of discourse analysis in neurolinguistics: some findings from the narratives of hemidecorticate adolescents. Top Lang Disorders. 1986(7):31-44.
Noah ZL, Hahn YS, Rubenstein JS, et al. Management of the child with severe brain injury. Crit Care Clin. 1992;8(1):59-77. [pmid: 1732033].
O'Sullivan C. Courageous kids: children with traumatic brain injuries. Nursing Spectrum. 1996;6(26):6-7. [pmid: 9433321].
Oberg L, Turkstra LS. Use of elaborative encoding to facilitate verbal learning after adolescent traumatic brain injury. J Head Trauma Rehabil. 1998;13(3):44-62. [pmid: 9582178].
Ong L, Selladurai BM, Dhillon MK, et al. The prognostic value of the Glasgow Coma Scale, hypoxia and computerised tomography in outcome prediction of pediatric head injury. Pediatr Neurosurg. 1996;24(6):285-91. [pmid: 8988493].
Osberg JS, Brooke MM, Baryza MJ, et al. Impact of childhood brain injury on work and family finances. Brain Inj. 1997;11(1):11-24. [pmid: 9012548].
Osberg JS, DiScala C, Gans BM. Utilization of inpatient rehabilitation services among traumatically injured children discharged from pediatric centers. Am J Phys Med Rehabil. 1990;69:67-72. [pmid: 2158795].
Ottewell CG. From the patient's point of view: my experiences during and after my high school rugby accident. J Cognit Rehabil. 1992;10(1):8-12.
Otto U. The preconcussion syndrome in children. Acta Paedopsychiatr. 1960;27:6-20. [pmid: 14429427].
Panting A, Merry P. The long term rehabilitation of severe head injuries with particular reference to the need for social and medical support for the patient's family. Rehabilitation. 1972;38:33-7.
Paret G, Barzilay Z. Apnea testing in suspected brain dead children: physiological and mathematical modeling. Intensive Care Med. 1995;21(3):247-52. [pmid: 7790614].
Paret G, Dekel B, Yellin A, et al. Pediatric craniocerebral wounds from plastic bullets: prognostic implications, course, and outcome. J Trauma. 1996;41(5):859-63. [pmid: 8913217].
Parker RS. Neurobehavioral outcome of children's mild traumatic brain injury. Semin Neurol. 1994;14(1):67-73. [pmid: 8029562].
Parkin AE, Maas F, Rodger S. Factors contributing to successful return to school for students with acquired brain injury: parent perspectives. Aust Occup Ther J. 1996;43(3/4):133-41.
Parmelee DX. Neuropsychiatric sequellae of traumatic brain injury in children and adolescents. Psychiatr Med. 1989;7(1):11-6. [pmid: 2657868].
Parmelee DX, Kowatch RA, Sellman J, et al. Ten cases of head-injured, suicide-surviving adolescents: challenges for rehabilitation. Brain Inj. 1989;3(3):295-300. [pmid: 2758191].
Parmelee DX, O'Shanick GJ. Neuropsychiatric interventions with head injured children and adolescents. Brain Inj. 1987;1(1):41-7. [pmid: 3454670].
Patterson CM. The role of the primary care physician in maximizing cognitive and behavioral recovery from moderate to severe pediatric traumatic brain injury. J Ark Med Soc. 1998;95(3):109-13. [pmid: 9735636].
Perrott SB. Neuropsychological sequelae, familial stress, environmental adaptation following pediatric head injury. Dev Neuropsychol. 1991;7:69-86.
Pettersen L. Sensitivity to emotional cues and social behavior in children and adolescents after head injury. Percep Mot Skills. 1991;73:1139-50. [pmid: 1805169].
Pfenninger J, Kaiser G, Lutschg J, et al. Treatment and outcome of the severely head injured child. Intensive Care Med. 1983;9(1):13-6. [pmid: 6833623].
Pieper B. In home family supports: what families of youngsters with traumatic brain injury really need. New York: New York Head Injury Association; 1991.
Polissar NL, Fay GC, Jaffe KM, et al. Mild pediatric traumatic brain injury: adjusting significance levels for multiple comparisons. Brain Inj. 1994;8(3):249-63. [pmid: 8004083].
Pollack IW. Reestablishing an acceptable sense of self. In: Savage R, editor, Educational dimensions of acquired brain injury. Austin, TX: Pro-Ed, Inc; 1994. p. 303-17.
Pollack MM, Patel KM, Ruttimann UE. The Pediatric Risk of Mortality III: Acute Physiology Score (PRISM III-APS): a method of assessing physiologic instability for pediatric intensive care unit patients. J Pediatr. 1997;131(4):575-81. [pmid: 9386662].
Prior M, Kinsella G, Sawyer M, et al. Cognitive and psychological outcomes after head injury in childhood. Aust Psychol. 1994;29:116-23.
Quine S, Pierce HP, Lyle DM. Relatives as lay-therapists for the severely head-injured. Brain Inj. 1988;2(2):139-49. [pmid: 3167271].
Ramundo ML, McKnight T, Kempf J, et al. Clinical predictors of computed tomographic abnormalities following pediatric traumatic brain injury. Pediatr Emerg Care. 1995;11(1):1-4. [pmid: 7739953].
Reed JC, Reitan RM. Verbal and performance differences among brain-injured children with lateralized motor deficits. Neuropsychologia. 1971;9:401-7. [pmid: 5164375].
Reilly JS, Bates EA, Marchman VA. Narrative discourse in children with early focal brain injury. Brain Lang. 1998;61(3):335-75. [pmid: 9570869].
Ried S, Strong G, Wright L, et al. Computers, assistive devices, and augmentative communication aids: technology for social inclusion. J Head Trauma Rehabil. 1995;10(5):80-90.
Riva D, Cazzaniga L. Late effects of unilateral brain lesions sustained before and after age one. Neuropsychologia. 1986;24(3):423-8. [pmid: 3736826].
Rivara F, Mueller B. The epidemiology and prevention of pediatric head injury. J Head Trauma Rehabil. 1986;1:7-15.
Rivara JB. Family functioning following pediatric traumatic brain injury. Pediatr Ann. 1994;23(1):38-44. [pmid: 8152863].
Rivara JB, Fay GC, Jaffe KM, et al. Predictors of family functioning one year following traumatic brain injury in children. Arch Phys Med Rehabil. 1992;73(10):899-910. [pmid: 1417464].
Rivara JB, Jaffe KM, Fay GC, et al. Family functioning and injury severity as predictors of child functioning one year following traumatic brain injury. Arch Phys Med Rehabil. 1993;74(10):1047-55. [pmid: 8215855].
Rivara JB, Jaffe KM, Polissar NL, et al. Family functioning and children's academic performance and behavior problems in the year following traumatic brain injury. Arch Phys Med Rehabil. 1994;75(4):369-79. [pmid: 8172493].
Rivara JB, Jaffe KM, Polissar NL, et al. Predictors of family functioning and change 3 years after traumatic brain injury in children. Arch Phys Med Rehabil. 1996;77(8):754-64. [pmid: 8702368].
Roddy SP, Cohn SM, Moller BA, et al. Minimal head trauma in children revisited: is routine hospitalization required?. Pediatrics. 1998;101(4 Pt 1):575-7. [pmid: 9521936].
Rogers PM, Kreutzer JS. Family crises following head injury: a network intervention strategy. J Neurosurg Nurs. 1984;16(6):343-6. [pmid: 6568260].
Roman MJ, Delis DC, Willerman L, et al. Impact of pediatric traumatic brain injury on components of verbal memory. J Clin Exp Neuropsychol. 1998;20(2):245-58. [pmid: 9777479].
Rose FD, Johnson DA, Attree EA. Rehabilitation of the head-injured child: basic research and new technology. Pediatr Rehabil. 1997;1(1):3-7. [pmid: 9689231].
Rosenthal M. Rehabilitation of the adult and child with traumatic brain injury. Philadelphia: Davis; 1990.
Ross BD, Ernst T, Kreis R, et al. 1H MRS in acute traumatic brain injury. J Magn Reson Imaging. 1998;8(4):829-40. [pmid: 9702884].
Rossi C, Sullivan SJ. Motor fitness in children and adolescents with traumatic brain injury. Arch Phys Med Rehabil. 1996;77(10):1062-5. [pmid: 8857887].
Rudel RG, Teuber HL. Spatial orientation in normal children and in children with early brain injury. Neuropsychologia. 1971;9:401-7. [pmid: 5164375].
Rudel RG, Teuber HL, Twitchell TE. Levels of impairment of sensorimotor function in children with early brain damage. Neuropsychologia. 1974;12:522-31.
Ruijs MB, Keyser A, Gabreels FJ. Long-term sequelae of brain damage from closed head injury in children and adolescents. Clin Neurol Neurosurg. 1990;92(4):323-8. [pmid: 1963822].
Ruijs MBM, Keyser A, Gabriel F. Clinical neurological trauma parameters for neuropsychological recovery and long-term outcome in paediatric closed head injury: a review of the literature. Clin Neurol Neurosurg. 1994;36:273-83. [pmid: 7889687].
Russo H, Bressolle F, Duboin MP. Pharmacokinetics of high-dose thiopental in pediatric patients with increased intracranial pressure. Ther Drug Monit. 1997;19(1):63-70. [pmid: 9029749].
Rutter M. Psychological sequelae of brain damage in children. Am J Psychiatry. 1981;138(12):1533-44. [pmid: 6795943].
Rutter M. Developmental neuropsychiatry: concepts, issues and prospects. J Clin Neuropsychol. 1982;4(2):91-115. [pmid: 7107951].
Rutter M, Chadwick O, Shaffer D, et al. A prospective study of children with head injuries: design and methods. Psychol Med. 1980;10(4):633-45. [pmid: 7208723].
Sakzewski L, Ziviani J. Factors affecting length of hospital stay for children with acquired brain injuries: a review of the literature. Aust Occup Ther J. 1996;43(3/4):113-24.
Sakzewski J, Ziviani J, Swanson C. Impact of early discharge planning and case management on length of hospital stay for children with acquired brain injury. Aust Occup Ther J. 1996;43(3/4):105-12.
Sandermann J, Haase J, Bartholdy NJ, et al. Nonsurgical treatment of a traumatic brain abscess in a child. Child Nerv Syst. 1986;2(1):49-51. [pmid: 3731165].
Sanford RA. Minor head injury in children. Semin Neurol. 1988;8(1):108-114. [pmid: 3064219].
Savage R. Identification, classification and placement issues for students with traumatic brain injuries. J Head Trauma Rehabil. 1991:1-9.
Savage RC. Integrating rehabilitation and education services for school-age children with brain injuries. J Head Trauma Rehabil. 1997;12(2):11-20.
Schmitt B, Bauersfeld U, Fanconi S, et al. The effect of the N-methyl-D-aspartate receptor antagonist dextromethorphan on perioperative brain injury in children undergoing cardiac surgery with cardiopulmonary bypass: results of a pilot study. Neuropediatrics. 1997;28(4):191-7. [pmid: 9309708].
Schmitz B, Skinner EA. Perceived control, effort, and academic performance: interindividual, intraindividual, and multivariate time-series analyses. J Pers Soc Psychol. 1993;64:1010-28.
Schneider GE. Is it really better to have your brain lesion early: a revision of the "Kennard Principle.". Neuropsychology. 1979;17:557-83.
Segalowitz SJ, Brown D. Mild head injury as a source of developmental disabilities. J Learn Disabil. 1991;24:551-9. [pmid: 1765730].
Segalowitz SJ, Lawson S. Subtle symptoms associated with self-reported mild head injury. J Learn Disabil. 1995;28(5):309-19. [pmid: 7775851].
Sellars CW, Vegter CH. Pediatric brain injury: a practical resource. Tucson, AZ: Communication Skill Builders; 1993.
Sellars CW, Vegter CH, Flaig AA. Pediatric brain injury: the special case of the very young child. Houston, TX: HdI Publishers 1997; 141.
Selz M. Neuropsychological test performance of normal, learning disabled, and brain damaged older children. J Nerv Ment Dis. 1979;167:298-302. [pmid: 448332].
Shaffer D. Behavioral sequelae of serious head injury in children and adolescents: the British studies. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Shaffer D, Bijur P, Chadwick OFD, et al. Head injury and later reading and disability. J Am Acad Child Psychiatr. 1980;19:592-610. [pmid: 7204792].
Sharma M, Sharma AK. Mode, presentation, CT findings and outcome of pediatric head injury. Indian Pediatr. 1994;31(6):733-9. [pmid: 7896410].
Shurtleff HA, Massagli TL, Hays RM, et al. Screening children and adolescents with mild or moderate traumatic brain injury to assist school reentry. J Head Trauma Rehabil. 1995;10(5):64-79.
Sigelman C, Shaffer DR. Life-span human development. Pacific Grove, CA: Brooks-Cole; 1995.
Silver BV, Boake C, Cavazos DI. Improving functional skills using behavioral procedures in a child with anoxic brain injury. Arch Phys Med Rehabil. 1994;75(7):742-5. [pmid: 8024417].
Silver BV, Yablon SA. Akathisia resulting from traumatic brain injury. Brain Inj. 1996;10(8):609-14. [pmid: 8836518].
Singer GHS, Glang A, Nixon C, et al. A comparison of two psychosocial interventions for parents of children with acquired brain injury: an exploratory study. J Head Trauma Rehabil. 1994;9(4):38-49.
Singer GHS, Nixon C. "You can't imagine unless you've been there yourself": a report on the concerns of parents of children with acquired brain injury. Washington: U.S. Department of Education; 1993.
Skinner E, Zimmer-Gembeck MJ, Connell J, editors, Individual differences and the development of perceived control Monogr Soc Res Child Dev 1998 63(2-3) i iv
Skippen P, Seear M, Poskitt K, et al. Effect of hyperventilation on regional cerebral blood flow in head-injured children. Crit Care Med. 1997;25(8):1402-9. [pmid: 9267957].
Slater EJ, Bassett SS. Adolescents with closed head injuries: a report of initial cognitive deficits. Am J Dis Child. 1988;142(10):1048-51. [pmid: 3177300].
Slifer KJ, Cataldo MD, Babbitt RL, et al. Behavior analysis and intervention during hospitalization for brain trauma rehabilitation. Arch Phys Med Rehabil. 1993;74(8):810-7. [pmid: 8347066].
Slifer KJ, Cataldo MD, Kurtz PF. Behavioural training during acute brain trauma rehabilitation: an empirical case study. Brain Inj. 1995;9(6):585-93. [pmid: 7581354].
Slifer KJ, Tucker CL, Gerson AC, et al. Operant conditioning for behavior management during posttraumatic amnesia in children and adolescents with brain injury. J Head Trauma Rehabil. 1996;11(1):39-50.
Slifer KJ, Tucker CL, Gerson AC, et al. Antecedent management and compliance training improve adolescents' participation in early brain injury rehabilitation. Brain Inj. 1997;11(12):877-89. [pmid: 9413622].
Sobus K, Alexander A, Harcke T. Undetected musculoskeletal trauma in children with traumatic brain injury or spinal cord injury. Arch Phys Med Rehabil. 1993;74:902-4. [pmid: 8379833].
Sohlberg M. Communication Disorders & Sciences. University of Oregon, Eugene OR. Personal communication, January 1999.
Sokol DK, Ferguson CF, Pitcher GA, et al. Behavioural adjustment and parental stress associated with closed head injury in children. Brain Inj. 1996;10(6):439-51. [pmid: 8816097].
Sollee ND, Kindlon DJ. Lateralized brain injury and behavior problems in children. J Abnorm Child Psychol. 1987;15(4):479-91. [pmid: 3437085].
Song SH, Kim SH, Kim KT, et al. Outcome of pediatric patients with severe brain injury in Korea: a comparison with reports in the west. Child Nerv Syst. 1997;13(2):82-6. [pmid: 9105742].
Snow JH, Hooper SR. Pediatric traumatic brain injury. Thousand Oaks, CA: Sage Publications; 1994.
Splaingard ML, Gaebler D, Havens P, et al. Brain injury: functional outcome in children with tracheostomies and gastrostomies. Arch Phys Med Rehabil. 1989;70(4):318-21. [pmid: 2930347].
St. James-Roberts I. Neurological plasticity, recovery from brain insult, and child development. Adv Child Dev Behav. 1979;14:253-319. [pmid: 44640].
Sternlicht M. Understanding the brain-damaged adolescent: behavior and treatment. In: Adler L, editor, Crosscultural research in human development: life-span perspectives. New York: Praeger Publishers; 1989. p. 78-84.
Stevens AM. Traumatic brain injury and special education: an information resource guide. Washington: U.S. Department of Education; 1994.
Stewart-Scott A, Douglas JM. Educational outcome for secondary and postsecondary students following traumatic brain injury. Brain Inj. 1998;12(4):317-31. [pmid: 9562914].
Stiles J, Nass R. Spatial grouping activity in young children with congenital right or left-hemisphere brain injury. Brain Cogn. 1991;15(2):201-22. [pmid: 2043364].
Stiles J, Stern C, Trauner D, et al. Developmental change in spatial grouping activity among children with early focal brain injury: evidence from a modeling task. Brain Cogn. 1996;31(1):46-62. [pmid: 8790934].
Stiles J, Thal D. Linguistic and spatial cognitive development following early focal brain injury: patterns of deficit and recovery. In: Johnson M, editor, Brain development and cognition. Oxford: Blackwell Publishers; 1993. p. 643-64.
Stiles-Davis J, Janowsky J, Engel M, et al. Drawing ability in four young children with congenital unilateral brain lesions. Neuropsychologia. 1988;26:359-71. [pmid: 3374798].
Stiles-Davis J, Sugarman S, Nass R. The development of spatial relations in four young children with right-cerebral-hemisphere damage: evidence for an early spatial constructive deficit. Brain Cogn. 1985;4:388-412. [pmid: 4084400].
Sutton LN, Wang Z, Duhaime AC, et al. Tissue lactate in pediatric head trauma: a clinical study using 1H NMR spectroscopy. Pediatr Neurosurg. 1995;22(2):81-7. [pmid: 7710977].
Suzman KB, Morris RD, Morris MK, et al. Cognitive-behavioral remediation of problem solving deficits in children with acquired brain injury. J Behav Ther Exp Psychiatr. 1997;28(3):203-12. [pmid: 9327299].
Szatmari P. Some methodologic criteria for studies in developmental neuropsychiatry. Psychiatr Dev. 1985;3(2):153-70. [pmid: 4048145].
Taylor HG, Alden J. Age-related differences in outcomes following childhood brain insults: an introduction and overview. J Int Neuropsychol Soc. 1997;3(6):555-67. [pmid: 9448369].
Taylor HG, Drotar D, Wade S, et al. Recovery from traumatic brain injury in children: the importance of the family. In: Broman S, Michel M, editors, Traumatic head injury in children. New York, NY: Oxford University Press; 1994. p. 188-216.
Telzrow CF. Management of academic and educational problems in head injury. J Learn Disabil. 1987;20(9):536-45. [pmid: 3320243].
Tepas JJ, DiScala C, Ramenofsky ML, et al. Mortality and head injury: the pediatric perspective. J Pediatr Surg. 1990;25(1):92-5. [pmid: 2299551].
Thakker JC, Splaingard M, Zhu J, et al. Survival and functional outcome of children requiring endotracheal intubation during therapy for severe traumatic brain injury. Crit Care Med. 1997;25(8):1396-401. [pmid: 9267956].
Thal DJ, Marchman V, Stiles J, et al. Early lexical development in children with focal brain injury. Brain Lang. 1991;40(4):491-527. [pmid: 1878781].
Thatcher RW. Maturation of the human frontal lobes: physical evidence for staging. Dev Neuropsychol. 1991;7:397-419.
Thompson NM, Francis DJ, Stuebing KK, et al. Motor, visual-spatial, somatosensory skills after closed head injury in children and adolescents: a study of change. Neuropsychology. 1994;8:333-42.
Thomsen IV. Do young patients have worse outcomes after severe blunt head trauma?. Brain Inj. 1989;3(2):157-62. [pmid: 2730973].
Todd JA, Anderson VA, Lawrence JA. Planning skills in head injured adolescents and their peers. Neuropsychol Rehabil. 1996;6:81-99.
Tomberg T, Rink U, Pikkoja E, et al. Computerized tomography and prognosis in paediatric head injury. Acta Neurochir. 1996;138(5):543-8. [pmid: 8800329].
Tompkins CA, Holland AL, Ratcliff G, et al. Predicting cognitive recovery from closed head injury in children and adolescents. Brain Cogn. 1990;13(1):86-97. [pmid: 2346641].
Towne RL, Entwisle L. Metaphoric comprehension in adolescents with traumatic brain injury and in adolescents with language/learning disability. Lang Speech Hear Serv Sch. 1993;24:100-7.
Trauner DA, Ballantyne A, Friedland S, et al. Disorders of affactive and linguistic prosody in children after early unilateral brain damage. Ann Neurol. 1996;39(3):361-7. [pmid: 8602755].
Tucker BF, Colson SE. Traumatic brain injury: an overview of school re-entry. Interven Sch Clin. 1992;27(4):198-206.
Turkstra LS, Holland AL. Assessment of syntax after adolescent brain injury: effects of memory on test performance. J Speech Lang Hear Res. 1998;41(1):137-49. [pmid: 9493740].
Turkstra LS, McDonald S, Kaufmann PM. Assessment of pragmatic communication skills in adolescents after traumatic brain injury. Brain Inj. 1996;10(5):329-45. [pmid: 8735664].
U.S. Department of Education. To assure the free public education of all children with disabilities: eighteenth report to Congress on the implementation of the Individuals with Disabilities Education Act. Washington: U.S. Department of Education; 1996.
Vander A, Sherman J, Luciano D. Human physiology: the mechanisms of body function. New York: McGraw-Hill; 1970, p. 194.
Vander Schaaf PJ, Kriel RL, Krach LE, et al. Late improvements in mobility after acquired brain injuries in children. Pediatr Neurol. 1997;16(4):306-10. [pmid: 9258963].
Vartiainen E, Karjalainen S, Karja J. Auditory disorders following head injury in children. Acta Otolaryngol. 1985;99(5-6):529-36. [pmid: 4024901].
Vigil-Sewell J, Sargent JD. Long-term outcome after severe brain injury in preschoolers is worse than expected. Arch Pediatr Adolesc Med. 1996;150(2):228. [pmid: 8556136].
Virginia Department of Education. The nature of services provided students with traumatic brain injury in Virginia. Richmond, VA: Office of Educational Research and Improvement; 1991. p. 2-11.
Waaland P. Families coping with childhood neurological disability: clinical assessment and treatment. Neuropsychol Rehabil. 1991;1:19-27.
Waaland P, Kreutzer J. Family response to childhood traumatic brain injury. J Head Trauma Rehabil. 1988;3:51-63.
Waaland PK. Pediatric traumatic brain injury: special topic report no. 3. Richmond, VA: Rehabilitation Research & Training Center on Severe Traumatic Brain Injury; 1990.
Waaland PK, Burns C, Cockrell J. Evaluation of needs of high- and low-income families following paediatric traumatic brain injury. Brain Inj. 1993;7(2):135-46. [pmid: 8453412].
Wade D, King N, Wenden F, et al. Routine follow up after head injury: a second randomised controlled trial. J Neurol Neurosurg Psychiatr. 1998;65:177-83. [pmid: 9703167].
Wade S, Drotar D, Taylor HG, et al. Assessing the effects of traumatic brain injury on family functioning: conceptual and methodological issues. J Pediatr Psychol. 1995;20(6):737-52. [pmid: 8558375].
Wade SL, Taylor HG, Drotar D, et al. Childhood traumatic brain injury: initial impact on the family. J Learn Disabil. 1996;29(6):652-61. [pmid: 8942309].
Wade SL, Taylor HG, Drotar D, et al. Family burden and adaptation during the initial year after traumatic brain injury in children. Pediatrics. 1998;102:110-6. [pmid: 9651422].
Ward J. The prospect of pediatric clinical trials: experience with adult trials. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Ward JD. Pediatric issues in head trauma. New Horiz. 1995;3(3):539-45. [pmid: 7496765].
Warschausky S, Cohen EH, Parker JG, et al. Social problem-solving skills of children with traumatic brain injury. Pediatr Rehabil. 1997;1(2):77-81. [pmid: 9689242].
Warzak WJ, Allan TM, Ford LA, et al. Common obstacles to the daily functioning of pediatric traumatically brain injured patients: perceptions of caregivers and psychologists. Child Health Care. 1995;24(2):133-41. [pmid: 10143003].
Webb C, Rose FD, Johnson DA, et al. Age and recovery from brain injury: clinical opinions and experimental evidence. Brain Inj. 1996;10(4):303-10. [pmid: 9044695].
Willett J, Ayoub C, Robinson D. Using growth modeling to examine systematic differences in growth: an example of change in the functioning of families at risk of maladaptive parenting, child abuse, and neglect. J Consult Clin Psychol. 1991;59:38-47. [pmid: 2002141].
Willett J, Sayer A. Using covariance structure analysis to detect correlates and predictors of individual change over time. Psychol Bull. 1994;116:363-81.
Williams D, Mateer CA. Developmental impact of frontal lobe injury in middle childhood. Brain Cogn. 1992;20(1):196-204. [pmid: 1382463].
Williams SE, Ris MD, Ayyangar R, et al. Recovery in pediatric brain injury: is psychostimulant medication beneficial?. J Head Trauma Rehabil. 1998;13(3):73-81. [pmid: 9582180].
Wilson SL, Powell GE, Brock D, et al. Vegetative state and responses to sensory stimulation: an analysis of 24 cases. Brain Inj. 1996;10(11):807-18. [pmid: 8905159].
Winogron HW, Kinghts RM, Bawden HN. Neuropsychological deficits following head injury in children. J Clin Neuropsychol. 1984;6:269-86.
Wit J, Maassen B, Gabreels F, et al. Traumatic versus perinatally acquired dysarthria: assessment by means of speech-like maximum performance tasks. Dev Med Child Neurol. 1994;36(3):221-9. [pmid: 8138071].
Wolcott GF, Lash M, Pearson S. Signs and strategies for educating students with brain injuries: a practical guide for teachers and schools. Houston, TX: HdI Publishers; 1995. p. 101.
Woods B. The restricted effects of right-hemisphere lesions after age one: Wechsler test data. Neuropsychologia. 1980;18(1):65-70. [pmid: 7366824].
Woods B, Carey S. Language deficits after apparent clinical recovery from childhood aphasia. Ann Neurol. 1979;6:405-9. [pmid: 92909].
Worley G, Hoffman JM, Paine SS, et al. 18-Fluorodeoxyglucose positron emission tomography in children and adolescents with traumatic brain injury. Dev Med Child Neurol. 1995;37(3):213-20. [pmid: 7890126].
Worthington J. The impact of adolescent development on recovery from traumatic brain injury. Rehabil Nurs. 1989;14(3):118-22. [pmid: 2657903].
Wrightson P, McGinn V, Gronwall D. Mild head injury in preschool children: evidence that it can be associated with a persisting cognitive defect. J Neurol Neurosurg Psychiatr. 1995;59(4):375-80. [pmid: 7561915].
Yeates KO, Blumenstein E, Patterson CM, et al. Verbal learning and memory following pediatric closed-head injury. J Int Neuropsychol Soc. 1995;1(1):78-87. [pmid: 9375212].
Yeates KO, Taylor HG, Drotar D, et al. Preinjury family environment as a determinant of recovery from traumatic brain injuries in school-age children. J Int Neuropsychol Soc. 1997;3(6):617-30. [pmid: 9448375].
Ylvisaker M. Language and communication disorders following pediatric head injury. J Head Trauma Rehabil. 1986;1(4):48-56.
Ylvisaker M. Communication outcome in children and adolescents with traumatic brain injury. Neuropsychol Rehabil. 1993;3:367-87.
Ylvisaker M, editor. Traumatic brain injury rehabilitation: children and adolescents. Boston: Butterworth-Heinemann; 1998.
Ylvisaker M. Department of Communication Disorders, College of St. Rose, Albany, NY. Personal communication February, 1999.
Ylvisaker M, Feeney TJ. Traumatic brain injury in adolescence: assessment and reintegration. Semin Speech Lang. 1995;16(1):32-44. [pmid: 7621328].
Ylvisaker M, Giola G. Comprehensive cognitive assessment. In: Ylvisaker M, editor, Traumatic brain injury rehabilitation: children and adolescents. Boston: Butterworth-Heinenmann; 1998.
Ylvisaker M, Szekeres SF, Hartwick P, et al. Cognitive intervention. In: Savage R, editor, Educational dimensions of acquired brain injury. Austin, TX: Pro-Ed Inc; 1994. p. 121-84.
Ylvisaker M, Weinstein M. Recovery of oral feeding after pediatric head injury. J Head Trauma Rehabil. 1989;4(4):51-63.
Yorkston KM, Jaffe KM, Polissar NL, et al. Written language production and neuropsychological function in children with traumatic brain injury. Arch Phys Med Rehabil. 1997;78(10):1096-102. [pmid: 9339159].
Zaucha K, Asarnow R, Satz P, et al. The UCLA studies of mild closed head injury in children adolescents. J Clin Exp Neuropsychol. 1993;15.
Zencius A, Wesolowski MD, Burke WH. Comparing motivational systems with two non-compliant head-injured adolescents. Brain Inj. 1989;3(1):67-71. [pmid: 2924043].
Zimmer-Gembeck M. Using hierarchical linear modeling and SAS PROC MIXED to investigate launch, ambient-level, and change-to-change relations. In: Skinner E, Zimmer-Gembeck M, Connell J, editors, Individual differences and the development of perceived control. Monog Soc Res Child Dev. 1998;63(2-3):187-204.
Zuckerman GB, Conway EE Jr. Accidental head injury. Pediatr Ann. 1997;26(10). [pmid: 9339463].