# References

Anderson VA, Moore C. Age at injury as a predictor of outcome following pediatric head injury: a longitudinal perspective. Child Neuropsychol. 1995;1:187-202.
Asarnow R, Satz P, Light R, et al. The UCLA study of mild closed head injury in children and adolescents. In: Broman S, Michel ME, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Bailey DJ, Burchinal M, McWilliam R. Age of peers and early childhood development. Child Dev. 1993;64:287-309.
Baltes P. Theoretical propositions of life-span development psychology: on dynamics of growth and decline. Dev Psychol. 1987;23(5):611-626.
Baltes P, Reese H, Nesselroade J. Life-span development psychology: introduction to research methods. Monterey, CA: Brooks/Cole; 1977.
Berger E, Worgotter G, Oppolzer A, et al. Neurological rehabilitation in children and adolescents. Pediatr Rehabil. 1997;1(4):229-33. [pmid: 9689259].
Berger K. The developing person through the life span. New York: Worth; 1998. p. 138ff.
Bergman A. Brain Injury Association, Alexandria, VA. Personal communication, December 1998.
Bergman L, Eklund G, Magnusson D. Problems and methods in longitudinal research: stability and change. In: Magnusson D, Bergman L, Kudinger G, et al, editors, Studying individual development: problems and methods. New York: Cambridge University Press; 1991.
Berk L. In: Development through the lifespan. Boston: Allyn & Bacon; 1998. p. 118ff.
Bijur P, Haslum M. Cognitive, behavioral, and motor sequelae of mild head injury in a national birth cohort. In: Broman S, Michel ME, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Blosser JL, DePompei R. The head-injured student returns to school: recognizing and treating deficits. Top Lang Disorders. 1989;9:67-77.
Boyer MG, Edwards P. Outcome 1 to 3 years after severe traumatic brain injury in children and adolescents. Injury. 1991;22(4):315-20. [pmid: 1937730].
Brett AW, Laatsch L. Cognitive rehabilitation therapy of brain-injured students in a public high school setting. Pediatr Rehabil. 1998;2(1):27-31. [pmid: 9661709].
Broman SH, Michel ME. Traumatic head injury in children. New York: Oxford University Press; 1994.
Bryk A, Raudenbush S. Application of hierarchical linear models to assessing change. Psychol Bull. 1987;101:147-58.
Bryk A, Raudenbush S. Hierarchical linear models: applications and data analysis methods. Newbury Park, CA: Sage Publications; 1992.
Burchinal M, Appelbaum M. Estimating individual developmental functions: methods and their assumptions. Child Dev. 1991;62:23-43.
Burke WH, Wesolowski MD, Buyer DM, et al. The rehabilitation of adolescents with traumatic brain injury: outcome and follow-up. Brain Inj. 1990;4(4):371-8. [pmid: 2252969].
Campbell D, Stanley J. Experimental and quasi-experimental designs for research. Chicago: Rand McNally; 1966.
Centers for Disease Control and Prevention. Traumatic brain injury in the United States. Unpublished data from the National Center for Injury Prevention and Control, May 1998.
Chapman SB, Culhane KA, Levin HS, et al. Narrative discourse after closed head injury in children and adolescents. Brain Lang. 1992;43(1):42-65. [pmid: 1643511].
Chesnut RM, Carney N, Maynard H, et al. Rehabilitation for traumatic brain injury. Evidence report no. 2 (Contract 290-97-0018 to Oregon Health Sciences University). Rockville, MD: Agency for Health Care Policy and Research. February 1999.
Connell J, Skinner E. Predicting trajectories of academic engagement: a growth curve analysis of children's motivation in school. Paper presented at: Meeting of the American Educational Research Association; Boston; 1990.
Dennis M. Intelligence after early brain injury: predicting IQ scores from medical variables. J Clin Exp Neuropsychol. 1985;7:526-54. [pmid: 4066908].
Dennis M, Barnes MA, Donnelly RE, et al. Appraising and managing knowledge: meta-cognitive skills after childhood head injury. Dev Neuropsychol. 1996;12:77-103.
Dennis M, Wilkinson M, Koski L, et al. Attention deficits in the long term after childhood head injury. In: Broman S, Michel M, editors, Traumatic brain injury in children. New York: Oxford University Press; 1994.
DePompei R. School of Speech-Language Pathology and Audiology, University of Akron, Akron OH. Personal communication, December 1998.
DiScala C, Osberg JS, Savage RC. Children hospitalized for traumatic brain injury: transition to postacute care. J Head Trauma Rehabil. 1997;12(2):1-10.
Donders J. Academic placement after traumatic brain injury. In: Annual meeting of the International Neuropsychological Society; Office of Educational Research and Improvement, U.S. Department of Education; 1992. p. 2-5.
Donders J. Academic placement after traumatic brain injury. J Sch Psychol. 1994;32(1):53-65.
Education for All Handicapped Children Act of 1975. Public Law 94-142, 89 Stat 773.
Fay GC, Jaffe KM, Polissar NL, et al. Mild pediatric traumatic brain injury: a cohort study. Arch Phys Med Rehabil. 1993;74(9):895-901. [pmid: 8379832].
Fay GC, Jaffe KM, Polissar NL, et al. Outcome of pediatric traumatic brain injury at three years: a cohort study. Arch Phys Med Rehabil. 1994;75(7):733-41. [pmid: 8024416].
Feeney TJ, Ylvisaker M. Choice and routine: antecedent behavioral interventions for adolescents with severe traumatic brain injury. J Head Trauma Rehabil. 1995;10(3):67-86.
Feldman HM, Holland AL, Kemp SS, et al. Language development after unilateral brain injury. Brain Lang. 1992;42:89-102. [pmid: 1547471].
Fletcher J, Ewing-Cobbs L, Francis D, et al. Variability in outcomes after traumatic brain injury in children: a developmental perspective. In: Traumatic head injury in children. New York: Oxford University Press; 1994.
Francis D, Fletcher J, Stuebing K, et al. Analysis of change: modeling individual growth. J Consult Clin Psychol. 1991;59:27-37. [pmid: 2002140].
Franzen KM, Roberts MA, Schmits D, et al. Cognitive remediation in pediatric traumatic brain injury. Child Neuropsychol. 1996;2(3):176-84.
Glang, A. Teaching Research. Eugene, OR. Personal communication, 1999.
Glang A, Singer G, Cooley E, et al. Tailoring direct instruction techniques for use with elementary students with brain injury. J Head Trauma Rehabil. 1992;7(4):93-108.
Glang A, Todis B, Cooley E, et al. Building social networks for children and adolescents with traumatic brain injury: a school-based intervention. J Head Trauma Rehabil. 1997;12(2):32-47.
Gordon, W. Mount Sinai Medical Center, New York. Personal Communication, January 1999.
Greenspan AI, MacKenzie EJ. Functional outcome after pediatric head injury. Pediatrics. 1994;94:425-32. [pmid: 7936848].
Heiskanen O, Kaste M. Late prognosis of severe brain injury in children. Dev Med Child Neurol. 1974;16:11-4. [pmid: 4205076].
Hirsch B, DuBois D. The identification and prediction of contrasting longitudinal trajectories. J Youth Adolesc. 1991;20:53-72.
Hu X, Wesson D, Kenney B, et al. Risk factors for extended disruption of family function after severe injury to a child. Can Med Assoc J. 1993;149:421-7. [pmid: 8348424]. [pmcid: 1485644].
Hudspeth WJ, Pribram KH. Stages of brain and cognitive maturation. J Educ Psychol. 1990;82:881-4.
Individuals with Disabilities Education Act (IDEA) of 1990. Pub Law 101-476, 20 U.S.C. § 1400.
Jaffe KM, Fay GC, Polissar NL, et al. Severity of pediatric traumatic brain injury and early neurobehavioral outcome: a cohort study. Arch Phys Med Rehabil. 1992;73(6):540-7. [pmid: 1622302].
Jaffe KM, Fay GC, Polissar NL, et al. Severity of pediatric traumatic brain injury and neurobehavioral recovery at one year: a cohort study. Arch Phys Med Rehabil. 1993;74(6):587-95. [pmid: 1622302].
Jaffe KM, Hays RM. Pediatric head injury: rehabilitative medical management. J Head Trauma. 1986;1:30-40.
Jaffe KM, Polissar NL, Fay GC, et al. Recovery trends over three years following pediatric traumatic brain injury. Arch Phys Med Rehabil. 1995;76(1):17-26. [pmid: 7811169].
Kaufmann PM, Fletcher JM, Levin HS, et al. Attentional disturbance after pediatric closed head injury. J Child Neurol. 1993;8:348-53. [pmid: 8228030].
Kinsella G, Prior M, Sawyer M, et al. Neuropsychological deficit and academic performance in children and adolescents following traumatic brain injury. J Pediatr Psychol. 1995;20(6):753-67. [pmid: 8558376].
Kinsella GJ, Prior M, Sawyer M, et al. Predictors and indicators of academic outcome in children 2 years following traumatic brain injury. J Int Neuropsychol Soc. 1997;3(6):608-16. [pmid: 9448374].
Kleinpeter U. Social integration after brain trauma during childhood. Acta Paedopsychiatr. 1976;42(2):68-75. [pmid: 788458].
Klonoff H, Clark C, Klonoff PS. Long-term outcome of head injuries: a 23 year follow up study of children with head injuries. J Neurol Neurosurg Psychiatr. 1993;56(4):410-5. [pmid: 8482963].
Klonoff H, Low MD, Clark C. Head injuries in children: a prospective five-year followup. J Neurol Neurosurg Psychiatr. 1977;40:1211-9. [pmid: 591990].
Klonoff H, Paris R. Immediate, short-term and residual effects of acute head injuries in children. Clinical Neuropsychology: Current Status and Applications 1974:178-210.
Kolb B. Brain development, plasticity, and behavior. Am Psychol. 1989;44(9):1203-12. [pmid: 2782728].
Krashen S. Lateralization, language learning, and the critical period: some new evidence. Lang Learn. 1973;23(1):63-74.
Levin HS, Eisenberg HM, Wigg NR, et al. Memory and intellectual ability after head injury in children and adolscents. Neurosurgery. 1982;11:668-73. [pmid: 7155331].
Light R, Neumann E, Lewis R, et al. An evaluation of a neuropsychologically based reeducation project for the head-injured child. J Head Trauma Rehabil. 1987;2(1):11-25.
Littell RC, Milliken GA, Stroup WW, et al. SAS system for mixed models. Cary, NC: SAS Insitute Inc.; 1996.
Luiselli JK, Gardner R, Arons M, et al. Comprehensive community-based education and neurorehabilitation for children and adolescents with traumatic brain injury. Behav Interven. 1998;13(3):181-200.
Matousek M, Peterson, I. Frequency analysis of the EEG background activity by means of age dependent age quotients. In: Peterson PKI, editor, Automation of clinical electroencephalography. New York: Raven Press; 1973. p. 75-102.
Max JE, Sharma A, Qurashi MI. Traumatic brain injury in a child psychiatry inpatient population: a controlled study. J Am Acad Child Adolesc Psychiatr. 1997;36(11):1595-601. [pmid: 9394945].
McArdle J, Epstein D. Latent growth curves within developmental structural equation models. Child Dev. 1987;58:110-33. [pmid: 3816341].
Michaud L, Rivara FP, Grady MS, et al. Predictors of survival and severity of disability after severe brain injury in children. Neurosurgery. 1992;31:254-64. [pmid: 1513431].
Michaud LJ. Evaluating efficacy of rehabilitation after pediatric traumatic brain injury. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Montado L, Schmitt M. Issues in applied developmental psychology: a life-span perspective. In: Baltes P, Brim O, editors, Life-span development and behavior. New York: Academic Press; 1982.
Osberg JS, Brooke MM, Baryza MJ, et al. Impact of childhood brain injury on work and family finances. Brain Inj. 1997;11(1):11-24. [pmid: 9012548].
Osberg JS, DiScala C, Gans BM. Utilization of inpatient rehabilitation services among traumatically injured children discharged from pediatric centers. Am J Phys Med Rehabil. 1990;69:67-72. [pmid: 2158795].
Parkin AE, Maas F, Rodger S. Factors contributing to successful return to school for students with acquired brain injury: parent perspectives. Aust Occup Ther J. 1996;43(3/4):133-41.
Riva D, Cazzaniga L. Late effects of unilateral brain lesions sustained before and after age one. Neuropsychologia. 1986;24(3):423-8. [pmid: 3736826].
Rivara JB, Fay GC, Jaffe KM, et al. Predictors of family functioning one year following traumatic brain injury in children. Arch Phys Med Rehabil. 1992;73(10):899-910. [pmid: 1417464].
Rivara JB, Jaffe KM, Polissar NL, et al. Predictors of family functioning and change 3 years after traumatic brain injury in children. Arch Phys Med Rehabil. 1996;77(8):754-64. [pmid: 8702368].
Rutter M, Chadwick O, Shaffer D, et al. A prospective study of children with head injuries: design and methods. Psychol Med. 1980;10(4):633-45. [pmid: 7208723].
Savage RC. Integrating rehabilitation and education services for school-age children with brain injuries. J Head Trauma Rehabil. 1997;12(2):11-20.
Schmitz B, Skinner EA. Perceived control, effort, and academic performance: interindividual, intraindividual, and multivariate time-series analyses. J Pers Soc Psychol. 1993;64:1010-28.
Sigelman C, Shaffer, DR. In: Life-span human development. 2nd ed. Pacific Grove, CA: Brooks-Cole; 1995.
Singer GHS, Glang A, Nixon C, et al. A comparison of two psychosocial interventions for parents of children with acquired brain injury: an exploratory study. J Head Trauma Rehabil. 1994;9(4):38-49.
Skinner E, Zimmer-Gembeck MJ, Connell, J. Individual differences and the development of perceived control. Monogr Soc Res Child Dev. 1998;63(2-3):i-iv.
Sobus K, Alexander A, Harcke T. Undetected Musculoskeletal trauma in children with traumatic brain injury or spinal cord injury. Arch Phys Med Rehabil. 1993;74:902-4. [pmid: 8379833].
Sohlberg M. Communication Disorders & Sciences. University of Oregon, Eugene, OR. Personal communication, January 1999.
Stiles J, Stern C, Trauner D, et al. Developmental change in spatial grouping activity among children with early focal brain injury: evidence from a modeling task. Brain Cogn. 1996;31(1):46-62. [pmid: 8790934].
Stiles J, Thal D. Linguistic and spatial cognitive development following early focal brain injury: patterns of deficit and recovery. In: Johnson M, editor, Brain development and cognition. Oxford: Blackwell Publishers; 1993. p. 643-64.
Suzman KB, Morris RD, Morris MK, et al. Cognitive-behavioral remediation of problem solving deficits in children with acquired brain injury. J Behav Ther Exp Psychiatr. 1997;28(3):203-12. [pmid: 9327299].
Taylor HG, Alden J. Age-related differences in outcomes following childhood brain insults: an introduction and overview. J Int Neuropsychol Soc. 1997;3(6):555-67. [pmid: 9448369].
Taylor HG, Drotar D, Wade S, et al. Recovery from traumatic brain injury in children: the importance of the family. In: Broman S, Michel, M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994. p. 188-216.
Thal DJ, Marchman V, Stiles J, et al. Early lexical development in children with focal brain injury. Brain Lang. 1991;40(4):491-527. [pmid: 1878781].
Thatcher RW. Maturation of the human frontal lobes: physical evidence for staging. Dev Neuropsychol. 1991;7:397-419.
Thompson NM, Francis DJ, Stuebing KK, et al. Motor, visual-spatial, somatosensory skills after closed head injury in children and adolescents: a study change. Neuropsychology. 1994;8:333-42.
U.S. Department of Education. To assure the free public education of all children with disabilities: eighteenth report to Congress on the implementation of the Individuals with Disabilities Education Act. Washington: U.S. Department of Education; 1996.
Vander Schaaf PJ, Kriel RL, Krach LE, et al. Late improvements in mobility after acquired brain injuries in children. Pediatr Neurol. 1997;16(4):306-10. [pmid: 9258963].
Virginia Department of Education. The nature of services provided students with traumatic brain injury in Virginia. Richmond: Office of Educational Research and Improvement; 1991: p. 2-11.
Waaland PK, Burns C, Cockrell J. Evaluation of needs of high- and low-income families following paediatric traumatic brain injury. Brain Inj. 1993;7(2):135-46. [pmid: 8453412].
Wade D, King N, Wenden F, et al. Routine follow up after head injury: a second randomised controlled trial. J Neurol, Neurosurg, & Psychiatry. 1998;65:177-83. [pmid: 9703167].
Wade S, Drotar D, Taylor HG, et al. Assessing the effects of traumatic brain injury on family functioning: conceptual and methodological issues. J Pediatr Psychol. 1995;20(6):737-52. [pmid: 8558375].
Wade SL, Taylor HG, Drotar D, et al. Childhood traumatic brain injury: initial impact on the family. J Learn Disabil. 1996;29(6):652-61. [pmid: 8942309].
Ward J. The prospect of pediatric clinical trials: experience with adult trials. In: Broman S, Michel M, editors, Traumatic head injury in children. New York: Oxford University Press; 1994.
Willett J, Ayoub C, Robinson D. Using growth modeling to examine systematic differences in growth: an example of change in the functioning of families at risk of maladaptive parenting, child abuse, and neglect. J Consult Clin Psychol. 1991;59:38-47. [pmid: 2002141].
Willett J, Sayer A. Using covariance structure analysis to detect correlates and predictors of individual change over time. Psychol Bull. 1994;116:363-81.
Woods B. The restricted effects of right-hemisphere lesions after age one: Wechsler test data. Neuropsychologia. 1980;18(1):65-70. [pmid: 7366824].
Yeates KO, Taylor HG, Drotar D, et al. Preinjury family environment as a determinant of recovery from traumatic brain injuries in school-age children. J Int Neuropsychol Soc. 1997;3(6):617-30. [pmid: 9448375].
Ylvisaker M. Department of Communication Disorders, College of St. Rose, Albany, NY. Personal Communication, February, 1999.
Ylvisaker M, editor. Traumatic brain injury rehabilitation: children and adolescents. Boston: Butterworth-Heinemann; 1998.
Ylvisaker M, Feeney TJ. Traumatic brain injury in adolescence: assessment and reintegration. Semin Speech Lang. 1995;16(1):32-44. [pmid: 7621328].
Ylvisaker M, Gioia G. Comprehensive cognitive assessment. In Ylvisaker, M, editor, Traumatic brain injury rehabilitation: children and adolescents. Boston, MA: Butterworth-Heinenmann; 1998.
Yorkston KM, Jaffe KM, Polissar NL, et al. Written language production and neuropsychological function in children with traumatic brain injury. Arch Phys Med Rehabil. 1997;78(10):1096-102. [pmid: 9339159].
Zimmer-Gembeck M. Using hierarchical linear modeling and SAS PROC MIXED to investigate launch, ambient-level, and change-to-change relations. In: Skinner E, Zimmer-Gembeck M, Connell J, editors. Individual differences and the development of perceived control. Monogr Soc Res Child Dev. 1998;63(2-3):187-204.