# Acknowledgments

We thank the Brain Injury Support Group of Portland, Randall Chesnut, MD, and Mark Ylvisaker, PhD, for their help in preparing this report.