# Discussion

## Conclusions

Our goal was to conduct a systematic review of the literature about child and adolescent TBI oriented around key research questions and to create a tool that could be used in future evidence-based investigations about recovery from TBI in this population. We prepared a matrix to be used to organize research according to the developmental dimensions and age categories addressed by studies. With the assistance of technical experts, we specified key questions about child and adolescent TBI rehabilitation and defined patient populations, interventions, and outcome measures. We compiled and categorized literature from seven databases -- medical, educational, and psychological. We reviewed the strongest of the studies we found containing data about key questions and created an evidence table template for use in future comprehensive studies.

## Quality of the Existing Literature

In general, studies have not been conducted with designs capable of providing evidence for effectiveness of interventions for children and adolescents with TBI. Because the focus of this project was effectiveness, many studies were excluded because they did not provide experimental evidence that could be used to guide practice. The published literature for this topic is primarily exploratory. It provides descriptions of programs that are widely accepted, logical approaches to treatment that have not been validated either through experimental design or in carefully controlled observational studies. The clinical experience represented in the published literature that has guided the design of intervention programs should generate the important hypotheses for controlled studies.

We did not find that assessment is any more standardized in the child and adolescent literature than in studies about adults. Some instruments are designed specifically for children, and others are a child's version of an adult instrument. The vast array of instruments used and their lack of standardization, superimposed upon the complexity of assessing children discussed earlier (Ylvisaker and Gioia, 1998), combine to illustrate the difficulties in assessment of technology for children. We suggest that questions about differences in evaluation between children and adults are premature. The important questions that apply to both adult and pediatric populations are, how and to what extent should assessment be standardized? What cognitive tests are the best predictors of function in life settings?

## Literature Retrieval

The literature on child and adolescent TBI -- found in databases spanning medicine, education, and psychology -- is not organized to facilitate an exhaustive systematic review. However, with respect to four of our five key questions (questions 1, 2, 3, and 5), we believe this review encompasses the relevant studies that contain data from the sources we used. Sources of information regarding special education placement patterns (question 2) other than scientific literature, such as State registries that may account for regional differences and give a more accurate tally of prevalence, need to be accessed and evaluated. Without knowing the extent of TBI in children and adolescents, we cannot estimate the proportion of children who are receiving special education. Without knowing the number of children with TBI who truly need special education, we cannot know if the current referral rate is adequate.

As discussed in Chapter 3 (Results), only 11 of the 61 studies reviewed for question 4 were acquired through applying the search strategy to bibliographic databases. Fifty studies were found from manual methods described in this report. We suspended the search for articles before exhausting all manual methods for acquiring them; therefore, the studies surveyed for question 4 may not constitute the entire body of relevant literature, and a complete, systematic review addressing subquestions within that topic is recommended.

## Recommendations for Including the Developmental Perspective in a Systematic Review

Given the scope and depth of information about development during childhood and adolescence, developmental science must be considered at all junctures of investigation about children and TBI. We developed a matrix to assist in identifying information gaps in the literature that could be addressed in future studies. To help locate these gaps, we identified all studies that spanned only one developmental stage at time of measurement and at time of injury and placed them in the appropriate cells of the developmental matrix from Table 1 (refer to Table 4). In such studies the participants were either selected or sorted in such a way that deficits in one stage of development could be assessed without being confounded with deficits in other stages. The result, shown in Table 4, displays where work that has controlled for the confounding variable of age has been concentrated and where it is lacking.

Table 4. Relevance of selected studies to topics and stages of development

Developmental Category
Chronological developmental stage | Somatic: neuro/hormonal | Somatic: sensorimotor | Intellectual/cognitive | Language | Emotional/behavioral | Social
Infancy: 0 to 24 months | Hudspeth,'90 Thatcher,'91 | | | Thal,'91 Feldman,'92 Marchman,'91
Preschool childhood:2 to 5 years | Hudspeth,'90 Thatcher,'91 | | Anderson,'97 Anderson,'95 Stiles,'96 Stiles,'93 Stiles,'91 Stiles,'88 | Anderson,'97 Thal,'91 Feldman,'92 Reilly,'98 | | Anderson,'97
School-age childhood: 6 to 11 years | Hudspeth,'90 Thatcher,'91 | Thompson,'94 | Anderson,'97,Anderson,'95,Stiles,'93,Kaufmann,'93 Asarnow,'95 Levin,'88,Dennis,'96,Riva,'86 | Anderson,'97 Reilly,'98 Chapman,'98 | Asarnow,'95 | Anderson,'97,Kleinpeter,'76 Asarnow,'95
Puberty and adolescence: 12 to 19 years | Hudspeth,'90 Thatcher,'91 Klonoff,'93 | Thompson,'94 | Kaufmann,'93,Anderson,'95 Asarnow,'95 Klonoff,'93,Levin,'88,Dennis,'96,Riva,'86 | | Segalowitz,'91 Asarnow,'95 Klonoff,'93 | Kleinpeter,'76 Asarnow,'95 Klonoff,'93

An example of a gap in current research on pediatric TBI -- apparent in column one of the matrix in Table 4 -- is the neglect of hormonal action on somatic, emotional, behavioral, and social recovery. Although the three cited articles span all developmental stages, they treat the nervous system only. A developmental perspective, as shown in Table 4, makes a gap in the research immediately apparent.

The matrix in Table 1 was designed as a tool to orient various investigations about children and TBI. It may be too complex for some research questions and too simple for others. If the matrix is to be used, we suggest that investigators consider how it might be altered to better suit their research questions.

The ratings of reviewed studies, shown in Table 3, allow us to display an important trend found in this sample of the literature: the steady increase in the sophistication of the research over the past 2 decades. This is shown graphically in Figure 2, which displays article ratings plotted against the year of publication. The vertical axis shows the rating of each article, with a larger number signifying a higher rank. The trend to higher quality research over time is apparent even in the work of individual authors with multiple publications in those years. The rank-order correlation between ratings and time is .47 (p < .01). In spite of this encouraging trend, significant problems still remain, for example, in sampling, due to the great difficulty of working with clinical populations. Notable exceptions include Bijur's population study (1994); large, multicenter samples (Klonoff, Low, and Clark, 1977; Klonoff, Clark, and Klonoff, 1993; Asarnow, Satz, Light, et al., 1994); and the large single-center, consecutive samples obtained by Dennis (1985), which provide prototypes for designing future research projects.

Figure 2. Rating of pediatric TBI literature on developmental issues